# References

1 US Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Rockville, MD. Agency for Healthcare Research and Quality. 1996.
2 Lamb S. Cultural and moral values surrounding care and (in)dependence in late life: reflections from India in an era of global modernity. Care Manag J. 2005;6:80-89. [pmid: 16544869].
3 Hauer K, Becker C, Lindemann U, Beyer N. Effectiveness of physical training on motor performance and fall prevention in cognitively impaired older persons: a systematic review. Am J Phys Med Rehabil. 2006;85:847-857. [pmid: 16998433].
4 U.S. Census Bureau. U.S. Interim Projections By Age, Sex, Race, and Hispanic Origin: 2000–2050. Suitland, MD. U.S. Census Bureau Population Division. 2004. Accessed at http://www.census.gov/ipc/www/usinterimproj. 8 December 2010.
5 Rubenstein LZ, Josephson KR. The epidemiology of falls and syncope. Clin Geriatr Med. 2002;18:141-158. [pmid: 12180240].
6 O’Loughlin JL, Robitaille Y, Boivin JF, Suissa S. Incidence of and risk factors for falls and injurious falls among the community-dwelling elderly. Am J Epidemiol. 1993;137:342-354. [pmid: 8452142].
7 Alexander BH, Rivara FP, Wolf ME. The cost and frequency of hospitalization for fall-related injuries in older adults. Am J Public Health. 1992;82:1020-1023. [pmid: 1609903].
8 Sterling DA, O’Connor JA, Bonadies J. Geriatric falls: injury severity is high and disproportionate to mechanism. J Trauma. 2001;50:116-119. [pmid: 11231681].
9 Bergeron E, Clement J, Lavoie A, et al. A simple fall in the elderly: not so simple. J Trauma. 2006;60:268-273. [pmid: 16508481].
10 Baker SP, O’Neil B, Ginsburg MJ, et al. The Injury Fact Book. 2nd ed. New York. Oxford University Press. 1992.
11 Fuller GF. Falls in the elderly. Am Fam Physician. 2000;61:2159-2168. [pmid: 10779256].
12 Rubenstein LZ, Josephson KR, Robbins AS. Falls in the nursing home. Ann Intern Med. 1994;121:442-451. [pmid: 8053619].
13 Ferrucci L, Guralnik JM, Studenski S, Fried LP, Cutler GB Jr, Walston JD. Designing randomized, controlled trials aimed at preventing or delaying functional decline and disability in frail, older persons: a consensus report. J Am Geriatr Soc. 2004;52:625-634. [pmid: 15066083].
14 Jorstad-Stein EC, Hauer K, Becker C, et al. Suitability of physical activity questionnaires for older adults in fall-prevention trials: a systematic review. J Aging Phys Act. 2005;13:461-481. [pmid: 16301756].
15 National Center for Injury Prevention and Control. Ten Leading Causes of Death By Age Group, United States–2003. Atlanta, GA. Centers for Disease Control and Prevention. 2007.
16 Centers for Disease Control and Prevention. Self-reported falls and fall-related injuries among persons aged ≥65 years—United States, 2006. MMWR Morb Mortal Wkly Rep. 2008;57:225-229. [pmid: 18322444].
17 Sattin RW, Lambert Huber DA, DeVito CA, et al. The incidence of fall injury events among the elderly in a defined population. Am J Epidemiol. 1990;131:1028-1037. [pmid: 2343855].
18 Centers for Disease Control and Prevention. Fatalities and injuries from falls among older adults—United States, 1993–2003 and 2001–2005. MMWR Morb Mortal Wkly Rep. 2006;55:1221-1224. [pmid: 17108890].
19 Centers for Disease Control. Public health surveillance of 1990 injury control objectives for the nation. MMWR CDC Surveill Summ. 1988;37:1-68.
20 Jensen GF, Christiansen C, Boesen J, Hegedus V, Transbol I. Epidemiology of postmenopausal spinal and long bone fractures: a unifying approach to postmenopausal osteoporosis. Clin Orthop Relat Res. 1982:75-81.
21 Cummings SR, Kelsey JL, Nevitt MC, O’Dowd KJ. Epidemiology of osteoporosis and osteoporotic fractures. Epidemiol Rev. 1985;7:178-208. [pmid: 3902494].
22 Magaziner J, Simonsick EM, Kashner TM, Hebel JR, Kenzora JE. Survival experience of aged hip fracture patients. Am J Public Health. 1989;79:274-278. [pmid: 2916711].
23 Lu-Yao GL, Baron JA, Barrett JA, Fisher ES. Treatment and survival among elderly Americans with hip fractures: a population-based study. Am J Public Health. 1994;84:1287-1291. [pmid: 8059887].
24 Lachman ME, Howland J, Tennstedt S, Jette A, Assmann S, Peterson EW. Fear of falling and activity restriction: the Survey of Activities and Fear of Falling in the Elderly (SAFE). J Gerontol B Psychol Sci Soc Sci. 1998;53:43-50.
25 Cumming RG, Salkeld G, Thomas M, Szonyi G. Prospective study of the impact of fear of falling on activities of daily living, SF-36 scores, and nursing home admission. J Gerontol A Biol Sci Med Sci. 2000;55:M299-M305. [pmid: 10819321].
26 Friedman SM, Munoz B, West SK, Rubin GS, Fried LP. Falls and fear of falling: which comes first? A longitudinal prediction model suggests strategies for primary and secondary prevention. J Am Geriatr Soc. 2002;50:1329-1335. [pmid: 12164987].
27 Roudsari BS, Ebel BE, Corso PS, Molinari NA, Koepsell TD. The acute medical care costs of fall-related injuries among US older adults. Injury. 2005;36:1316-1322. [pmid: 16214476].
28 American Geriatrics Society, British Geriatrics Society, American Academy of Orthopaedic Surgeons Panel on Falls Prevention. Guideline for the prevention of falls in older persons. J Am Geriatr Soc. 2001;49:664-672. [pmid: 11380764].
29 Englander F, Hodson TJ, Terregrossa RA. Economic dimensions of slip and fall injuries. J Forensic Sci. 1996;41:733-746. [pmid: 8789837].
30 Kannus P, Sievanen H, Palvanen M, Jarvinen T, Parkkari J. Prevention of falls and consequent injuries in elderly people. Lancet. 2005;366:1885-1893. [pmid: 16310556].
31 Tinetti ME. Preventing falls in elderly persons. N Engl J Med. 2003;348:42-49. [pmid: 12510042].
32 Connell BR, Wolf SL. Atlanta FICSIT Group. Environmental and behavioral circumstances associated with falls at home among healthy elderly individuals. Arch Phys Med Rehabil. 1997;78:179-186. [pmid: 9041900].
33 Gill T, Taylor AW, Pengelly A. A population-based survey of factors relating to the prevalence of falls in older people. Gerontol. 2005;51:340-345.
34 Tinetti ME, Doucette JT, Claus EB. The contribution of predisposing and situational risk factors to serious fall injuries. J Am Geriatr Soc. 1995;43:1207-1213. [pmid: 7594153].
35 French DD, Campbell R, Spehar A, Cunningham F, Foulis P. Outpatient medications and hip fractures in the US: a national veterans study. Drugs Aging. 2005;22:877-885. [pmid: 16245960].
36 Li W, Keegan TH, Sternfeld B, Sidney S, Quesenberry CP Jr, Kelsey JL. Outdoor falls among middle-aged and older adults: a neglected public health problem. Am J Public Health. 2006;96:1192-1200. [pmid: 16735616].
37 Nguyen ND, Pongchaiyakul C, Center JR, Eisman JA, Nguyen TV. Identification of high-risk individuals for hip fracture: a 14-year prospective study. J Bone Miner Res. 2005;20:1921-1928. [pmid: 16234964].
38 Sattin RW, Rodriguez JG, DeVito CA, Wingo PA. Study to Assess Falls Among the Elderly (SAFE) Group. Home environmental hazards and the risk of fall injury events among community-dwelling older persons. J Am Geriatr Soc. 1998;46:669-676. [pmid: 9625180].
39 Stalenhoef PA, Diederiks JP, Knottnerus JA, Kester AD, Crebolder HF. A risk model for the prediction of recurrent falls in community-dwelling elderly: a prospective cohort study. J Clin Epidemiol. 2002;55:1088-1094. [pmid: 12507672].
40 Stevens JA. Falls among older adults—risk factors and prevention strategies. J Safety Res. 2005;36:409-411. [pmid: 16242155].
41 Steinweg KK. The changing approach to falls in the elderly. Am Fam Physician. 1997;56:1815-1823. [pmid: 9371011].
42 Leipzig RM, Cumming RG, Tinetti ME. Drugs and falls in older people: a systematic review and meta-analysis, I: psychotropic drugs. J Am Geriatr Soc. 1999;47:30-39. [pmid: 9920227].
43 Leipzig RM, Cumming RG, Tinetti ME. Drugs and falls in older people: a systematic review and meta-analysis, II: cardiac and analgesic drugs. J Am Geriatr Soc. 1999;47:40-50. [pmid: 9920228].
44 Kelly KD, Pickett W, Yiannakoulias N, et al. Medication use and falls in community-dwelling older persons. Age Ageing. 2003;32:503-509. [pmid: 12957999].
45 National Institute for Clinical Excellence. Falls: The Assessment and Prevention of Falls in Older People. Clinical Guideline No. 21. London. National Institute for Clinical Excellence. 2004. Accessed at http://www.nice.org.uk/nicemedia/live/10956/29583/29583.pdf. 8 December 2010.
46 National Center for Injury Prevention and Control. What You Can Do to Prevent Falls. Atlanta, GA. Centers for Disease Control and Prevention. 2009. Accessed at http://www.cdc.gov/HomeandRecreationalSafety/Falls/WhatYouCanDoToPreventFalls.html. 8 December 2010.
47 Rubenstein LZ, Solomon DH, Roth CP, et al. Detection and management of falls and instability in vulnerable elders by community physicians. J Am Geriatr Soc. 2004;52:1527-1531. [pmid: 15341556].
48 Wenger NS, Solomon DH, Roth CP, et al. The quality of medical care provided to vulnerable community-dwelling older patients. Ann Intern Med. 2003;139:740-747. [pmid: 14597458].
49 Chou WC, Tinetti ME, King MB, Irwin K, Fortinsky RH. Perceptions of physicians on the barriers and facilitators to integrating fall risk evaluation and management into practice. J Gen Intern Med. 2006;21:117-122. [pmid: 16336618].
50 Fortinsky RH, Iannuzzi-Sucich M, Baker DI, et al. Fall-risk assessment and management in clinical practice: views from healthcare providers. J Am Geriatr Soc. 2004;52:1522-1526. [pmid: 15341555].
51 Tinetti ME, Gordon C, Sogolow E, Lapin P, Bradley EH. Fall-risk evaluation and management: challenges in adopting geriatric care practices. Gerontologist. 2006;46:717-725. [pmid: 17169927].
52 Beswick AD, Rees K, Dieppe P, et al. Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis. Lancet. 2008;371:725-735. [pmid: 18313501].
53 Gillespie LD, Robertson MC, Gillespie WJ, et al. Interventions for preventing falls in older people living in the community. Cochrane Database Syst Rev. 2009:CD007146.
54 Gillespie LD, Gillespie WJ, Robertson MC, Lamb SE, Cumming RG, Rowe BH. Interventions for preventing falls in elderly people. Cochrane Database Syst Rev. 2003:CD000340.
55 Chang JT, Morton SC, Rubenstein LZ, et al. Interventions for the prevention of falls in older adults: systematic review and meta-analysis of randomised clinical trials. BMJ. 2004;328:680. [pmid: 15031239].
56 Parker MJ, Gillespie WJ, Gillespie LD. Hip protectors for preventing hip fractures in older people. Cochrane Database Syst Rev. 2005:CD001255.
57 Gates S, Fisher JD, Cooke MW, Carter YH, Lamb SE. Multifactorial assessment and targeted intervention for preventing falls and injuries among older people in community and emergency care settings: systematic review and meta-analysis. BMJ. 2008;336:130-133. [pmid: 18089892].
58 Sherrington C, Whitney JC, Lord SR, Herbert RD, Cumming RG, Close JC. Effective exercise for the prevention of falls: a systematic review and meta-analysis. J Am Geriatr Soc. 2008;56:2234-2243. [pmid: 19093923].
59 Barton MB, Miller T, Wolff T, et al. How to read the new recommendation statement: methods update from the U.S. Preventive Services Task Force. Ann Intern Med. 2007;147:123-127. [pmid: 17576997].
60 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
61 Day L, Fildes B, Gordon I, Fitzharris M, Flamer H, Lord S. Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325:128. [pmid: 12130606].
62 Lord SR, Tiedemann A, Chapman K, et al. The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53:1296-1304. [pmid: 16078954].
63 Campbell AJ, Robertson MC, La Grow SJ, et al. Randomised controlled trial of prevention of falls in people aged ≥75 with severe visual impairment: the VIP trial. BMJ. 2005;331:817. [pmid: 16183652].
64 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-188. [pmid: 3802833].
65 Laird RD, Studenski S, Perera S, Wallace D. Fall history is an independent predictor of adverse health outcomes and utilization in the elderly. Am J Manag Care. 2001;7:1133-1138. [pmid: 11767299].
66 Cameron ID, Cumming RG, Kurrle SE, et al. A randomised trial of hip protector use by frail older women living in their own homes. Inj Prev. 2003;9:138-141. [pmid: 12810740].
67 Porthouse J, Cockayne S, King C, et al. Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 2005;330:1003. [pmid: 15860827].
68 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. 2004;23:1351-1375. [pmid: 15116347].
69 Tinetti ME, Baker DI, McAvay G, et al. A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331:821-827. [pmid: 8078528].
70 Stevens M, Holman CD, Bennett N, de Klerk N. Preventing falls in older people: outcome evaluation of a randomized controlled trial. J Am Geriatr Soc. 2001;49:1448-1455. [pmid: 11890582].
71 van Haastregt JC, Diederiks JP, van Rossum E, de Witte LP, Voorhoeve PM, Crebolder HF. Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321:994-998. [pmid: 11039967].
72 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21:1539-1558. [pmid: 12111919].
73 Egger M, Davey SG, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-634. [pmid: 9310563].
74 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005;58:894-901. [pmid: 16085192].
75 Spice CL, Morotti W, George S, et al. The Winchester Falls project: a randomised controlled trial of secondary prevention of falls in older people. Age Ageing. 2009;38:33-40. [pmid: 18829689].
76 Davison J, Bond J, Dawson P, Steen IN, Kenny RA. Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention—a randomised controlled trial. Age Ageing. 2005;34:162-168. [pmid: 15716246].
77 Lightbody E, Watkins C, Leathley M, Sharma A, Lye M. Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age Ageing. 2002;31:203-210. [pmid: 12006310].
78 Wagner EH, LaCroix AZ, Grothaus L, et al. Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84:1800-1806. [pmid: 7977921].
79 Elley CR, Robertson MC, Garrett S, et al. Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56:1383-1389. [pmid: 18808597].
80 Close J, Ellis M, Hooper R, Glucksman E, Jackson S, Swift C. Prevention of Falls in the Elderly Trial (PROFET): a randomised controlled trial. Lancet. 1999;353:93-97. [pmid: 10023893].
81 Newbury JW, Marley JE, Beilby JJ. A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 2001;175:104-107. [pmid: 11556409].
82 Hogan DB, MacDonald FA, Betts J, et al. A randomized controlled trial of a community-based consultation service to prevent falls. CMAJ. 2001;165:537-543. [pmid: 11563205].
83 Shumway-Cook A, Silver I, Mary L, York S, Cummings P, Koepsell T. Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol. 2007;62:1420-1427.
84 Hendriks MR, Bleijlevens MH, van Haastregt JC, et al. Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56:1390-1397. [pmid: 18662214].
85 Birks YF, Porthouse J, Addie C, et al. Randomized controlled trial of hip protectors among women living in the community. Osteoporos Int. 2004;15:701-706. [pmid: 14997286].
86 Gallagher JC, Fowler SE, Detter JR, Sherman SS. Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 2001;86:3618-3628. [pmid: 11502787].
87 Harwood RH, Foss AJ, Osborn F, Gregson RM, Zaman A, Masud T. Falls and health status in elderly women following first eye cataract surgery: a randomised controlled trial. Br J Ophthalmol. 2005;89:53-59. [pmid: 15615747].
88 Gray-Donald K, Payette H, Boutier V. Randomized clinical trial of nutritional supplementation shows little effect on functional status among free-living frail elderly. J Nutr. 1995;125:2965-2971. [pmid: 7500174].
89 Prince RL, Austin N, Devine A, Dick IM, Bruce D, Zhu K. Effects of ergocalciferol added to calcium on the risk of falls in elderly high-risk women. Arch Intern Med. 2008;168:103-108. [pmid: 18195202].
90 Cumming RG, Ivers R, Clemson L, et al. Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55:175-181. [pmid: 17302652].
91 Foss AJ, Harwood RH, Osborn F, Gregson RM, Zaman A, Masud T. Falls and health status in elderly women following second eye cataract surgery: a randomised controlled trial. Age Ageing. 2006;35:66-71. [pmid: 16364936].
92 Dukas L, Bischoff HA, Lindpaintner LS, et al. Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc. 2004;52:230-236. [pmid: 14728632].
93 Luukinen H, Lehtola S, Jokelainen J, Vaananen-Sainio R, Lotvonen S, Koistinen P. Pragmatic exercise-oriented prevention of falls among the elderly: a population-based, randomized, controlled trial. Prev Med. 2007;44:265-271. [pmid: 17174387].
94 Green J, Forster A, Bogle S, Young J. Physiotherapy for patients with mobility problems more than 1 year after stroke: a randomised controlled trial. Lancet. 2002;359:199-203. [pmid: 11812553].
95 Robertson MC, Devlin N, Gardner MM, Campbell AJ. Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls, 1: randomised controlled trial. BMJ. 2001;322:697-701. [pmid: 11264206].
96 Ashburn A, Fazakarley L, Ballinger C, Pickering R, McLellan LD, Fitton C. A randomised controlled trial of a home based exercise programme to reduce the risk of falling among people with Parkinson’s disease. J Neurol Neurosurg Psychiatry. 2007;78:678-684. [pmid: 17119004].
97 Campbell AJ, Robertson MC, Gardner MM, Norton RN, Tilyard MW, Buchner DM. Randomised controlled trial of a general practice programme of home based exercise to prevent falls in elderly women. BMJ. 1997;315:1065-1069. [pmid: 9366737].
98 Pfeifer M, Begerow B, Minne HW, Abrams C, Nachtigall D, Hansen C. Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res. 2000;15:1113-1118. [pmid: 10841179].
99 Pfeifer M, Begerow B, Minne HW, Suppan K, Fahrleitner-Pammer A, Dobnig H. Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int. 2009;20:315-322. [pmid: 18629569].
100 Rubenstein LZ, Josephson KR, Trueblood PR, et al. Effects of a group exercise program on strength, mobility, and falls among fall-prone elderly men. J Gerontol A Biol Sci Med Sci. 2000;55:M317-M321. [pmid: 10843351].
101 Coleman EA, Grothaus LC, Sandhu N, Wagner EH. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. 1999;47:775-783. [pmid: 10404919].
102 Dhesi JK, Jackson SH, Bearne LM, et al. Vitamin D supplementation improves neuromuscular function in older people who fall. Age Ageing. 2004;33:589-595. [pmid: 15501836].
103 Clemson L, Cumming RG, Kendig H, Swann M, Heard R, Taylor K. The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52:1487-1494. [pmid: 15341550].
104 Barnett A, Smith B, Lord SR, Williams M, Baumand A. Community-based group exercise improves balance and reduces falls in at-risk older people: a randomised controlled trial. Age Ageing. 2003;32:407-414. [pmid: 12851185].
105 Buchner DM, Cress ME, de Lateur BJ, et al. The effect of strength and endurance training on gait, balance, fall risk, and health services use in community-living older adults. J Gerontol A Biol Sci Med Sci. 1997;52:M218-M224. [pmid: 9224433].
106 Buchner DM, Cress ME, Wagner EH, de Lateur BJ, Price R, Abrass IB. The Seattle FICSIT/MoveIt study: the effect of exercise on gait and balance in older adults. J Am Geriatr Soc. 1993;41:321-325. [pmid: 8440857].
107 Wolf SL, Barnhart HX, Kutner NG, McNeely E, Coogler C, Xu T. Atlanta FICSIT Group. Reducing frailty and falls in older persons: an investigation of Tai Chi and computerized balance training. J Am Geriatr Soc. 1996;44:489-497. [pmid: 8617895].
108 Lord SR, Ward JA, Williams P, Strudwick M. The effect of a 12-month exercise trial on balance, strength, and falls in older women: a randomized controlled trial. J Am Geriatr Soc. 1995;43:1198-1206. [pmid: 7594152].
109 Ganz DA, Bao Y, Shekelle PG, Rubenstein LZ. Will my patient fall?. JAMA. 2007;297:77-86. [pmid: 17200478].
110 Buchner DM, Hornbrook MC, Kutner NG, et al. Development of the common data base for the FICSIT trials. J Am Geriatr Soc. 1993;41:297-308. [pmid: 8440854].
111 Bischoff-Ferrari HA, Orav EJ, Dawson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Arch Intern Med. 2006;166:424-430. [pmid: 16505262].
112 Campbell AJ, Robertson MC, Gardner MM, Norton RN, Buchner DM. Psychotropic medication withdrawal and a home-based exercise program to prevent falls: a randomized, controlled trial. J Am Geriatr Soc. 1999;47:850-853. [pmid: 10404930].
113 Morgan RO, Virnig BA, Duque M, Abdel ME, DeVito CA. Low-intensity exercise and reduction of the risk for falls among at-risk elders. J Gerontol A Biol Sci Med Sci. 2004;59:1062-1067. [pmid: 15528779].
114 Logghe IH, Zeeuwe PE, Verhagen AP, et al. Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. J Am Geriatr Soc. 2009;57:70-75. [pmid: 19054193].
115 Voukelatos A, Cumming RG, Lord SR, Rissel C. A randomized, controlled trial of Tai Chi for the prevention of falls: the Central Sydney Tai Chi trial. J Am Geriatr Soc. 2007;55:1185-1191. [pmid: 17661956].
116 Li F, Harmer P, Fisher KJ, et al. Tai Chi and fall reductions in older adults: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2005;60:187-194. [pmid: 15814861].
117 McCarney R, Warner J, Iliffe S, van HR, Griffin M, Fisher P. The Hawthorne Effect: a randomised, controlled trial. BMC Med Res Methodol. 2007;7:30. [pmid: 17608932].
118 Li F, Harmer P, Fisher KJ, McAuley E. Tai Chi: improving functional balance and predicting subsequent falls in older persons. Med Sci Sports Exerc. 2004;36:2046-2052. [pmid: 15570138].
119 Nelson ME, Layne JE, Bernstein MJ, et al. The effects of multidimensional home-based exercise on functional performance in elderly people. J Gerontol A Biol Sci Med Sci. 2004;59:154-160. [pmid: 14999030].
120 Milne AC, Avenell A, Potter J. Meta-analysis: protein and energy supplementation in older people. Ann Intern Med. 2006;144:37-48. [pmid: 16389253].
121 Pahor M, Blair SN, Espeland M, et al. Effects of a physical activity intervention on measures of physical performance: results of the Lifestyle Interventions and Independence for Elders Pilot (LIFE-P) study. J Gerontol A Biol Sci Med Sci. 2006;61:1157-1165. [pmid: 17167156].
122 Perell KL, Nelson A, Goldman RL, Luther SL, Prieto-Lewis N, Rubenstein LZ. Fall risk assessment measures: an analytic review. J Gerontol. 2001;56A:M761-M766.
123 Hornbrook MC, Stevens VJ, Wingfield DJ, Hollis JF, Greenlick MR, Ory MG. Preventing falls among community-dwelling older persons: results from a randomized trial. Gerontologist. 1994;34:16-23. [pmid: 8150304].
124 Spivack BS. Preventing falls: direct intervention is needed. BMJ. 2008;336:343. [pmid: 18276673].
125 Tinetti ME. Multifactorial fall-prevention strategies: time to retreat or advance. J Am Geriatr Soc. 2008;56:1563-1565. [pmid: 18808601].
126 Cranney A, Horsley T, O’Donnell S, et al. Effectiveness and Safety of Vitamin D in Relation to Bone Health Evidence Report/Technology Assessment No 158. Rockville, MD. Agency for Healthcare Research and Quality. 2007.
127 Jackson RD, LaCroix AZ, Gass M, et al. Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med. 2006;354:669-683. [pmid: 16481635].
128 Chung M, Balk EM, Brendel M, ET AL. Vitamin D and Calcium: Systematic Review of Health Outcomes Evidence Report/Technology Assessment No 183. Rockville, MD. Agency for Healthcare Research and Quality. 2009.
129 Institute of Medicine. Dietary Reference Intakes for Calcium and Vitamin D. Washington, DC. National Academies Pr. 2010.
130 Chou R, Dana T, Bougastos C. Screening older adults for impaired visual acuity: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;151:44-58. [pmid: 19581646].
131 Tinetti ME. Prevention of falls and fall injuries in elderly persons: a research agenda. Prev Med. 1994;23:756-762. [pmid: 7845954].
132 Pfeifer M, Bergerow B, Minne HW. Vitamin D and muscle function. Osteoporos Int. 2002;13:187-194. [pmid: 11991436].
133 Tinetti ME, Speechley M, Ginter SF. Risk factors for falls among elderly persons living in the community. N Engl J Med. 1988;319:1701-1707. [pmid: 3205267].
134 D’Agostino RB Sr, Vasan RS, Pencina MJ, et al. General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008;117:743-753. [pmid: 18212285].
135 Tromp AM, Pluijm SM, Smit JH, Deeg DJ, Bouter LM, Lips P. Fall-risk screening test: a prospective study on predictors for falls in community-dwelling elderly. J Clin Epidemiol. 2001;54:837-844. [pmid: 11470394].
136 Morris R, Harwood RH, Baker R, Sahota O, Armstrong S, Masud T. A comparison of different balance tests in the prediction of falls in older women with vertebral fractures: a cohort study. Age Ageing. 2007;36:78-83. [pmid: 17264139].
137 Stalenhoef PA, Diederiks JP, Knottnerus JA, de Witte LP, Crebolder HF. The construction of a patient record-based risk model for recurrent falls among elderly people living in the community. Fam Pract. 2000;17:490-496. [pmid: 11120721].
138 Means KM, Rodell DE, O’Sullivan PS. Obstacle course performance and risk of falling in community-dwelling elderly persons. Arch Phys Med Rehabil. 1998;79:1570-1576. [pmid: 9862303].
139 Scott V, Votova K, Scanlan A, Close J. Multifactorial and functional mobility assessment tools for fall risk among older adults in community, home-support, long-term and acute care settings. Age Ageing. 2007;36:130-139. [pmid: 17293604].
140 Rizzo JA, Baker DI, McAvay G, Tinetti ME. The cost-effectiveness of a multifactorial targeted prevention program for falls among community elderly persons. Med Care. 1996;34:954-969. [pmid: 8792783].
141 Robertson MC, Devlin N, Scuffham P, Gardner MM, Buchner DM, Campbell AJ. Economic evaluation of a community based exercise programme to prevent falls. J Epidemiol Community Health. 2001;55:600-606. [pmid: 11449021].
142 Sach TH, Foss AJ, Gregson RM, et al. Falls and health status in elderly women following first eye cataract surgery: an economic evaluation conducted alongside a randomised controlled trial. Br J Ophthalmol. 2007;91:1675-1679. [pmid: 17585002].
143 Robertson MC, Gardner MM, Devlin N, McGee R, Campbell AJ. Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls, 2: controlled trial in multiple centres. BMJ. 2001;322:701-704. [pmid: 11264207].
144 Ganz DA, Higashi T, Rubenstein LZ. Monitoring falls in cohort studies of community-dwelling older people: effect of the recall interval. J Am Geriatr Soc. 2005;53:2190-2194. [pmid: 16398908].
145 Lamb SE, Jorstad-Stein EC, Hauer K, Becker C. Prevention of Falls Network Europe Outcomes Consensus Group. Development of a common outcome data set for fall injury prevention trials: the Prevention of Falls Network Europe consensus. J Am Geriatr Soc. 2005;53:1618-1622. [pmid: 16137297].
146 Agostini JV, Tinetti ME. Drugs and falls: rethinking the approach to medication risk in older adults. J Am Geriatr Soc. 2002;50:1744-1745. [pmid: 12366634].
147 Gillespie L. Preventing falls in elderly people. BMJ. 2004;328:653-654. [pmid: 15031213].
148 Thompson SG. Why and how sources of heterogeneity should be investigated, Systematic Reviews in Health Care: Meta-Analysis in Context. Egger M, Davey SG, Altman DG, editors. London. BMJ. 2001:157-175.
149 Agrawal Y, Carey JP, la Santina CC, Schubert MC, Minor LB. Disorders of balance and vestibular function in US adults: data from the National Health and Nutrition Examination Survey, 2001–2004. Arch Intern Med. 2009;169:938-944. [pmid: 19468085].
150 Deary IJ, Whalley LJ, Batty GD, Starr JM. Physical fitness and lifetime cognitive change. Neurology. 2006;67:1195-1200. [pmid: 17030752].
151 Katz S, Downs TD, Cash HR, Grotz RC. Progress in development of the index of ADL. Gerontologist. 1970;10:20-30. [pmid: 5420677].
152 Mahoney FI, Barthel DW. Functional evaluation: the Bathel Index. Md State Med J. 1965;14:61-65. [pmid: 14258950].
153 Berg KO, Wood-Dauphinee SL, Williams JI, Maki B. Measuring balance in the elderly: validation of an instrument. Can J Public Health. 1992;83(Suppl 2):S7-S11. [pmid: 1468055].
154 Brooks R. EuroQol: the current state of play. Health Policy. 1996;37:53-72. [pmid: 10158943].
155 Tinetti ME, Richman D, Powell L. Falls efficacy as a measure of fear of falling. J Gerontol. 1990;45:239-243.
156 Duncan PW, Weiner DK, Chandler J, Studenski S. Functional reach: a new clinical measure of balance. J Gerontol. 1990;45:M192-M197. [pmid: 2229941].
157 Lawton MP, Brody EM. Assessment of older people: self-maintaining and instrumental activities of daily living. Gerontologist. 1969;9:179-186. [pmid: 5349366].
158 Ware JJ, Kosinski M, Keller SD. A 12-item Short-Form Health Survey: construction of scales and preliminary tests of reliability and validity. Med Care. 1996;34:220-233. [pmid: 8628042].
159 Ware JE, Sherbourne CD. The MOS 36-item Short-Form Health Survey (SF-36), 1: conceptual framework and item selection. Med Care. 1992;30:473-483. [pmid: 1593914].
160 Podsiadlo D, Richardson S. The timed “Up & Go” : a test of basic functional mobility for frail elderly persons. J Am Geriatr Soc. 1991;39:142-148. [pmid: 1991946].
161 Tinetti ME. Performance-oriented assessment of mobility problems in elderly patients. J Am Geriatr Soc. 1986;34:119-126. [pmid: 3944402].
162 Tinetti ME, Baker DI, Garrett PA, Gottschalk M, Koch ML, Horwitz RI. Yale FICSIT: risk factor abatement strategy for fall prevention. J Am Geriatr Soc. 1993;41:315-320. [pmid: 8440856].
163 Dawson-Hughes B, Harris SS, Krall EA, Dallal GE. Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. 1997;337:670-676. [pmid: 9278463].