# Results

To be included in this review, an intervention was required to measure falls as a primary or secondary outcome. Thus, the 36 unique trials (39 articles) reviewed for KQ 1 are a subset of the 47 trials (51 articles) reviewed for KQ 2. Falling was assessed in a variety of ways in these intervention studies (e.g., number of fallers, fall rate, time to first fall, and number of frequent fallers). Number of fallers is the most consistent measure of falling across all studies with the remaining measures used selectively. To enhance comparability, we primarily discuss number of fallers (risk for falling) in the results below. We also reported fall rate if data were available.

## KQ 1 Is There Direct Evidence That Primary Care Interventions Reduce Fall-Related Injury, Improve Quality of Life, Reduce Disability, or Reduce Mortality When Used Alone or in Combination to Reduce Falls in Community-Dwelling Older Adults?

Thirty-six of the 47 primary care interventions to prevent falling included in this review reported data on at least one health outcome.

Three studies67,75,76 pre-specified mortality as a health outcome and reported no reduction in mortality associated with the intervention. All-cause mortality was assessed in 26 studies as part of attrition (10 multifactorial assessment and management,62,69,77–84 10 single clinical treatment,66,67,85–92 and six exercise/physical therapy63,93–97). We found no evidence that primary care interventions had a significant impact on all-cause mortality after 3 to 36 months (Figure 2). The pooled relative risk for all-cause mortality was 0.90 (95% CI, 0.80 to 1.02) with low statistical heterogeneity (I^2^=0%). Results from the fixed effect model were similar. Data that would allow us to evaluate fall-related mortality were not available in the evaluated studies. The results do not rule out the possibility of a longer-term influence on all-cause mortality or fall-related mortality. Given that all-cause mortality was not identified as a health outcome in most studies that reported deaths, mortality is not discussed further as part of the health outcome results.

Figure 2 Pooled Analysis: All-Cause Mortality of Primary Care Interventions to Prevent Falls (KQ1)

Figure 2 displays a forest plot of all falls prevention trials reporting between-group differences in all-cause mortality. Data for the figure are presented alongside the forest plot. The pooled relative risk for all-cause mortality was 0.90 (95% CI, 0.80 to 1.02), with low statistical heterogeneity (chi-square=0%).

The evidence for fall-related fracture includes 16 unique trials assessing multifactorial assessment and management,69,75,76,82 hip protectors,66,85 correction of vision-related defects,87,90,91 vitamin D supplementation,67,86,89,98,99 and exercise or physical therapy interventions.96,100 Quality of life was reported in 12 unique trials assessing multifactorial assessment and management,79,81,84,101 correction of vision-related defects,87,91 vitamin D supplementation,102 clinical education/behavioral counseling,103 and exercise or physical therapy.96,100,104–106 Disability was reported in 13 unique trials assessing multifactorial assessment and management,75,77–81,84 correction of vision-related defects,87,91 and exercise or physical therapy.94,97,105–107 Results from these trials are discussed by intervention type. Given that few studies reported each of these health outcomes, the results are not robust. Furthermore, these results may reflect selective reporting and should be interpreted with caution.

### Multifactorial Assessment and Management

Summary of findings. Of 14 multifactorial assessment and management interventions, 11 fair- to good-quality trials reported health outcomes identified for inclusion in this review. These studies included measures of fall-related fractures,69,75,76,82 quality of life,79,81,84,101 and disability (Table 2).75,77–81,84 All of these trials were conducted in high-risk populations; in seven trials participants were selected based solely on history of a fall75–77,79,80,82,84 and in three trials, based on presence of at least one of several fall-related risk factors (including history of a fall).69,78,81 While these studies provided no evidence that multifactorial assessment and management interventions improved quality of life, they provided limited evidence of reduced fall-related fractures and reduced disability.

Table 2 Study Characteristics of Multifactorial Clinical Assessment Interventions to Reduce Fall-Related Injury, Improve Quality of Life, or Reduce Disability (KQ1)

For more details about each study, see Table 7 and Appendix C Table 1

Study reference, Setting, USPSTF quality rating | Fall-related injury | Quality of life | | | Disability
Comprehensive intervention (assessment + multifactorial treatment)
Close 1999^80^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | ADL: Mean change in Barthel score at 12 months IG: −1.4 CG: −0.4 p=0.0001
Hogan 2001^82^ Canada Fair | Fracture rate per person-year: NR # fractures: 5 fractures (3 femoral) in CG, 3 (2 femoral) in IG # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | ADL: NR IADL: NR
Tinetti 1994^69^ Tinetti 1993^162^ Buchner 1993^110^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: IG: 4 (3%) CG: 7 (5%) p=NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | ADL: NR IADL: NR
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | ADL: Medical Outcomes Study physical function score
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | (%) | IG | CG
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Change from BL to Year 1
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Sustained High Function | 27 | 24
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Sustained Ltd Function | 48 | 45
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Improved | 10 | 11
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Worsened | 15 | 20*
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Change from BL to Year 2
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Sustained High Function | 25 | 24
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Sustained Ltd Function | 47 | 44
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Improved | 11 | 11
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Worsened | 17 | 21
Wagner 1994^78^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | *p≤0.01 for difference with IG
Targeted intervention (assessment + referral and targeted intervention or education)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: Physical component summary score, Median (IQR) | | | ADL: Nottingham Extended Activities of Daily Living (range 0–22) Median ADL score (IQR)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | Baseline | Followup | | Baseline | Followup
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | IG: | 35.4 (29.4–43.8) | 39.4 (29.9–46.0) | IG: | 19.0 (18.0–21.0) | 18.0 (17.0–20.0)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | CG: | 36.5 (29.7–43.9) | 37.2 (29.0–45.4) | CG: | 19.0 (16.0–2.0) | 19.0 (17.0–20.0)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | p =0.25 Mental component summary score, Median (IQR) | | | P=0.43 (group comparison at 12 months controlling for baseline value)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | Baseline | Followup | P=0.43 (group comparison at 12 months controlling for baseline value)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | | P=0.43 (group comparison at 12 months controlling for baseline value)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | IG : | 57.5 (50.1–61.8) | 56.7 (48.8–61.3) | P=0.43 (group comparison at 12 months controlling for baseline value)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | CG: | 58.7 (53.1–62.5) | 57.7(49.4–61.9) | P=0.43 (group comparison at 12 months controlling for baseline value)
Elley 2008^79^ New Zealand Good | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | p=0.40 EuroQol: NR | | | P=0.43 (group comparison at 12 months controlling for baseline value)
Hendriks 2008^84^ Netherlands Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: Mean (SD) at 12 months IG: 0.70 (0.25) CG: 0.71 (0.28) Difference (95% CI) (from multiple linear regression): −0.012 (−0.06 to 0.03) p=0.59 | | | ADL & IADL: Grogan Activity Restriction Scale (range 11–44) Mean ADL/IADL score (SD) at 12-months IG: 15.2 (1.8) CG: 15.4 (5.6) Difference (95% CI) (from multiple linear regression): −0.03 (−0.64 to 0.64) p=0.94
Referral only intervention (assessment + referral only)
Lightbody 2002^77^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | ADL: Barthel Index
Lightbody 2002^77^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Mean (SD) | IG | CG
Lightbody 2002^77^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR
Lightbody 2002^77^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | Baseline | 19.0 (2.0) | 19 (2.3)
Lightbody 2002^77^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | 6-mo follow-up | 18.5 (2.37) | 17.8 (3.6)
Lightbody 2002^77^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | p<0.04
Newbury 2001^81^ Australia Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NS EuroQol: NR | | | ADL: NS IADL: NR

# number; % – percent; SF-36 – 36-item Short-Form Health Survey; SF-12 – 12-item Short-Form Health Survey; NR – not reported; NS – not significant; ADL – activities of daily living; IADL – instrumental activities of daily living; IQR – interquartile range; SD – standard deviation; BL – baseline; Ltd – limited

NOTE: Lord 2005^62^ and Shumway-Cook 2007^83^ report mortality data only, see Appendix C Table 1 for details.

The four fair-quality trials (n=1,282) that assessed fall-related fractures among older adults showed a nonsignificant reduced risk for fracture associated with multifactorial assessment and management.69,75,76,82 The pooled relative risk was 0.83 (95% CI, 0.61 to 1.14) with low heterogeneity (I^2^=0%). In one trial of a multifactorial intervention, Tinetti and colleagues69 reported fractures in four people out of 147 in the intervention group, compared with seven people out of 144 in the control group, during the 12-month followup period. We calculated a relative risk of 0.49 (95% CI, 0.09 to 2.58) for this trial. Hogan and colleagues reported fractures in three out of 75 in the intervention group, compared with five out of 77 in the control group, during the 12-month followup period. We calculated a relative risk of 0.62 (95% CI, 0.15 to 2.49) for this trial. Davison and colleagues76 reported fractures in six intervention subjects (4%) compared with 11 (7%) in controls during 12 months of followup (RR, 0.53 [95% CI, 0.20 to 1.39]). Spice and colleagues75 reported fractures in 40 of the subjects in the more intensive intervention group (19%) compared with 35 (22%) of the controls (OR, 0.90 [95% CI, 0.61 to 1.34]). These studies were not powered to evaluate a difference in fracture rate. These studies relied on self-reports of fall-related fractures using monthly calendars with followup phone calls to fallers to assess injuries resulting from the fall.

None of the four fair- to good-quality multifactorial assessment and management trials (n=914) in older adults reported a significant change in quality of life after 12 months of followup.79,81,84,101 Three trials assessed change in self-reported quality of life using the SF-36 instrument,79,81,101 and the fourth used the EuroQol instrument.84 Two of these studies reported blinding of outcome assessors.79,84

Seven fair-quality multifactorial assessment and management trials (n=3,237) evaluated effects on disability with mixed results.75,77–81,84 One trial (n=1,242) including older adults with one or more fall risk factors reported that a multifactorial assessment and management program was associated with a significant difference in the percentage of participants with worsened disability in the intervention group (15%) compared with controls (20%) after 12 months (p<0.05).78 Limitations in activities of daily life were assessed using the Medical Outcome Study physical function scale. Two studies reported slightly less disability, based on the Barthel Index, in the intervention group, compared with the control (mean difference in change ranged from 0.6 to 1.0 on a 100 point scale), representing a greater improvement in one study80 and less of a decline in the others.75,77 This difference, however, is not clinically meaningful. The remaining three studies reported no significant improvements in disability.79,81,84

### Single Clinical Treatment

Eleven of the 16 clinical trials reported fall-related fracture, quality of life, or disability (Table 3). Interventions that included a single clinical treatment are diverse, and thus it is more relevant to describe the evidence for subgroups of similar interventions: vitamin D (with or without calcium),67,86,89,98,99,102 vision correction,87,90,91 and hip protectors.66,85 Eight of the 11 trials were restricted to women66,67,85–87,89,91,98 and all except one were conducted in high-risk populations.86

Table 3 Study Characteristics of Clinical Management Interventions to Reduce Fall-Related Injury, Improve Quality of Life, or Reduce Disability (KQ1)

For more details of each study, see Table 9 and Appendix C Table 2

Study reference, Setting, USPSTF quality rating | Fall-related injury | | | Quality of life | | | | Disability
Hip protectors
Birks 2004^85^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: Hip fractures: No significant difference Total fractures (calculated): IG: 135/1388 (9.7%) CG: 310/2781 (11.1%) # people sustaining multiple events: Hip fracture: IG: 0/1388 (0%) CG: 3/2781 (0.1%) | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Risk of hip fracture when falling while wearing hip protectors, compared with/fall with no hip protectors: RR=0.23 (95% CI, 0.08 to 0.67). No significant differences in falls causing injury requiring hospital care. Fracture rate per person-year: NR # fractures: | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Fracture site | IG | CG | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Lower limb | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Hip | 21 | 22 | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Adjusted RR, 0.92 (95% CI, 0.51 to 1.68) | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Pelvis | 8 | 6 | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Other | 3 | 6 | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Upper limb | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Wrist | 12 | 6 | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Arms/shoulder | 5 | 5 | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | Other | 3 | 4 | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Cameron 2003^66^ Australia Fair | # people sustaining fractures: IG: 31 peripheral, non-hip fractures in 25 people; 21 hip fractures CG: 27 peripheral non-hip fractures in 25 people; 22 hip fractures # people sustaining multiple events: NR | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Vision correction
Cumming 2007^90^ Australia Fair | Fracture rate per person-year: NR # (%) fractures: NR # (%) people sustaining fractures: IG: 31 (10.0%) CG: 18 (5.7%) OR (95% CI): 1.74 (0.97 to 3.11) # people sustaining multiple events: NR | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Foss 2006^91^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: IG: 5 CG: 3 p=NS # people sustaining fractures: IG: 5/120 (4%) CG: 2/119 (2%) p=NS # people sustaining multiple events: NS | | | SF-12: NR SF-36: NR EuroQol: No significant difference | | | | ADL:
Foss 2006^91^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: IG: 5 CG: 3 p=NS # people sustaining fractures: IG: 5/120 (4%) CG: 2/119 (2%) p=NS # people sustaining multiple events: NS | | | SF-12: NR SF-36: NR EuroQol: No significant difference | | | | | Mean
Foss 2006^91^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: IG: 5 CG: 3 p=NS # people sustaining fractures: IG: 5/120 (4%) CG: 2/119 (2%) p=NS # people sustaining multiple events: NS | | | SF-12: NR SF-36: NR EuroQol: No significant difference | | | | | BL | 6 mo | difference (95% CI)
Foss 2006^91^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: IG: 5 CG: 3 p=NS # people sustaining fractures: IG: 5/120 (4%) CG: 2/119 (2%) p=NS # people sustaining multiple events: NS | | | SF-12: NR SF-36: NR EuroQol: No significant difference
Foss 2006^91^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: IG: 5 CG: 3 p=NS # people sustaining fractures: IG: 5/120 (4%) CG: 2/119 (2%) p=NS # people sustaining multiple events: NS | | | SF-12: NR SF-36: NR EuroQol: No significant difference | | | | IG | 18.7 | 18.7
Foss 2006^91^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: IG: 5 CG: 3 p=NS # people sustaining fractures: IG: 5/120 (4%) CG: 2/119 (2%) p=NS # people sustaining multiple events: NS | | | SF-12: NR SF-36: NR EuroQol: No significant difference | | | | CG | 18.9 | 18.8 | −0.1 (−0.2 to 0.3)
Foss 2006^91^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: IG: 5 CG: 3 p=NS # people sustaining fractures: IG: 5/120 (4%) CG: 2/119 (2%) p=NS # people sustaining multiple events: NS | | | SF-12: NR SF-36: NR EuroQol: No significant difference | | | | p= 0.61 IADL: NR
Harwood 2005^87^ United Kingdom Good | Fracture rate per person-year: NR # fractures: IG: 4 CG: 12 # people sustaining fractures: IG: 4 CG: 12 RR (95% CI): 0.33 (0.1 to 1.0); p=0.04 # people sustaining multiple events: NR | | | SF-12: NR SF-36: NR EuroQol: | | | | ADL: Barthal index (mean)
Harwood 2005^87^ United Kingdom Good | Fracture rate per person-year: NR # fractures: IG: 4 CG: 12 # people sustaining fractures: IG: 4 CG: 12 RR (95% CI): 0.33 (0.1 to 1.0); p=0.04 # people sustaining multiple events: NR | | | | Mean | | | | IG | CG
Harwood 2005^87^ United Kingdom Good | Fracture rate per person-year: NR # fractures: IG: 4 CG: 12 # people sustaining fractures: IG: 4 CG: 12 RR (95% CI): 0.33 (0.1 to 1.0); p=0.04 # people sustaining multiple events: NR | | | | IG | CG
Harwood 2005^87^ United Kingdom Good | Fracture rate per person-year: NR # fractures: IG: 4 CG: 12 # people sustaining fractures: IG: 4 CG: 12 RR (95% CI): 0.33 (0.1 to 1.0); p=0.04 # people sustaining multiple events: NR | | | | | | | Baseline | 6.7 | 7.1
Harwood 2005^87^ United Kingdom Good | Fracture rate per person-year: NR # fractures: IG: 4 CG: 12 # people sustaining fractures: IG: 4 CG: 12 RR (95% CI): 0.33 (0.1 to 1.0); p=0.04 # people sustaining multiple events: NR | | | Baseline | 0.70 | 0.70 | | 6 months | 7.2 | 6.5
Harwood 2005^87^ United Kingdom Good | Fracture rate per person-year: NR # fractures: IG: 4 CG: 12 # people sustaining fractures: IG: 4 CG: 12 RR (95% CI): 0.33 (0.1 to 1.0); p=0.04 # people sustaining multiple events: NR | | | 6 months | 0.73 | 0.67 | | Mean difference (95% CI): 0.1 (−0.2 to 0.3); p=0.05 IADL: NR
Harwood 2005^87^ United Kingdom Good | Fracture rate per person-year: NR # fractures: IG: 4 CG: 12 # people sustaining fractures: IG: 4 CG: 12 RR (95% CI): 0.33 (0.1 to 1.0); p=0.04 # people sustaining multiple events: NR | | | Mean difference (95% CI): 0.06 (0.01 to 0.11); p=0.02 | | | | Mean difference (95% CI): 0.1 (−0.2 to 0.3); p=0.05 IADL: NR
Vitamin D
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | SF-12: NR SF-36 mean scores (SD): | | | | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | | Baseline | 6 months | P | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | | | | | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | Role-physical | CG: 44.2 (40.2) | 56.2 (42.4) | 0.05 | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | | IG: No significant difference | | | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | Social function | CG: 66.3 (28.3) | 76.8 (27.6) | 0.03 | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | | IG: No significant difference | | | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | Role-emotional | CG: 78.6 (36.8) | 89.3 (25.5) | 0.04 | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | | IG: No significant difference | | | ADL: NR IADL: NR
Dhesi 2004^102^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | Physical functioning: No significant difference Mental health: No significant difference Bodily pain: No significant difference General health: No significant difference Vitality: No significant difference EuroQol: NR | | | | ADL: NR IADL: NR
Pfeifer 2000^98^ Germany Fair | Fracture rate per person-year: NR # fractures: IG: 3 (4%); CG: 6 (9%); p=0.1367 # people sustaining fractures: NR # people sustaining multiple events: NR | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Porthouse 2005^67^ England Fair | Fracture rate per person year: NR # fractures: NR # people sustaining fractures: IG: unequally allocated 34/714 (4.8%); equally allocated 24/607 (4.0%) CG: unequally allocated 69/1391 (5.0%); equally allocated 22/602 (3.7%) # people sustaining multiple events: NR | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR
Prince 2008^89^ Australia Fair | Fracture rate per person year: NR # fractures: NR # people sustaining fractures: IG: 1 (0.7%) CG: 1 (0.7%) # people sustaining multiple events: NR | | | SF-12: NR SF-36: NR EuroQol: NR | | | | ADL: NR IADL: NR

USPSTF – U.S. Preventive Services Task Force; # – number; % – percent; SF-36 – 36-item Short-Form Health Survey; SF-12 – 12-item Short-Form Health Survey; NR – not reported; ADL – activities of daily living; IADL – instrumental activities of daily living; BL – baseline; mo – month; CI – confidence interval; IG – intervention group; CG – control group; RR – relative risk

NOTE: Gray-Donald 1995^88^ and Dukas 2004^92^ only report mortality for data relevant for KQ 1. See Appendix C Table 2 for more detail.

Summary of findings. Hip protectors. Hip protectors were not associated with a significant reduction in 24-month risk for fall-related fractures among high-risk women with an average age of 78–83 years (n=4,769) (Figure 3).66,85 One third (31%) to one half (53%) of women wore their hip protectors as intended.

Figure 3 Pooled Risk for Fall-Related Fractures in Single Clinical Treatment Interventions: Hip Protector Trials (KQ 1)

Figure 3 displays a forest plot of all hip protector trials reporting between-group differences in fall-related fractures. Data for the figure are presented alongside the forest plot. The pooled relative risk for fall-related fractures was 0.89 (95% CI, 0.75 to 1.06), with low statistical heterogeneity (chi-square=0%).

Vision correction. Three of four vision-correction trials (n=1,161) among adults aged 78–81 years on average reported health outcomes.87,90,91 All studies were rated fair to good quality. The results for fall-related fractures were mixed and data were not pooled due to very high statistical heterogeneity. One of the trials of expedited cataract surgery was associated with a reduced risk for fractures,87 while the other was associated with a nonsignificant increased risk.91 The third trial treated vision deficiencies based on screening results and reported a nonsignificant increased risk for fall-related fractures (OR, 2.5 [95% CI, 0.5 to 12.5]).90 Additionally, no significant differences were observed in 6-month change in disability among 545 participants87,91 or quality of life among 239 participants.91

Vitamin D. Six of eight vitamin D trials67,86,89,98,99,102 reported health outcomes 6 to 36 months after the beginning of treatment. Trials included healthy ambulatory women and men aged 65 years or older;86,99 individuals with vitamin D deficiency and a history of falling,89 vitamin D deficiency without a history of falling,98 or a history of falling without vitamin D deficiency;102 and women at risk for hip fracture.67 No trials evaluated disability. All studies were rated as fair quality.

Five studies (n=4,252) tabulated the number of people who experienced a fall-related fracture67,86,89,98,99 and one study assessed quality of life.102 Risk for fall-related fractures was not reduced over 12 months among women aged 71–77 years on average (pooled RR, 0.85 [95% CI, 0.64 to 1.12]) (I^2^=0%) (Figure 4). The trial that evaluated improvements in quality of life found no significant improvement.102

Figure 4 Pooled Risk for Fall-Related Fractures in Single Clinical Treatment Interventions: Vitamin D Trials (KQ 1)

Figure 4 displays a forest plot of all vitamin D trials reporting between-group differences in fall-related fractures. Data for the figure are presented alongside the forest plot. The pooled relative risk for fall-related fractures was 0.85 (95% CI, 0.64 to 1.12), with low statistical heterogeneity (chi-square=0%).

Study details. Hip protectors. Two fair-quality trials66,85 (n=4,769) assessed the influence of hip protectors on overall risk for fracture among high-risk noninstitutionalized women over 24 months of followup, during which 415 women fell in one study 85 and there was a total of 1,437 falls in the other study (mean, 2.2 to 2.7 per person).66 Both interventions provided participants with semi-rigid shields sewn into modified underwear. One trial (n=600) provided intervention-group participants with a nurse to assist with fitting the protectors and encourage adherence. The nurse made three home visits followed by two telephone calls to intervention participants.66 The other intervention (n=4,169) mailed the hip protectors with an educational pamphlet.85 While adherence was higher in the trial including the nurse contact (53%)66 compared with the trial without contact (38%)85 at 6 months, neither was associated with a significant reduced risk for any fracture or hip fractures in intention-to-treat analyses. The pooled relative risk for experiencing a fall-related fracture during 24 months after initiation of the intervention was 0.89 (95% CI, 0.75 to 1.06) (I^2^=0%) (Figure 3).

Vision correction. Two trials evaluated expedited cataract surgery.87,91 A third trial evaluated single clinical treatment of vision problems identified through screening.90 All of the participants (n=1,161), women aged 78–81 years on average, were identified as high-risk populations by virtue of selection for frailty or for an age of 70 years or older and cataracts. Fall-related fractures were self-reported in all three trials and were assessed by monthly postcards, a telephone followup (if the postcard was not returned),90 or during a telephone interview or clinic visit every 3 months.87,91

The trials of expedited cataract surgery among women with unoperated cataracts87,91 (n=545) found mixed results. Harwood and colleagues87 reported a significant risk reduction for fall-related fracture (four persons in the intervention group compared with 12 in the control group [p=0.04]). Foss and colleagues,91 on the other hand, reported a nonsignificant increased risk in the intervention group compared with the control group. Expedited cataract surgery trials also reported no significant reduction in disability, as measured by the Barthel Index,87,91 or quality of life, as measured by the EuroQol.91 An intervention including an eye exam and treatment was associated with a significantly increased risk for sustaining a fall-related fracture in the intervention group, compared with the usual care control.90

Vitamin D. In a fair-quality study (n=148) restricted to women who were vitamin D deficient (25-hydroxycholecalciferol level<50 nmol/liter), a regimen of vitamin D and calcium supplement (400 IU vitamin D and 600 mg calcium daily) for 8 weeks was associated with a 4% risk for sustaining a fall-related fracture over 1 year, compared with 9% in the control group that received only the calcium supplement.98 This difference was not statistically significant, although the study may have been underpowered. A study (n=242) in healthy older adults that was also not powered to detect a significant reduction in the number of fractures reported 12 fractures in the calcium plus vitamin D group (800 IU of cholecalciferol per day) compared with 19 fractures in the control group that received calcium only (p=0.12).99 Another study (n=246) in healthy women reported a nonsignificant reduction in risk for nonvertebral fractures (RR, 0.60 [95% CI, 0.28 to 1.27]) for 0.25 μg of calcitriol twice per day compared with placebo.86 Another fair-quality study89 (n=302) restricted to women who were vitamin D deficient (25-hydroxycholecalciferol level<24.0 nmol/liter) and had fallen at least once during the previous year evaluated a higher-dose vitamin D and calcium supplement (1000 IU vitamin D2 and 250 IU calcium citrate tablets twice daily) compared with calcium supplementation alone for 1 year. One woman in each group experienced a fall-related fracture during the year of followup.89 A large study (n=3,314) among women with at least one risk factor for hip fracture evaluated a vitamin D plus calcium supplement (two tablets of 1000 mg of calcium and 800 IU of vitamin D3 daily) for 6 months.67 Women in the intervention group also received a brief education/counseling visit with a nurse that focused on reducing fracture risk and a pamphlet describing how to consume adequate calcium and vitamin D from dietary sources. The control group only received the pamphlet in the mail. After a median followup of 25 months, the risk for fall-related fractures was 4.8% in the intervention group and 5.0% in the control group.

Change in quality of life was assessed in an intervention comparing an intramuscular injection of 600,000 IU of ergocalciferol with a placebo injection among men and women (n=139) who had fallen during the previous 8 weeks.102 Dhesi and colleagues found no significant change in the intervention group between baseline and 6-month followup in any of the eight subscales of the SF-36 measure of health-related quality of life. Control participants, on the other hand, reported small but statistically significant improvements in two of the subscales (social functioning and role-emotional). The difference in changes between the two groups was not assessed.

The followup period for all of these trials was 6 to 36 months. As such, the absence of any influence on distal outcomes may reflect inadequate time to see an improvement or rare events, in the case of fractures.

### Clinical Education/Behavioral Counseling

Summary of findings. One good-quality study (n=310) of a low-intensity behavioral counseling intervention (<26 contact hours) in community-dwelling older adults reported no significant difference in change in quality of life after 14 months103 (Table 4). The 7-week intervention included 2 hours per week of group sessions taught by an occupational therapist. The sessions were designed to assist older adults in developing strategies to reduce fall risk. The control group received two social visits with an occupational therapy student. Quality of life was assessed using the physical function and mental function composite scores of the SF-36. All women included in the trial had a history of at least one fall during the previous year or had a fear of falling.

Table 4 Study Characteristics of Clinical Education or Behavioral Counseling Interventions to Reduce Fall-Related Injury, Improve Quality of Life, or Reduce Disability (KQ 1)

For more details of this study, see Table 13 and Appendix C Table 3

Study reference, Setting, USPSTF quality rating | Fall-related injury | Quality of life | Disability
Clemson 2004^103^ Australia Good | Fracture rate per person year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: n (mean change +/−SD) Mental health component CG: 125 (−0.52±10.00) IG: 133 (0.01±9.65) Mean difference (95% CI): 0.53 (−2.95 to 1.88) Physical component CG:125 (0.68±9.04) IG: 133 (−0.02±8.34) Mean difference (95% CI): 0.70 (−2.94 to 1.88) EuroQol: NR | ADL: NR IADL: NR

USPSTF – U.S. Preventive Services Task Force; # – number; SF-36 – 36-item Short Form Health Survey; SF-12 – 12-item Short Form Health Survey; SD – standard deviation; CI – confidence interval; NR – not reported; ADL – activities of daily living; IADL – instrumental activities of daily living

### Home Hazard Modification

No trials reported health outcomes related to home hazard modification interventions other than mortality (Table 5).

Table 5 Study Characteristics of Home Hazard Modification Interventions to Reduce Fall-Related Injury, Improve Quality of Life, or Reduce Disability (KQ 1)

For more details of this study, see Table 12 and Appendix C Table 4

Study reference, Setting, USPSTF quality rating | Fall-related injury | Quality of life | Disability
Campbell 2005^63^ New Zealand Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | ADL: NR IADL: NR

USPSTF – U.S. Preventive Services Task Force; # – number; SF-36 – 36-item Short Form Health Survey; SF-12 – 12-item Short Form Health Survey; NR – not reported; ADL – activities of daily living; IADL – instrumental activities of daily living

NOTE: This study only reported mortality for data that is relevant for KQ 1.

### Exercise and Physical Therapy

Summary of findings. Of 17 exercise or physical therapy intervention trials, seven fair-quality trials (n=1,072) of physical activity in community-dwelling older adults assessed multiple health outcomes, including measures of fall-related fractures,96,100,107 quality of life,96,100,104–106 and disability94,97,105–107 (Table 7). Six of these trials were conducted in a high-risk population: three were identified based on gait and balance impairments,100,104,105 two were restricted based on chronic disease status (Parkinson’s disease)96 or recent stroke,94 and one was restricted to women aged 80 years or older.97 The remaining trial included an unselected population.107

Table 7 Study Characteristics of Multifactorial Clinical Assessment Interventions to Prevent Falls (KQ 2)

For more details about each study see Appendix C Table 1

Study reference, Setting, USPSTF quality rating | N patients randomized, Age | Risk category, % high risk | # (%) fallers, # (%) frequent fallers, Length of followup | | | High-risk status | | | Adverse effects
Comprehensive intervention (assessment + multifactorial treatment)
Close 1999^80^ United Kingdom Fair | Randomized: 397 IG: 184 CG: 213 Mean age (SD): 78.2 (7.5) IG: 77.3 (7.4) CG: 78.9 (7.6) | Risk category: Other (fall history) Proportion: 100% | # (%) fallers: IG: 59/184 (32%) CG: 111/213 (52%) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | All are high risk | | | NR
Hogan 2001^82^ Canada Fair | Randomized: 163 IG: 79 CG: 84 Mean age (SD): IG: 77.4 (7.3) CG: 77.9 (6.2) | Risk category: Other (fall history) Proportion: 1+ falls: 100% 2+ falls: 47.2% | # (%) fallers: IG: 54/75 (72.0%) CG: 61/77 (79.2%) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | In a post-hoc subgroup analysis, IG subjects with >2 falls in the 3 months pre-study were less likely to fall (p=0.046) and had a significantly longer time between falls (p<0.001) compared with CG. No significant differences between the CG and IG in cumulative # of falls (311 v. 241; p=0.34), having 1+ falls (79.2% v. 72.0%; p=0.30) or in the mean # of falls (4.0 vs 3.2; p=0.43). | | | NR
Lord 2005^62^ Australia Fair | Randomized: 620 IG: 210 CG: 204 Mean age (SD): IG (EI): 80.3 (4.3) IG (MI): 80.7 (4.6) CG: 80.2 (4.6) | Risk category: Screening Tool: Physiological Profile Assessment (PPA) Proportion: 100% | # (%) fallers: IG: 93 (46.0) CG: 90 (44.8) # (%) frequent fallers (2+ falls): IG: 49 (24.3) CG: 45 (22.4) Followup: 1 year | | | All are high risk | | | NR
Tinetti 1994^69^ Tinetti 1993^162^ Buchner 1993^110^ United States Fair | Randomized: 301 IG: 153 CG: 148 Mean age (SD): IG: 78.3 (5.3) CG: 77.5 (5.3) | Risk category: Medication specific, gait and/or balance impairment, other (inability to transfer safely to bathtub or toilet, environmental hazards for falls, impairment in leg or arm muscle strength or range of motion) Proportion: 100% had at least 1 risk factor | # (%) fallers: IG: 52 (35) CG: 68 (47) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | All are high risk | | | Death IG: 7 (5%) CG: 5 (3%) Hospitalization IG: 32 (21%) CG: 36 (24%) Musculoskeletal symptoms IG: 10 CG: none p=NS
Wagner 1994^78^ United States Fair | Randomized: 1,559 IG: 635 CG: 607 Mean age: IG: 72.5 IG (visit only): 72.6 CG: 72.5 | Risk category: Visual impairment, prescription drug use, other (inadequate exercise, high-risk alcohol use, hearing impairment, increased fall risk) Proportion: Overall: NR By risk category: 5–73% | # falls: NR # (%) fallers (calc): | | | NR | | | NR
Wagner 1994^78^ United States Fair | Randomized: 1,559 IG: 635 CG: 607 Mean age: IG: 72.5 IG (visit only): 72.6 CG: 72.5 | Risk category: Visual impairment, prescription drug use, other (inadequate exercise, high-risk alcohol use, hearing impairment, increased fall risk) Proportion: Overall: NR By risk category: 5–73% | | IG | CG | NR | | | NR
Wagner 1994^78^ United States Fair | Randomized: 1,559 IG: 635 CG: 607 Mean age: IG: 72.5 IG (visit only): 72.6 CG: 72.5 | Risk category: Visual impairment, prescription drug use, other (inadequate exercise, high-risk alcohol use, hearing impairment, increased fall risk) Proportion: Overall: NR By risk category: 5–73% | | | | NR | | | NR
Wagner 1994^78^ United States Fair | Randomized: 1,559 IG: 635 CG: 607 Mean age: IG: 72.5 IG (visit only): 72.6 CG: 72.5 | Risk category: Visual impairment, prescription drug use, other (inadequate exercise, high-risk alcohol use, hearing impairment, increased fall risk) Proportion: Overall: NR By risk category: 5–73% | Year 1 | 175 (27.5) | 223 (36.8) | NR | | | NR
Wagner 1994^78^ United States Fair | Randomized: 1,559 IG: 635 CG: 607 Mean age: IG: 72.5 IG (visit only): 72.6 CG: 72.5 | Risk category: Visual impairment, prescription drug use, other (inadequate exercise, high-risk alcohol use, hearing impairment, increased fall risk) Proportion: Overall: NR By risk category: 5–73% | Year 2 | 199 (31.4) | 177 (29.2) | NR | | | NR
Wagner 1994^78^ United States Fair | Randomized: 1,559 IG: 635 CG: 607 Mean age: IG: 72.5 IG (visit only): 72.6 CG: 72.5 | Risk category: Visual impairment, prescription drug use, other (inadequate exercise, high-risk alcohol use, hearing impairment, increased fall risk) Proportion: Overall: NR By risk category: 5–73% | # (%) frequent fallers (2+ falls): NR Followup: 2 years | | | NR | | | NR
Targeted intervention (assessment + referral and targeted intervention or education)
Elley 2008^79^ New Zealand Good | Randomized: 312 IG: 155 CG: 157 Mean age (SD): 80.8 (5.0) IG: 80.4 (4.8) CG: 81.1 (5.3) | Risk category: Other (fall history) Proportion: 100% | # (%) fallers: IG: 106 (68.4) CG: 98 (62.4) # (%) frequent fallers (2+ falls): IG: 69 (44.5) CG: 54 (34.4) Followup: 1 year | | | All are high risk | | | NR
Lord 2005^62^ Australia Fair | Randomized: 620 IG: 206 CG: 204 Mean age (SD): IG: 80.7 (4.6) CG: 80.2 (4.6) | Risk category: Screening Tool: Physiological Profile Assessment (PPA) Proportion: 100% | # (%) fallers: IG: 94 (48.5) CG: 90 (44.8) # (%) frequent fallers (2+ falls): IG: 37 (19.1) CG: 45 (22.4) Followup: 1 year | | | All are high risk | | | NR
Shumway-Cook 2007^83^ United States Good | Randomized: 453 IG: 226 CG: 227 Mean age (range): 75.6 (65–96) | Risk category: Other: (fall history in previous 3 months) Proportion: IG: 27% CG: 28% | # (%) fallers: IG: 124 (55) CG: 130 (57) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | | N | IRR (95% CI) | NR
Shumway-Cook 2007^83^ United States Good | Randomized: 453 IG: 226 CG: 227 Mean age (range): 75.6 (65–96) | Risk category: Other: (fall history in previous 3 months) Proportion: IG: 27% CG: 28% | # (%) fallers: IG: 124 (55) CG: 130 (57) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | | | | NR
Shumway-Cook 2007^83^ United States Good | Randomized: 453 IG: 226 CG: 227 Mean age (range): 75.6 (65–96) | Risk category: Other: (fall history in previous 3 months) Proportion: IG: 27% CG: 28% | # (%) fallers: IG: 124 (55) CG: 130 (57) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | Yes | 124 | 0.61 (0.34–1.10)* | NR
Shumway-Cook 2007^83^ United States Good | Randomized: 453 IG: 226 CG: 227 Mean age (range): 75.6 (65–96) | Risk category: Other: (fall history in previous 3 months) Proportion: IG: 27% CG: 28% | # (%) fallers: IG: 124 (55) CG: 130 (57) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | No | 329 | 0.95 (0.68–1.33) | NR
Shumway-Cook 2007^83^ United States Good | Randomized: 453 IG: 226 CG: 227 Mean age (range): 75.6 (65–96) | Risk category: Other: (fall history in previous 3 months) Proportion: IG: 27% CG: 28% | # (%) fallers: IG: 124 (55) CG: 130 (57) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | *p=0.20 | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | # (%) fallers: | | | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | | IG | CG | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | | | | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | 12 mo | 63 (50) | 53 (44) | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | 18 mo | 68 (57) | 58 (52) | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | # (%) frequent fallers (2+ falls): | | | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | | IG | CG | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | | | | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | 12 mo | 34 (27) | 29 (24) | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | 18 mo | 43 (36) | 35 (31) | All are high risk | | | NR
Van Haastregt 2000^71^ Netherlands Fair | Randomized: 316 IG: 159 CG: 157 Mean age (SD): IG: 77.2 (5.1) CG: 77.2 (5.0) | Risk category: Other (fall history, mobility limitation) Proportion: 100% had at least 1 risk factor | Followup: 18 months | | | All are high risk | | | NR
Referral only intervention (assessment + referral only)
Hendriks 2008^84^ Netherlands Fair | Randomized: 333 IG: 166 CG:167 Mean age (SD): IG: 74.5 (5.9) CG: 75.2 (6.9) | Risk category: Other (fall history) Proportion: 100% | # (%) fallers at 12-mo: IG: 55 (46) CG: 61 (47) # (%) frequent fallers (2+ falls): IG: 32 (26) CG: 34 (26) Followup: 1 year | | | All are high risk | | | NR
Lightbody 2002^77^ United Kingdom Fair | Randomized: 348 IG: 171 CG: 177 Median age (IQR): IG: 75 (70–82) CG: 75 (70–81) | Risk category: Other (fall history) Proportion: 100% | # (%) fallers: IG: 39 (25%) CG: 41 (26%) # (%) frequent fallers: NR Followup: 6 months | | | All are high risk | | | IG had higher rate of fall-related GP attendance
Newbury 2001^81^ Australia Fair | Randomized: 100 IG: 50 CG: 50 Median age (range): IG: 78.5 (75–88) CG: 80 (75–91) | Risk category: NR Proportion: NR | # (%) fallers: IG: 12 (26.7) CG: 17 (38.6) # (%) frequent fallers (2+ falls): NR Followup: 1 year | | | NA | | | NR

N – number; # – number; % – percent; USPSTF – U.S. Preventive Services Task Force; IG – intervention group; CG – control group; SD – standard deviation; NR – not reported; IQR – interquartile range; EI – extensive intervention; MI – minimal intervention; SF-36 – 36-item Short Form Health Survey; IRR – incident risk ratio; CI – confidence interval

In two trials (n=201), exercise interventions addressing muscle strengthening and balance did not significantly reduce risk for fall-related fractures in community-dwelling high-risk older adults 3 to 6 months after initiation of the intervention.96,100 The third trial included a Tai Chi intervention and did not report any fracture-risk data.107

Only one of the four studies evaluating change in quality of life found significant improvement after 3 to 6 months of followup.95,96,104–106 Ashburn and colleagues96 reported a significant difference of 5.7 units (95% CI, 0.47 to 11.0) in change in quality of life, as measured by the EuroQol instrument, after adjusting for baseline EuroQol, balance, functional reach, and disability. The remaining three trials assessed quality of life with the SF-36 instrument.95,104–106 Rubenstein and colleagues100 reported a nonsignificant improvement of 7 points in quality of life (physical function subscale) in the intervention group compared with the control group (p=0.08).

No significant reduction in disability was observed among older adults followed for 4 to 6 months (n=708).94,97,105–107 The followup period for all of these trials was short. As such, the absence of any influence on distal outcomes may reflect inadequate time to see an improvement or rare events, in the case of fractures. Additional details about the interventions are provided below in KQ 2.

## KQ 2 Do Primary Care Interventions Used Alone or in Combination in Community-Dwelling Older Adults Reduce Risk for or Rate of Falls/Fallers?

### Multifactorial Assessment and Management Interventions

Summary of findings. In seven arms (n=3,195) of comprehensive multifactorial assessment and management interventions among older adults,69,75,76,78,80,82,108 the interventions were associated with reduced risk for falling compared with usual care 12 months after entry. The pooled estimate of relative risk was 0.75 (95% CI, 0.58 to 0.99), with high heterogeneity (I^2^=86.4%) (Figure 5). Among the nine noncomprehensive multifactorial clinical assessment intervention arms,71,75,77,79,81,83,84,108 the risk for falling was not reduced (RR, 1.04 [95% CI, 0.98 to 1.10]) (Figure 6). The statistical heterogeneity of these trials was low (I^2^=0%).

Figure 5 Pooled Risk for Falling in Comprehensive Multifactorial Assessment and Management Interventions (KQ 2)

Figure 5 displays a forest plot of all comprehensive multifactorial assessment and management trials reporting between-group differences in risk for falling. Data for the figure are presented alongside the forest plot. The pooled relative risk for falling was 0.75 (95% CI, 0.58 to 0.99), with high statistical heterogeneity (chi-square=86.4%).

Figure 6 Pooled Risk for Falling in Noncomprehensive Multifactorial Assessment and Management Interventions (KQ 2)

Figure 6 displays a forest plot of all noncomprehensive multifactorial assessment and management trials reporting between-group differences in risk for falling. Data for the figure are presented alongside the forest plot. The pooled relative risk for falling was 1.04 (95% CI, 0.98 to 1.10), with low statistical heterogeneity (chi-square=0%).

Study details. Fourteen trials of multifactorial assessment and management interventions62,69,71,75–84,101 measured fall outcomes. These trials (n=5,570) randomized community-dwelling adults aged 65 years or older (Table 6). The average age of participants was 75 years or older, except for one study in which the average age was 72.5 years.78 The majority of participants were women (percentage ranged from 40% to 77%) and none of the studies reported a substantial proportion of nonwhite or Hispanic participants. Only four of the trials were conducted in the United States,69,78,83,101 while the majority were conducted in other countries, including the United Kingdom,75–77,80 the Netherlands,71,84 Australia,62,81 and Canada.82 Most trials identified participants through primary care practices or insurance rolls, while four identified community-dwelling participants presenting to the emergency department for a fall-related event.76,77,80,84 One study recruited directly from the community.83 Seven trials recruited participants who had a history of falling,75–77,79,80,82,84 and four trials recruited a high-risk population by screening for multiple possible risk factors.62,69,71,78,101 The remaining two trials were conducted in unselected populations.81,83 In the eleven studies that reported a history of falls during the 12-month period preceding the trial initiation, the percentage of individuals experiencing a fall ranged from 33% to 100%.69,71,75–80,82,84,101 Most studies excluded older adults with evidence of cognitive impairment or physical disability.

Table 6 Study Characteristics of Exercise/Physical Therapy Interventions to Reduce Fall-Related Injury, Improve Quality of Life, or Reduce Disability (KQ 1)

For more details of each study, see Table 10 and Appendix C Table 5

Study reference, Setting, USPSTF quality rating | Fall-related injury | Quality of life | | | | | Disability
Ashburn 2007^96^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: IG: 2/67 (3%) CG: 6/67 (9%) p=0.141 # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol Mean (SD): | | | | | ADL: NR IADL: NR
Ashburn 2007^96^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: IG: 2/67 (3%) CG: 6/67 (9%) p=0.141 # people sustaining multiple events: NR | | IG | CG | Adjusted* Diff (95% CI) | p | ADL: NR IADL: NR
Ashburn 2007^96^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: IG: 2/67 (3%) CG: 6/67 (9%) p=0.141 # people sustaining multiple events: NR | | | | | | ADL: NR IADL: NR
Ashburn 2007^96^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: IG: 2/67 (3%) CG: 6/67 (9%) p=0.141 # people sustaining multiple events: NR | Baseline | 63.1 (17.1) | 64.6 (14.5) | | | ADL: NR IADL: NR
Ashburn 2007^96^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: IG: 2/67 (3%) CG: 6/67 (9%) p=0.141 # people sustaining multiple events: NR | 8 weeks | 61.3 (19.8) | 61.7 (14.5) | −0.7 (−5.6 to 4.3) | 0.793 | ADL: NR IADL: NR
Ashburn 2007^96^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: IG: 2/67 (3%) CG: 6/67 (9%) p=0.141 # people sustaining multiple events: NR | 6 months | 63.0 (18.7) | 56.6 (16.9) | 5.7 (0.47 to 11.0) | 0.033 | ADL: NR IADL: NR
Ashburn 2007^96^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: IG: 2/67 (3%) CG: 6/67 (9%) p=0.141 # people sustaining multiple events: NR | *Adjusted for SAS, baseline, Berg Balance/Functional Reach/EuroQol, and location | | | | | ADL: NR IADL: NR
Barnett 2003^104^ Australia Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: Groups did not differ after 6 months EuroQol: NR | | | | | ADL: NR IADL: NR
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: | | | | | ADL: NR IADL: # independent IADLs (out of 5): Mean (SD)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | CG | IG(ET) | IG(ST) | IG(ET+ST) | ADL: NR IADL: # independent IADLs (out of 5): Mean (SD)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | | | | | | ADL: NR IADL: # independent IADLs (out of 5): Mean (SD)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | General health | | | | | ADL: NR IADL: # independent IADLs (out of 5): Mean (SD)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | Baseline | 77 (14) | 78 (18) | 78 (10) | 71 (15) | | | Baseline | 6-mo
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | 6-month change | −2 (14) | 1 (10) | 1 (9) | 1 (11) | CG | | 4.6 (0.7) | 0.2 (0.7)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | Bodily pain | | | | | IG (ET) | | 4.7 (0.6) | 0.2 (0.5)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | Baseline | 76 (21) | 78 (24) | 74 (21) | 73 (22) | IG (ST) | | 4.8 (0.7) | 0.1 (0.7)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | 6-month change | 1 (20) | −2 (19) | 2 (22) | −1 (19) | IG (ET+ST) | | 4.6 (1.0) | 0.1 (0.4)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | Role physical
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | Baseline | 71 (28) | 73 (31) | 65 (39) | 72 (32)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | 6-month change | 3 (38) | 10 (38) | 4 (47) | −1 (29)
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | EuroQol: NR
Campbell 1997^97^ New Zealand Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | ADL: NR IADL: No differences between the group scores: median, 8.0; range, 0–8
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | ADL:
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | | IG | | CG
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | | n | outcome | n | outcome
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | Baseline | 85 | 18 (16–19) | 85 | 18 (16–19)
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | 3 months p=0.497 | 81 | 18 (16–19) | 80 | 18 (16–19)
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | 6 months p=0.888 | 73 | 18 (16–19) | 77 | 18 (16–19)
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | 9 months p=0.478 | 72 | 18 (16–19) | 74 | 18 (16–20)
Green 2002^94^ United Kingdom Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events: NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | IADL: NR
Rubenstein 2000^100^ United States Fair | Fracture rate per person-year: 0 (both groups) # fractures: 0 (both groups) # people sustaining fractures: 0 (both groups) # people sustaining multiple events: 0 (both groups) | SF-12: NR SF-36: Physical functioning: NS Role limits-physical: NS Health perceptions: NS | | | | | ADL: NR IADL: NR
Rubenstein 2000^100^ United States Fair | Fracture rate per person-year: 0 (both groups) # fractures: 0 (both groups) # people sustaining fractures: 0 (both groups) # people sustaining multiple events: 0 (both groups) | Health question: | IG | CG | | | ADL: NR IADL: NR
Rubenstein 2000^100^ United States Fair | Fracture rate per person-year: 0 (both groups) # fractures: 0 (both groups) # people sustaining fractures: 0 (both groups) # people sustaining multiple events: 0 (both groups) | | | | | | ADL: NR IADL: NR
Rubenstein 2000^100^ United States Fair | Fracture rate per person-year: 0 (both groups) # fractures: 0 (both groups) # people sustaining fractures: 0 (both groups) # people sustaining multiple events: 0 (both groups) | Baseline | 51.8±26.3 | 50.9±20.2 | | | ADL: NR IADL: NR
Rubenstein 2000^100^ United States Fair | Fracture rate per person-year: 0 (both groups) # fractures: 0 (both groups) # people sustaining fractures: 0 (both groups) # people sustaining multiple events: 0 (both groups) | Post-test | 67.9±21.4 | 46.3±22.7 | | | ADL: NR IADL: NR
Rubenstein 2000^100^ United States Fair | Fracture rate per person-year: 0 (both groups) # fractures: 0 (both groups) # people sustaining fractures: 0 (both groups) # people sustaining multiple events: 0 (both groups) | ANOVA (group × time): F(1,53) = 8.5 p=0.005 EuroQol: NR | | | | | ADL: NR IADL: NR
Wolf 1996^107^ United States Fair | Fracture rate per person-year: NR # fractures: NR # people sustaining fractures: NR # people sustaining multiple events:NR | SF-12: NR SF-36: NR EuroQol: NR | | | | | ADL: NR IADL: No significant changes observed across groups

# number; % – percent; IG – intervention group; CG – control group; SF-36 – 36-item Short Form Health Survey; SF-12 – 12-item Short Form Health Survey; NR – not reported; ADL – activities of daily living; IADL – instrumental activities of daily living; Diff – difference; SD – standard deviation; CI – confidence interval; ANOVA – analysis of variance; ET – endurance training; ST – strength training

NOTE: Luukenin 2007^93^, Robertson 2001^95^, and Campbell 2005^63^ only report mortality for data relevant to KQ 1. See Appendix C Table 5 for more detail.

Components of multifactorial assessment and management interventions are described in Table 8. The primary fall risk factors identifiable during a clinical evaluation were generally evaluated as part of the multifactorial assessments;109 the majority of assessments included visual acuity, gait and balance, medication use, and home environment. We evaluated a total of 16 different active treatment arms in 14 trials that ranged from comprehensive (multifactorial assessment and provision of medical and social care) 69,75,76,78,80,82,108 to noncomprehensive (multifactorial assessment and referral or limited management).62,71,75,79,81,83,84,101 Control groups primarily received usual care, although two trials (described in three studies) provided social visits designed to mirror time and attention provided to the intervention group.69,82,110 These may at least partially explain the reduced effect size reported in one of these trials.82

Table 8 Multifactorial Clinical Assessment Trials: Components

| Multifactorial Assessment | | | | | | | Assessment-Based Intervention
Study ID | Orthostatic hypotension | Visual acuity | Gail and balance examination | Medication use | Cognition | Home environment | Other
Close 1999^80^ | X | X | X | X | X | X | Disability, psychological | Referral plus comprehensive intervention
Elley 2008^79^ | X | X | X | X | | X | Continence, cardiovascular, bone health | Referral and targeted intervention (exercise)
Hendriks 2008^84^ | X | X | X | X | X | X | Hearing, range of motion, foot assessment, psychological, disability | Referral only
Hogan 2001^82^ | X | X | X | X | | X | Behavior, alcohol use, disability | Referral plus comprehensive intervention
Lightbody 2002^77^ | X | X | X | X | X | X | Hearing, cardiovascular, foot assessment, psychological | Referral only
Lord 2005^62^ | | X | X | | | | Physiological tests including strength and reaction time | IG1: Referral plus comprehensive intervention IG2: Referral plus education
Newbury 2001^81^ | | X | | X | | X | Hearing, alcohol use, disability, nutrition, social, psychological | Referral only
Shumway-Cook 2007^83^ | | X | X | X | | | Physical activity, alcohol use, psychological, disability | Referral and targeted intervention (exercise)
Tinetti 1994^69^ | X | | X | X | | X | Disability | Referral plus comprehensive intervention
Van Haastregt 2000^71^ | | | | X | X | X | Disability, psychological, social, general examination | Referral plus education
Wagner 1994^78^ | | X | | X | | X | Physical activity, alcohol use, hearing | Referral plus comprehensive intervention

We conducted meta-analyses of all 14 trials reporting risk for falling. The reduced risk for falling was not statistically significant (RR, 0.90 [95% CI, 0.80 to 1.02]), but the statistical heterogeneity was substantial (I^2^=79.6%). After removing one study that appeared to be an outlier,80 the heterogeneity was reduced to 44.9% and the relative risk estimate was attenuated to 0.96 (95% CI, 0.90 to 1.04). Publication bias was assessed using the funnel plot and Egger’s regression test; no important publication bias was detected. Of the study-level factors evaluated in a meta-regression, only comprehensiveness (comprehensive vs. noncomprehensive) explained a significant amount of the heterogeneity in the effect estimate (−0.30 [SE, 0.11]) (p=0.009).

Given the significant results in the meta-regression for comprehensiveness, we conducted meta-analyses stratified by the comprehensiveness of the intervention (Figures 5 and 6). The pooled relative risk was 0.75 among the seven comprehensive trial arms (95% CI, 0.58 to 0.99). The statistical heterogeneity, however, was substantial (I^2^=86.4%). This analysis was restricted to the most comprehensive arm of the trials with two intervention arms.62,75 After removing an outlier,80 the heterogeneity was substantially reduced to 44.4% and the relative risk remained significant (RR, 0.90 [95% CI, 0.82 to 0.99]). The remaining heterogeneity was not explained in meta-regressions using study-level variables. Among the seven noncomprehensive trial arms, the risk for falling was not reduced (RR, 1.04 [95% CI, 0.98 to 1.10]). The statistical heterogeneity was low (I^2^=0%).

Among the comprehensive interventions, one study also reported a significant reduction in fall rate. Tinetti and colleagues reported 31% reduction in fall rate in the intervention group compared with the control group (incidence rate ratio, 0.69 [95% CI, 0.52 to 0.90]).69 Only one noncomprehensive trial measured fall rate and reported no reduction in the rate of falling.79

Study design and quality. We rated two79,83 trials as good quality and the remaining trials as fair quality (see Appendix B Table 3 for quality criteria). Most trials did not report whether treatment allocation was blinded or whether those conducting followup assessments were blind to the treatment condition. The majority had retention rates between 70% and 90%. While recent trials used prospective methods to assess falls, older studies 78,101 assessed falls retrospectively after 12 months. Most trials reported the percentage of fallers based on the number available for analysis rather than the number randomized.

Overall, the results of these trials may not be generalizable to nonwhite or Hispanic older adults, or older adults with cognitive limitation or physical disability. Two studies relied on self-referral from community-based or health-care based advertising,82,83 and thus may have enrolled participants who were more motivated to participate in interventions. The 12-month risk for falling in the control group ranged from 37%^78^ to 79%^82^ following study initiation.82 Overall, the risk for falling in the included participants was higher than that of the average community-dwelling adult aged 65 years and older, of whom approximately one third fall every year.16 Thus, these findings may be most relevant to a high-risk population. Additionally, the majority of these studies were conducted outside of the United States and may vary from “usual care” in the United States.

### Single Clinical Treatment

Sixteen trials evaluating single clinical treatment strategies to reduce falling are described by subgroups: vitamin D (with or without calcium),67,86,89,92,98,99,102,111 vision correction,61,87,90,91 hip protectors,66,85 medication withdrawal,112 and nutritional supplementation88 (Table 9).

Table 9 Study Characteristics of Clinical Management Interventions to Prevent Falls (KQ 2)

For more details of each study see Appendix C Table 2

Study reference, Setting, USPSTF quality rating | N patients randomized, Age | Intervention and control description, Length of followup | Risk category, % high risk | # (%) fallers, # (%) frequent fallers | | | High risk status | Adverse effects
Hip protectors
Birks 2004^85^ United Kingdom Fair | Randomized: 4,169 IG: 1388 CG: 2781 Mean age (SD): IG: 77.9 (5.7) CG: 77.8 (5.5) | Intervention: Hip protectors Control: Leaflet Followup: Median 28 mo | Risk category: Other (≥1 risk factor for hip fracture) Proportion: 100% | # (%) fallers: | | | All are high risk | NR
Birks 2004^85^ United Kingdom Fair | Randomized: 4,169 IG: 1388 CG: 2781 Mean age (SD): IG: 77.9 (5.7) CG: 77.8 (5.5) | Intervention: Hip protectors Control: Leaflet Followup: Median 28 mo | Risk category: Other (≥1 risk factor for hip fracture) Proportion: 100% | | IG | CG | All are high risk | NR
Birks 2004^85^ United Kingdom Fair | Randomized: 4,169 IG: 1388 CG: 2781 Mean age (SD): IG: 77.9 (5.7) CG: 77.8 (5.5) | Intervention: Hip protectors Control: Leaflet Followup: Median 28 mo | Risk category: Other (≥1 risk factor for hip fracture) Proportion: 100% | | | | All are high risk | NR
Birks 2004^85^ United Kingdom Fair | Randomized: 4,169 IG: 1388 CG: 2781 Mean age (SD): IG: 77.9 (5.7) CG: 77.8 (5.5) | Intervention: Hip protectors Control: Leaflet Followup: Median 28 mo | Risk category: Other (≥1 risk factor for hip fracture) Proportion: 100% | 12 mo | 261 (27.7) | 726 (37.5) | All are high risk | NR
Birks 2004^85^ United Kingdom Fair | Randomized: 4,169 IG: 1388 CG: 2781 Mean age (SD): IG: 77.9 (5.7) CG: 77.8 (5.5) | Intervention: Hip protectors Control: Leaflet Followup: Median 28 mo | Risk category: Other (≥1 risk factor for hip fracture) Proportion: 100% | 24 mo | 111 (24.1) | 304 (30.5) | All are high risk | NR
Birks 2004^85^ United Kingdom Fair | Randomized: 4,169 IG: 1388 CG: 2781 Mean age (SD): IG: 77.9 (5.7) CG: 77.8 (5.5) | Intervention: Hip protectors Control: Leaflet Followup: Median 28 mo | Risk category: Other (≥1 risk factor for hip fracture) Proportion: 100% | # (%) frequent fallers (2+ falls): NR | | | All are high risk | NR
Cameron 2003^66^ Australia Fair | Randomized: 600 IG: 302 CG: 298 Mean age (SD): 83 IG: 83.2 (5.1) CG: 83.0 (4.9) | Intervention: Hip protectors Control: Not explicit Followup: 24 mo | Risk category: Other (fall history) Proportion: 100% | # (%) fallers: NR # (%) frequent fallers (2+ falls): IG: 139 (46) CG: 131 (44) | | | All are high risk | IG: 3 fractures while wearing hip protectors; 5 significant bruises; 16 (5%) had skin irritation/infection
Pharmacological/nutrition intervention
Campbell 1999^112^ New Zealand Fair (study also located in Exercise/PT) | Randomized: 93 (3 IGs) MW: 24 CG: 24 Mean age (SD): MW: 74.6 (5.5) CG: 75.2 (5.6) | Intervention: Medication reduction Control: Original medication in study capsules Followup: 44 wks | Risk category: Medication specific (taking psychotropics Proportion: 100% | # (%) fallers: NR # (%) frequent fallers (2+ falls): NR (Article reports fall rate per person-year and total # of falls) | | | All are high risk | NR
Gray-Donald 1995^88^ Canada Fair | Randomized: 50 IG: 25 CG: 25 Mean age (SD): IG: 76 (7) CG: 79 (8) | Intervention: Cans of liquid supplement and home visits Control: Home visits Followup: 12 wks | Risk category: Other (nutritional risk) Proportion: 100% | # (%) fallers: | | | All are high risk | NR
Gray-Donald 1995^88^ Canada Fair | Randomized: 50 IG: 25 CG: 25 Mean age (SD): IG: 76 (7) CG: 79 (8) | Intervention: Cans of liquid supplement and home visits Control: Home visits Followup: 12 wks | Risk category: Other (nutritional risk) Proportion: 100% | | Baseline | 12 wks | All are high risk | NR
Gray-Donald 1995^88^ Canada Fair | Randomized: 50 IG: 25 CG: 25 Mean age (SD): IG: 76 (7) CG: 79 (8) | Intervention: Cans of liquid supplement and home visits Control: Home visits Followup: 12 wks | Risk category: Other (nutritional risk) Proportion: 100% | | | | All are high risk | NR
Gray-Donald 1995^88^ Canada Fair | Randomized: 50 IG: 25 CG: 25 Mean age (SD): IG: 76 (7) CG: 79 (8) | Intervention: Cans of liquid supplement and home visits Control: Home visits Followup: 12 wks | Risk category: Other (nutritional risk) Proportion: 100% | IG | 6 (25) | 0 (0) | All are high risk | NR
Gray-Donald 1995^88^ Canada Fair | Randomized: 50 IG: 25 CG: 25 Mean age (SD): IG: 76 (7) CG: 79 (8) | Intervention: Cans of liquid supplement and home visits Control: Home visits Followup: 12 wks | Risk category: Other (nutritional risk) Proportion: 100% | IG | 5 (33) | 0 (0) | All are high risk | NR
Gray-Donald 1995^88^ Canada Fair | Randomized: 50 IG: 25 CG: 25 Mean age (SD): IG: 76 (7) CG: 79 (8) | Intervention: Cans of liquid supplement and home visits Control: Home visits Followup: 12 wks | Risk category: Other (nutritional risk) Proportion: 100% | (≥7 cans/wk) | | | All are high risk | NR
Gray-Donald 1995^88^ Canada Fair | Randomized: 50 IG: 25 CG: 25 Mean age (SD): IG: 76 (7) CG: 79 (8) | Intervention: Cans of liquid supplement and home visits Control: Home visits Followup: 12 wks | Risk category: Other (nutritional risk) Proportion: 100% | CG: | 1 (4) | 5 (21) | All are high risk | NR
Gray-Donald 1995^88^ Canada Fair | Randomized: 50 IG: 25 CG: 25 Mean age (SD): IG: 76 (7) CG: 79 (8) | Intervention: Cans of liquid supplement and home visits Control: Home visits Followup: 12 wks | Risk category: Other (nutritional risk) Proportion: 100% | # (%) frequent fallers (2+ falls): NR | | | All are high risk | NR
Vision correction
Cumming 2007^90^ Australia Fair | Randomized: 616 IG: 309 CG: 307 Mean age (SD): IG: 80.9 (6.3) CG: 80.3 (5.7) | Intervention: Eye exam and treatment Control: Usual care Followup: 1 yr | Risk category: Other (frailty) Proportion: 100% | # (%) fallers: IG: 201 (65.0) CG: 153 (49.8) # (%) frequent fallers (2+ falls): IG: 117 (37.9) CG: 153 (30.6) | | | Effect similar in those with and wothout history of falls in past yr (RR, 2.11 [1.44–3.08] vs. RR, 1.52 [1.09–2.10]) | Increased fall and fracture risk in the IG
Day 2002^61^ Australia Fair (study also located in Exercise/PT & HH) | Randomized: 1,107 Continued: 1,090 (7 IGs) IG: 139 CG: 137 Mean age (SD): All: 76.1 (5.0) | Intervention: Those with poor vision went to usual eye care provider, rest got leaflet Control: Waitlist control Followup: 18 mo | Risk category: NR Proportion: NA | # (%) fallers: IG: 84 (60.4) CG: 87 (63.5) # (%) frequent fallers (2+ falls): NR | | | NA | NR
Foss 2006^91^ United Kingdom Fair | Randomized: 239 IG: 120 CG: 119 Mean age (range): IG: 79.2 (70–90) CG: 79.9 (70–92) | Intervention: Cataract surgery Control: Routine wait for surgery Followup: 1 yr | Risk category: Eye disease, visual impairment Proportion: 100% | # (%) fallers: IG: 48 (40) CG: 41 (34) # (%) frequent fallers (2+ falls): IG: 22 (18) CG: 22 (18) | | | All are high risk | Iris damage, posterior capsular rupture, posterior capsular opacification noted at 6 months
Harwood 2005^87^ United Kingdom Good | Randomized: 306 IG: 154 CG: 152 Median age (range): IG: 78.8 (70–95) CG: 78.1 (70–90) | Intervention: Cataract surgery Control: Routine wait for surgery Followup: 1 yr | Risk category: Eye disease, visual impairment Proportion: 100% | # (%) fallers: IG: 76 (49) CG: 69 (45) # (%) frequent fallers (2+ falls): IG: 28 (18) CG: 38 (25) | | | All are high risk | Iris damage, posterior capsular rupture, posterior capsular opacification noted at 6 months
Vitamin D
Bischoff-Ferrari 2006^111^ Dawson-Hughes 1997^163^ United States Fair | Randomized: 445 IG: 219 CG: 226 Mean age (SD): IG: women: 71 (5) men: 70 (4) CG: women: 71 (5) men: 71 (5) | Intervention: Vitamin D Control: Placebo Followup: 3 yrs | Risk category: Other (female sex, less physically active, and lower 25-OHD levels) Proportion: Female: 55.3% Female + less physically active: 43.5% Male + less physically active: 40.2% 25-OHD<32 ng/mL: NR | # (%) fallers: IG: 107 (49) CG: 124 (55) # (%) frequent fallers (2+ falls): NR | | | Reduced odds of falling in ambulatory older women by 46% and less-active women by 65%. 69 (50%) less active and 65 (61%) more active women fell. 36 (46%) less active and 60 (50%) more active men fell. Vit D/calcium reduced odds of falling in women (OR, 0.54 [0.30–0.97]) but not men (OR, 0.93 [0.50–1.72]). Fall reduction most pronounced in less active women (OR, 0.35 [0.15–0.81]). | NR
Dhesi 2004^102^ United Kingdom Fair | Randomized: 139 IG: 70 CG: 69 Mean age (SD): IG: 77.0 (6.3) CG: 76.6 (6.1) | Intervention: Vitamin D Control: Placebo Followup: 6 mo | Risk category: Other (fall history) Proportion: 100% | # (%) fallers (calc): IG: 11 (15.7) CG: 14 (20.3) # (%) frequent fallers (2+ falls): NR | | | All are high risk | NR
Dukas 2004^92^ Switzer-land Fair | Randomized: 378 IG: 193 CG: 187 Mean age (SD): IG: 75.0 (4.4) CG: 75.0 (4.1) | Intervention: Vitamin D Control: Placebo Followup: 36 wks | Risk category: Other (low calcium intake) Proportion: IG: 50.0% CG: 48.4% | # (%) fallers: IG: 40 (20.8) CG: 46 (24.7) # (%) frequent fallers (2+ falls): NR | | | # falls: ≥ 512 mg/d daily Ca intake IG: 28 (29) CG: 22 (24) <512 mg/d daily Ca intake IG: 18 (19) CG: 29 (30) # (%) fallers: ≥ 12 mg/d daily Ca intake IG: 24 (25) CG: 20 (22) <512 mg/d daily Ca intake IG: 16 (17) CG: 26 (27) | 6 (1 in CG, 5 in IG) had slight transient hypercalcemia, 2 in IG had mild asymptomatic hypercalcemia; no significant diff in serious adverse effects attributable to treatment
Pfeifer 2000^98^ Germany Fair | Randomized: 148 IG: 74 CG: 74 Mean age (SD): IG: 74.8 (0.5) CG: 74.7 (0.5) | Intervention: Vitamin D and calcium Control: Placebo and calcium Followup: 1 yr | Risk category: Other (vitamin D deficient) Proportion: 100% | # (%) fallers: IG: 11 (16) CG: 19 (28) # (%) frequent fallers (2+ falls): NR | | | All are high risk | NR
Porthouse 2005^67^ England Fair | Randomized: 3454 IG: 1321 CG: 1993 Mean age (SD): IG: 77.0 (5.10) CG: 76.7 (5.02) | Intervention: Nurse visit and supply of Ca and vit D. Brochure on general falls prevention and appropriate Ca/vit D intake from dietary sources Control: Brochure only Followup: Median 25 mo | Risk category: N/A Proportion: N/A | # (%) fallers: NR # (%) frequent fallers (2+ falls): NR Odds of falling by 12 mo after supplementation, 0.98 (95% CI, 0.79–1.2) | | | N/A | NR
Prince 2008^89^ Australia Fair | Randomized: 302 IG: 151 CG: 151 Mean age (SD): IG: 77.0 (4.2) CG: 77.4 (5.0) | Intervention: Vitamin D and calcium Control: Calcium Followup: 1 year | Risk category: Other (vitamin D deficient and fall history) Proportion: 100% | # (%) fallers: IG: 80 (53.0) CG: 95 (62.9) # (%) frequent fallers (2+ falls): NR | | | All are high risk | No diff in cancer, ischemic heart disease, stroke, constipation, or fracture rates; 1 in IG had mild asymptomatic hypercalcemia

N – number; # – number; % – percent; USPSTF – U.S. Preventive Services Task Force; IG – intervention group; CG – control group; SD – standard deviation; NR – not reported

Summary of findings. Vitamin D. Among seven fair-quality trials (n=5,216) in adults aged 71–77 years on average, vitamin D with or without calcium was associated with a reduced risk for falling during 6 to 36 months of followup (pooled RR, 0.83 [95% CI, 0.75 to 0.91]) (I^2^=14.6%).67,86,89,92,98,99,102,111 Only one of the individual trials,99 however, reported a statistically significant reduction in fall risk (Figure 7).

Figure 7 Pooled Risk for Falling In Single Clinical Treatment Interventions: Vitamin D (KQ 2)

Figure 7 displays a forest plot of all vitamin D trials reporting between-group differences in risk for falling. Data for the figure are presented alongside the forest plot. The pooled relative risk for falling was 0.83 (95% CI, 0.75 to 0.91), with low statistical heterogeneity (chi-square=14.6%).

Vision correction. Among four fair- to good-quality trials (n=1,437) in adults aged 76–81 years on average, risk for falling during 12 to 18 months of followup was not reduced as a result of vision correction (improving acuity or correcting cataracts with surgery).61,87,90,91

Hip protectors. In two trials (n=4,769), the effect of hip protectors on falling risk was mixed among high-risk women aged 78–83 years on average, with a significant protective effect in one trial85 and no effect in the second.66 Adherence to the hip protectors was low in both studies.

Medication withdrawal. One fair-quality study (n=48) among adults with an average age of 75 years reported no reduction in fall rate associated with medication withdrawal (with or without exercise).112 An additional three multifactorial assessment and management interventions also included medication assessment and management and were effective in preventing fallers.78,80,82

Protein supplementation. In one fair-quality study (n=50) among frail adults with an average age of 78 years, nutritional supplements and home visits over 12 weeks were significantly associated with a reduced risk for falling (zero falls in the intervention group vs. five falls in the control group at 3 months) (p<0.05).88

Study details. Vitamin D. We evaluated eight trials (n=5,216) of vitamin D supplementation conducted in community-dwelling older adults aged 71–77 years on average (Table 9). These studies included more women than men. Four of the trials’ participants were 100% female and the remaining four’s participants ranged from 51% to 80% female. Six studies did not report race or ethnicity; the two that did consisted primarily of nonHispanic white participants (77% to 97%).102,111 Four trials were conducted in populations defined as high risk by virtue of recent falls and/or vitamin D deficiency, and the remaining four studies used populations that were unselected except for age (≥65 years).

The overall vitamin D intervention dosages ranged from 22,400 IU over 8 weeks98 to 766,500 IU over 36 months.111 Delivery was variable across studies, including intramuscular injection, daily oral dose, and mega oral dose every 4 months. Two of the studies evaluated ergocalciferol (vitamin D2)89,102 and the remaining studies evaluated cholecalciferol (vitamin D3). Five trials included calcium supplements with the vitamin D. The control groups ranged from no intervention to placebo to calcium supplements only.

Among adults aged 71–77 years on average (n=5,216), vitamin D with or without calcium was associated with a reduced risk for falling during 6 to 36 months of followup (pooled RR, 0.83 [95% CI, 0.75 to 0.91]) (I^2^=14.6%). However, only one of the individual trials reported statistically significant reductions (Table 9, Figure 7).99 Only one study evaluated differences in fall rate and reported a significantly lower rate of falls in the group receiving calcitriol compared with the group receiving placebo (0.27 falls/year in intervention group vs. 0.43 falls/year in placebo group [p=0.0015]). The majority of these trials were not sufficiently powered to observe a significant reduction in risk for falling. Excluding one large study,67 these individual studies randomized between 139 to 445 participants. Two of the trials conducted analyses of the cumulative development of the number of subjects with no falls.99,111 These analyses suggest that the minimum required time to observe an effect on falls outcomes appears to be 12 months and that between group differences may be maintained but probably do not increase after 12 months.

All studies were rated as fair quality. Only three trials assessed falls prospectively using a diary or questionnaire;86,99,102 the remaining trials assessed falls retrospectively with periods of recall ranging from 6 weeks89 to 12 months.98

Vision correction. Four trials (n=1,437) in adults aged 76–81 years on average evaluated the effect of vision correction (after screening for visual impairment) on risk for falling. Three trials were conducted in populations deemed high-risk because of frailty or having uncorrected cataracts (with or without a history of falling). The fourth study had a population that was unselected except for age (>70 years). Two studies included only women and evaluated expedited cataract surgery compared with routine wait controls.87,91 One of the trials of expedited cataract surgery evaluated first cataract surgery,87 while the other evaluated second cataract surgery.91 The other two studies primarily included women (60%–68%) and evaluated vision screening and referral/treatment.61,90

None of the trials significantly reduced the risk for falling.61,87,90,91 The trial evaluating first cataract surgery, however, reported a significantly reduced fall rate among the intervention group participants compared with the controls. Rate of falling was reduced by 34% in the operated group (incidence rate ratio, 0.66 [95% CI, 0.45 to 0.96]).87 One of the trials that evaluated the effect of visual treatment impairment based on screening results reported a statistically significant 30% increased risk for falling in the intervention group compared with the control group (95% CI, 14 to 50).90 This result is described further in KQ 3 (harms). Studies were rated as fair- to good-quality.

Hip protectors. In one large, fair-quality study (n=4,169), hip protectors were associated with a significant reduction in 12-month risk for sustaining a fall among high-risk women with an average age of 78 years (28% in the intervention group vs. 38% in the control group [p<0.001]).85 These results may be conservative, as the 6-month adherence rate among the intervention group was 38%. A second smaller, fair-quality study reported no significant effect of hip protectors on the total number of falls or on being a frequent faller.66 This study employed a study nurse to make routine home visits to encourage use of the hip protectors among intervention group participants. While the adherence was higher in this study than in others, it was still low (57% after 12 months) (Table 9). Additional study details were provided in KQ 1.

Medication withdrawal. One fair-quality study (n=48) evaluated the influence of medication withdrawal (with and without exercise) on fall outcomes among adults with an average age of 75 years and taking psychotropic medications, but did not report fall risk.112 The number of falls per group was lower in the intervention group (17 falls out of 48 people) compared with the control group (29 falls out of 22 people). The fall rate, however, was not significantly lower among the intervention group compared with the groups that did not receive medication withdrawal (difference of 0.64 falls/person-year [95% CI, −0.07 to 1.35]) (Table 9). These results compare the rate of falling among the trial arms that received medication withdrawal (medication withdrawal alone and medication withdrawal plus exercise) to the rate of falling in the trial arms that did not receive medication withdrawal (exercise plus regular medications with no alteration and a control group that received only regular medications). An additional four multifactorial assessment and management interventions also included medication assessment and withdrawal.75,78,80,82 All four trials were associated with a significantly reduced risk for falling. The pooled estimate for all five studies together was noninformative because of high statistical heterogeneity (I^2^=91.9%). These studies have been described previously, thus they are not discussed further in this section.

Protein supplementation. One small study (n=50) evaluated the effect of protein supplementation among frail adults with an average age of 79 years.88 The majority of participants were female and had less than high school education. All were frail and at nutritional risk, defined as involuntary weight loss of greater than 5% body weight in previous month, greater than 7.5% in 3 months, or greater than 10% in 6 months, and a body mass index of less than 24.

The intervention group received 235 mL of liquid supplement twice a day and home visits once per week. The control group received weekly home visits providing encouragement and dietary suggestions. The intervention was associated with a reduced risk for falling (zero falls in the intervention group vs. five falls in the control group at 3 months [p<0.05]).

This study was rated fair quality. Outcome assessors were blinded to intervention status and there was no attrition from assessment during the 3-month followup. However, participants in the control group were slightly more likely to report having a good appetite at baseline (suggesting potentially better health) and falls were assessed retrospectively at 6 and 12 weeks.

### Exercise and Physical Therapy

Summary of findings. Of the 17 fair- to good-quality trials (n=3,716) of exercise/physical therapy in community-dwelling older adults, 13 were consistent with a reduced risk for falling. The majority of differences, however, were not statistically significant. Pooled data suggest that those participating in an exercise/physical therapy intervention were less likely to fall during followup (RR, 0.86 [95% CI, 0.80 to 0.92) (I^2^=5.4%) (Figure 8). There was an indication that exercise had a greater effect on fall risk in the trials that were conducted in higher-risk populations (Figures 9 and 10).

Figure 8 Pooled Risk for Falling in Exercise/Physical Therapy Interventions (KQ 2)

Figure 8 displays a forest plot of all exercise/physical therapy trials reporting between-group differences in risk for falling. Data for the figure are presented alongside the forest plot. The pooled relative risk for falling was 0.86 (95% CI, 0.80 to 0.92), with low statistical heterogeneity (chi-square=5.4%).

Figure 9 Pooled Risk for Falling in Exercise/Physical Therapy Interventions (KQ 2): Low-Risk Populations*

Figure 9 displays a forest plot of all exercise/physical therapy trials conducted in low-risk populations (risk for falling in the control group was 35% or less) and reporting between-group differences in risk for falling. Data for the figure are presented alongside the forest plot. The pooled relative risk for falling was 0.98 (95% CI, 0.82 to 1.62), with low statistical heterogeneity (chi-square=0%).

Figure 10 Pooled Risk for Falling in Exercise/Physical Therapy Interventions (KQ 2): High-Risk Populations*

Figure 10 displays a forest plot of all exercise/physical therapy trials conducted in high-risk populations (risk for falling in the control group was greater than 35%) and reporting between-group differences in risk for falling. Data for the figure are presented alongside the forest plot. The pooled relative risk for falling was 0.84 (95% CI, 0.78 to 0.91), with low statistical heterogeneity (chi-square=1.1%).

Study details. These trials (n=3,985) randomized community-dwelling older adults to exercise/physical therapy interventions (Table 10). The majority of participants were aged 75 years or older on average. In five trials, the average age was 80 or older.63,93,95,113 Women were more common than men in the majority of trials; most trials consisted of between 60% and 100% female participants. One study was restricted to men,100 and three trials were evenly split or had more men.94,96,105 The majority of trials did not report race or ethnicity. The trials reporting race or ethnicity data were primarily nonHispanic white (≥90%). Ten of the physical activity trials were conducted in high-risk populations. Of these 10 trials, three were identified based on gait and balance impairments,100,104,105 one based on falls during the past year or one or more risk factors for falling,93,114 one based on use of psychotropic medication,112 and one based on visual impairment; two were restricted based on chronic disease status (Parkinson’s disease plus at least one fall in the previous year)96 or recent stroke,94 and one included only people with a recent hospitalization or period of bed rest.107 The remaining studies were conducted in unselected populations.61,95,97,107,108,115,116 The percentage of participants who reported falling during the 12 months preceding the intervention (excluding trials that selected participants based on history of a fall at baseline) ranged from 10% to 64%.

Table 10 Study Characteristics of Exercise/Physical Therapy Interventions to Prevent Falls (KQ 2)

For more details of each study see Appendix C Table 5

Study reference, Setting, USPSTF quality rating | N patients randomized, Age, Length of followup | Risk category, % high risk | # (%) fallers, # (%) frequent fallers | | | High risk status | Adverse effects
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | # (%) fallers: | | | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | | IG | CG | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | | | | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | 8 wks | 37 (57) | 42 (66) | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | 6 mo | 46 (73) | 49 (78) | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | # (%) frequent fallers (2+ falls): | | | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | | IG | CG | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | | | | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | 8 wks | 21 (32) | 28 (44) | All are high risk | NR
Ashburn 2007^96^ United Kingdom Fair | Randomized: 142 IG: 70 CG: 72 Mean age (SD): IG: 72.7 (9.6) CG: 71.6 (8.8) Followup: 6 mo | Risk category: Parkinson’s disease Proportion: 100% | 6 mo | 35 (56) | 42 (68) | All are high risk | NR
Barnett 2003^104^ Australia Fair | Randomized: 163 IG: 83 CG: 80 Mean age (SD): IG: 74.4 (4.9) CG: 75.4 (6.0) Followup: 1 yr | Risk category: Gait and/or balance impairment Proportion: 100% | # (%) fallers/nonfallers: IG: 27 (35.5) CG: 37 (50.0) # (%) frequent fallers (2+ falls): IG: 8 (10.8) CG: 18 (24.3) | | | All are high risk | NR
Buchner 1997^105^ Buchner 1993^106^ United States Fair | Randomized: 105 to FICSIT IG (ET): 25 IG (ST): 25 IG (ET+ST): 25 CG: 30 Mean age: IG(ET): 75 IG(ST): 75 IG(ET+ST): 74 CG: 75 Followup: 6 mo | Risk category: Other (balance and/or gait impairment) Proportion: 100% | # (%) fallers: Year 1 IG: 32 (42) CG: 18 (60) # (%) frequent fallers (2+ falls): NR | | | All are high risk | NR
Campbell 1997^97^ New Zealand Fair | Randomized: 233 IG: 116 CG: 117 Mean age (SD): IG: 84.1 (3.1) CG: 84.1 (3.4) Followup: 1 yr | Risk category: Unselected (authors describe as a high risk population because all are female) Proportion: NA | # (%) fallers (calc): IG: 53 (46) CG: 62 (53) # (%) frequent fallers (2+ falls): IG: 22 (19) CG: 34 (29) | | | All are high risk | NR
Campbell 1999^112^ New Zealand Fair (study also located in Clinical Mgmt) | Randomized: 93 (3 IGs) OM + Ex: 21 CG: 24 Mean age (SD): OM + Ex: 73.1 (6.3) CG: 75.2 (5.6) Followup: 44 wks | Risk category: Medication- specific (taking psychotropics) Proportion: 100% | # (%) fallers: NR # (%) frequent fallers (2+ falls): NR (Fall rate per person-year and total # of falls reported) | | | All are high risk | NR
Campbell 2005^63^ New Zealand Fair (study also located in Home Hazard) | Randomized: 391 (3 IGs) IG (Otago): 97 CG: 96 Mean age (SD): IG (Otago): 83.4 (4.9) CG: 84.0 (4.9) Followup: 1 yr | Risk category: Eye diseases/visual impairment Proportion: 100% | # (%) fallers: IG (Otago): 47 (48) CG: 59 (61) # (%) frequent fallers (2+ falls): IG (Otago): 27 (28) CG: 29 (30) | | | All are high risk | NR
Day 2002^61^ Australia Fair (study also located in Clinical Mgmt & Home Hazard) | Randomized: 1107 (7 IGs) Continued: 1090 IG (ex): 135 CG: 137 Mean age (SD): All: 76.1 (5.0) Followup: 18 mo | Risk category: Unselected Proportion: NA | # (%) fallers: IG (ex): 76/135 (56.3) CG: 87/137 (63.5) # (%) frequent fallers (2+ falls): NR | | | NA | NR
Green 2002^94^ United Kingdom Fair | Randomized: 170 IG: 85 CG: 85 Mean age (SD): IG: 71.5 (8.7) CG: 73.5 (8.3) Followup: 9 mo | Risk category: Cerebrovascular disorder (stroke) Proportion: 100% | # (%) fallers: | | | All are high risk
Green 2002^94^ United Kingdom Fair | Randomized: 170 IG: 85 CG: 85 Mean age (SD): IG: 71.5 (8.7) CG: 73.5 (8.3) Followup: 9 mo | Risk category: Cerebrovascular disorder (stroke) Proportion: 100% | | IG | CG | All are high risk
Green 2002^94^ United Kingdom Fair | Randomized: 170 IG: 85 CG: 85 Mean age (SD): IG: 71.5 (8.7) CG: 73.5 (8.3) Followup: 9 mo | Risk category: Cerebrovascular disorder (stroke) Proportion: 100% | | | | All are high risk
Green 2002^94^ United Kingdom Fair | Randomized: 170 IG: 85 CG: 85 Mean age (SD): IG: 71.5 (8.7) CG: 73.5 (8.3) Followup: 9 mo | Risk category: Cerebrovascular disorder (stroke) Proportion: 100% | BL-3 months | 13 (16) | 809 (11) | All are high risk
Green 2002^94^ United Kingdom Fair | Randomized: 170 IG: 85 CG: 85 Mean age (SD): IG: 71.5 (8.7) CG: 73.5 (8.3) Followup: 9 mo | Risk category: Cerebrovascular disorder (stroke) Proportion: 100% | 3–6 months | 16 (22) | 15 (19) | All are high risk
Green 2002^94^ United Kingdom Fair | Randomized: 170 IG: 85 CG: 85 Mean age (SD): IG: 71.5 (8.7) CG: 73.5 (8.3) Followup: 9 mo | Risk category: Cerebrovascular disorder (stroke) Proportion: 100% | 6–9 months | 17 (24) | 10 (14) | All are high risk
Green 2002^94^ United Kingdom Fair | Randomized: 170 IG: 85 CG: 85 Mean age (SD): IG: 71.5 (8.7) CG: 73.5 (8.3) Followup: 9 mo | Risk category: Cerebrovascular disorder (stroke) Proportion: 100% | Overall | 30 (35) | 23 (27) | All are high risk
Green 2002^94^ United Kingdom Fair | Randomized: 170 IG: 85 CG: 85 Mean age (SD): IG: 71.5 (8.7) CG: 73.5 (8.3) Followup: 9 mo | Risk category: Cerebrovascular disorder (stroke) Proportion: 100% | # (%) frequent fallers (2+ falls): NR | | | All are high risk
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | # (%) fallers: | IG | CG | NA | NR
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | | | | NA | NR
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | During | 27 (28) | 43 (46) | NA | NR
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | 6 mo after | 15 (16) | 43 (46) | NA | NR
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | # (%) frequent fallers (2+ falls): | | | NA | NR
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | | IG | CG | NA | NR
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | | | | NA | NR
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | During | 7 (7) | 21 (22) | NA | NR
Li 2005^116^ United States Fair | Randomized: 256 IG: 125 CG: 131 Mean age (SD): IG: 76.94 (4.69) CG: 77.99 (5.14) Followup: 1 yr | Risk category: Unselected Proportion: NA | 6 mo after | NR | NR | NA | NR
Lord 1995^108^ Australia Fair | Randomized: 374 IG: 187 CG: 187 Mean age (SD): IG: 71.6 (5.5) CG: 71.7 (5.3) Followup: 1 yr | Risk category: Unselected Proportion: NA | # (%) fallers: IG: 26 (34.7) CG: 33 (35.1) # (%) frequent fallers (2+ falls): IG: 8 (10.7) CG: 12 (12.8) | | | NA | NR
Luukinen 2007^93^ Finland Fair | Randomized: 486 IG: 243 CG: 243 Mean age (SD): IG: 88 (3) CG: 88 (3) Followup: 16 mo | Risk category: Other (various) Proportion: 100% had 1+ risk factors | # (%) fallers: IG: 126 (58) CG: 136 (62) # (%) frequent fallers (2+ falls): NR | | | All are high risk | NR
Morgan 2004^113^ United States Fair | Randomized: 294 IG: 119 CG: 110 Lost before BL: 49 Incomplete data: 16 (IG: 8, CG: 8) Mean age (SD): IG: 81.0 (7.6) CG: 80.1 (7.4) Followup: 1 yr | Risk category: Other (recent hospitalization or bed rest) Proportion: 100% | # (%) fallers: IG: 34 (28.6) CG: 34 (30.9) # (%) frequent fallers (2+ falls): NR | | | All are high risk | NR
Robertson 2001^95^ New Zealand Fair | Randomized: 240 IG: 121 CG: 119 Mean age (SD): IG: 80.8 (3.8) CG: 81.1 (4.5) Followup: 1 yr | Risk category: Unselected Proportion: NA | # (%) fallers: NR # (%) frequent fallers (2+ falls): NR (Fall rate per person-year and total # of falls reported) | | | NA | One participant fell while exercising as instructed
Rubenstein 2000^100^ United States Fair | Randomized: 59 IG: 31 CG: 28 Mean age (SD): IG: 76.4 (4.9) CG: 74.4 (43.4)* *Reported SD appears to be a typo Followup: 12 wks | Risk category: Gait and/or balance impairment Proportion: 100% | # (%) fallers: IG: 12 (38.7) CG: 9 (32.1) # (%) frequent fallers (2+ falls): NR | | | All are high risk | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | # (%) fallers: | IG | CG | NA | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | | | | NA | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | 16 wks | 61 (17.6) | 70 (20.8) | NA | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | 24 wks | 71 (20.5) | 81 (24.0) | NA | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | # (%) frequent fallers (2+ falls): | | | NA | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | | IG | CG | NA | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | | | | NA | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | 16 wks | 8 (2.3) | 13 (3.9) | NA | NR
Voukalatos 2007^115^ Australia Good | Randomized: 702 IG: 353 CG: 349 Mean age (SD): 69 (6.5) IG: 69 CG: 69 Followup: 6 mo | Risk category: Unselected Proportion: NA | 24 wks | 15 (4.3) | 27 (8.0) | NA | NR
Wolf 1996^107^ United States Fair | Randomized: 200 IG(TC): 72 IG(BT): 64 CG: 64 Mean age (SD): IG(TC): 76.9 (4.8) IG(BT): 76.3 (5.1) CG: 75.4 (4.1) Followup: 4 mo | Risk category: Unselected Proportion: NA | # (%) fallers: NR # (%) frequent fallers (2+ falls): NR (Total # of falls reported) | | | NA | NA

N – number; # – number; % – percent; USPSTF – U.S. Preventive Services Task Force; IG – intervention group; CG – control group; SD – standard deviation; NR – not reported; NA – not applicable; BL – baseline; FICSIT – Frailty and Injuries: Cooperative Studies of Intervention Techniques; ET – endurance training; ST – strength training; OM – original medication; Ex – exercise; TC – Tai Chi; BT – balance training

Trial characteristics are listed in Table 11. Exercise/physical therapy trials included a variety of components that can be summarized into three major categories: gait, balance, or functional training; strength or resistance exercise; and general exercise (including walking, cycling, aerobic activity, and endurance exercise). All but one trial included gait, balance, and/or functional training. The majority of trials included at least two exercise components, about half of which were primarily group-based exercises conducted in the community. The remaining trials were individual-based and generally conducted at home. Five studies were conducted in the United States. The remaining trials were conducted in the United Kingdom, Finland, Australia, and New Zealand.

Table 11 Components of Exercise/Physical Therapy Interventions

Study reference, Sample size (n) | Intervention components | Format and delivery of intervention (individual vs group-based, location, by whom) | Intensity* of physical activity interventions (hours) | Effect size (95% CI) for proportion of fallers
Ashburn 2007^96^ n=142 | Gait, balance, functional training: range of movement, balance training Strength resistance exercise: progressive muscle strengthening General (walking, aerobic, endurance): walking exercises Other: strategies for fall prevention and movement initiation/compensation | Individual In-home by physiotherapist | Very low | 0.94 (0.77 to 1.15)
Barnett 2003^104^ n=163 | Gait, balance, functional training: functional exercises, balance and coordination exercises Strength resistance exercise: strength work General (walking, aerobic, endurance): aerobic activity Other: home-based exercise program with diaries to record participation, written information on practical strategies for avoiding falls, such as hand and foot placement if loss of balance occurred | Individual and group Classes in community setting by accredited exercise instructor, plus home exercise | Medium | 0.71 (0.49 to 1.04)
Buchner 1997^105^ n=105 | Gait, balance, functional training: None Strength resistance exercise: one or two sets of 10 reps of resistence training with weight machines General (walking, aerobic, endurance): stationary bicycles Other: None | Group-based Location and instructor NR | Medium | 0.71 (0.48 to 1.05)
Campbell 1997^97^ n=233 | Gait, balance, functional training: balance exercises Strength resistance exercise: strength exercises General (walking, aerobic, endurance): walking plan Other: None | Individual In-home by physiotherapist | High | 0.86 (0.66 to 1.12)
Campbell 1999^112^ n=93 | Gait, balance, functional training: balance training Strength resistance exercise: muscle strengthening General (walking, aerobic, endurance): walking plan Other: None | Individual In-home by physiotherapist | Low | 0.67 (0.47 to 0.95)
Campbell 2005^63^ n=391 | Gait, balance, functional training: balance exercises Strength resistance exercise: strength exercises General (walking, aerobic, endurance): walking plan Other: None | Individual In-home by physiotherapist | High | 0.79 (0.61 to 1.02)
Day 2002^61^ n=1107 | Gait, balance, functional training: exercises to improve flexibility And Balance Strength Resistance Exercise: exercises to improve leg strength General (walking, aerobic, endurance): None Other: None | Individual and group Classes plus home exercise, location and instructor NR | Low | 0.83 (0.71 to 0.97)
Green 2002^94^ n=170 | Gait, balance, functional training: details NR Strength resistance exercise: None General (walking, aerobic, endurance): None Other: None | Individual Assessed at a PT center; intervention at home or in outpatient rehabilitation center by physiotherapist | Very low | 1.34 (0.87 to 2.07)
Li 2005^116^ n=256 | Gait, balance, functional training: Tai Chi following the 24-form Yang style and synchronized breathing Strength resistance exercise: None General (walking, aerobic, endurance): None Other: None | Group-based Location NR, Tai Chi instructors | High | 0.61 (0.42 to 0.91)
Lord 1995^108^ n=374 | Gait, balance, functional training: activities for flexibility and hand-eye and foot-eye coordination Strength resistance exercise: strenghthening exercises General (walking, aerobic, endurance): aerobic exercises and activities for endurance Other: None | Group-based Classes at a community hall and a public hospital, instructor NR | High | 0.99 (0.65 to 1.50)
Luukinen 2007^93^ n=486 | Gait, balance, functional training: home exercises in a standing position if possible, sitting if not, lying if neither Strength resistance exercise: None General (walking, aerobic, endurance): walking exercises Other: None | Individual and group-based Exercises in small groups, location NR; self-care exercises at home, by physiotherapist and occupational therapist | Very low | 0.94 (0.81 to 1.10)
Morgan 2004^113^ n=294 | Gait, balance, functional training: exercise to directly affect neuromuscular functioning, balance, and gait Strength resistance exercise: exercise for neuromuscular functioning includes element of muscle strength General (walking, aerobic, endurance): None Other: None | Group-based Location NR, physical therapist and physical therapy assistant | Low | 0.92 (0.62 to 1.38)
Robertson 2001^95^ n= 240 | Gait, balance, functional training: progressive balance retraining Strength resistance exercise: progressive muscle stregthening General (walking, aerobic, endurance): walking plan Other: None | Individual In-home, by nurses and physiotherapist | High | Cannot calculate
Rubenstein 2000^100^ n=59 | Gait, balance, functional training: balance training Strength resistance exercise: strength training General (walking, aerobic, endurance): endurance training Other: None | Group-based Classes at VA Ambulatory Care Center by exercise physiology graduate students | Medium | 1.20 (0.60 to 2.42)
Voukalatos 2007^115^ n=702 | Gait, balance, functional training: Tai Chi, generally Sun style Strength resistance exercise: None General (walking, aerobic, endurance): None Other: None | Group-based Classes at community venues by experienced or accredited Tai Chi instructors | Low | 0.85 (0.64 to 1.13)
Wolf 1996^107^ n=200 | Gait, balance, functional training: Tai Chi or balance training (standing on a platform and moving cursor on screen to target by moving center of mass, without foot displacement) Strength resistance exercise: None General (walking, aerobic, endurance): None Other: None | Tai Chi: group-based Location NR and instructor NR Balance training: individual Location and instructor NR | Low | Cannot calculate

N – sample size; CI – confidence interval; NR – not reported; PT – physical therapy; VA – Veterans Administration

NOTE: Control group descriptions are not shown. Control groups were true controls (e.g., usual care, minimal intervention, or attention control).

We evaluated a total of 20 treatment arms in 17 unique trials. Three trials evaluated 12-month interventions.63,95,104 The duration of the remaining trials ranged from 6 to 26 weeks (median, 12.5 weeks). Treatment intensity (estimated in hours of contact) ranged from 2 to 80 hours. Control groups varied from no treatment/usual care to social visits or educational information unrelated to falls. One Tai Chi intervention matched the number of contact hours in the intervention group with stretching and relaxation classes.116

The majority of trials were consistent with a beneficial effect on falling or fall rate compared with controls. Most of these differences, however, were not statistically significant. Across all trials, the 12-month risk for falls in the intervention group compared with the control group ranged from 39% lower116 to 34% higher.94 Meta-analysis of all 15 trials reporting fall risk was conducted (Figure 8). Among physical activity interventions, the pooled relative risk estimate for reduction in percentage of fallers comparing the intervention to the control group was 0.86 (95% CI, 0.80 to 0.92), with minimal heterogeneity (I^2^=5.4%). We detected no evidence of publication bias based on Egger’s test and a visual inspection of Begg’s funnel plot. Two intervention arms of a trial intended to improve balance (Tai Chi or platform training) were combined in our meta-analysis.107 Results were unchanged when the more intense of the two arms was included. A parallel analysis was conducted on the subset of trials that reported fall rate, which resulted in a very similar pattern of results (RR, 0.76 [95% CI, 0.67 to 0.89]) (I^2^=55.4%).

Three of the trials had intervention arms that included exercise plus another intervention type.61,63,112 One trial included an intervention arm that evaluated exercise plus home hazard modification in addition to an exercise-only arm.63 One trial included an intervention arm that evaluated exercise plus treatment of visual impairment and an intervention arm that evaluated exercise plus home hazard modification in addition to an exercise-only arm.61 A third trial evaluated exercise (exercise alone and exercise plus medication withdrawal), comparing these groups to a group that did not receive exercise (a medication withdrawal group plus the control group). We conducted an additional meta-analysis including these combination intervention arms and the results were similar, although the statistical heterogeneity was slightly greater (I^2^=12.4%).

Meta-regression identified no study-level variables that explained significant within-study variability. Visual analyses examining pattern of results by intervention intensity, number of intervention components, type of intervention (group vs. not), and risk status of participants (selected vs. unselected and percentage fallers in previous year) confirmed that there was no pattern in intervention effectiveness by these variables. Differences in results, however, were observed when the observed fall risk among the control group after randomization (>35% vs. <35%) was used as a measure of risk status. This stratification roughly represents the groups above and below the average fall risk for people aged 65 years or older. Meta-analyses stratified by fall risk in the control group support the qualitative observation. The pooled risk from 10 trials with more than 35% of the control group falling during the intervention was similar to the overall results (RR, 0.84 [95% CI, 0.78 to 0.91]) (I^2^=1.1%) (Figure 10). However, the pooled relative risk among the five trials with 35% or less of the control group falling was not significant (0.98 [95% CI, 0.82 to 1.62]) (I^2^=0%) (Figure 9).

Study design and quality. One trial was rated good quality,115 while the remaining trails were rated fair quality (see Appendix B Table 3 for quality criteria). It is not possible to blind participants to their group assignment in physical activity trials, and most of the trials did not report whether those collecting followup assessments of falls were blinded to intervention status. The majority of the interventions did not provide an attention control to address a possible Hawthorne effect.117 Many studies reported retention of 80% or more, although retention in five trials was below 80%.93,108,112,113,116 Three studies appeared to have differential attrition,97,100,105 but these differences were not tested statistically. All of the studies relied on self-reported falls. Participants in most trials were provided with a calendar or diary to record falls and queried at least monthly by study staff to report falls over the past month throughout the study period; five trials assessed falls retrospectively with periods of recall ranging from 2 weeks100 to 3 months.94 Trials conducted in unselected older adults tended to limit the population to healthier older adults, resulting in a large percentage of screened older adults not randomized for the intervention.95,107,116 Similarly, the high-risk populations are also very unique (e.g., stroke patients94 or extremely frail105 or recently hospitalized).113 As such, results may not generalize to other selected populations, such as those selected based on history of falls.

### Home Hazard Modification

Summary of findings. Three fair-quality trials (n=2,348) in community-dwelling adults aged 76–84 years on average assessed the influence of home hazard assessment and modification on risk for falling. All three trials were consistent with a reduced risk, ranging from 7% to 41%, when comparing the intervention group with the control group. This risk reduction, however, was only statistically significant in one study (n=196) conducted among high-risk older adults.63 In a meta-analysis, the pooled relative risk was 0.81 (95% CI, 0.63 to 1.04), with significant heterogeneity (I^2^=70.4%) (Figure 11). An additional five multifactorial assessment and management trials included home hazard assessment and modification as a component of the overall intervention.71,75–77,84 Adding these trials to the meta-analysis attenuated the risk reduction and did not change the significance (RR, 0.90 [95% CI, 0.77 to 1.06]) (I^2^=54.5%). As these three trials have been discussed previously, they will not be discussed further in this category.

Figure 11 Pooled Risk for Falling in Home Hazard Modification Interventions (KQ 2)

Figure 11 displays a forest plot of all home hazard modification trials reporting between-group differences in risk for falling. Data for the figure are presented alongside the forest plot. The pooled relative risk for falling was 0.81 (95% CI, 0.63 to 1.04), with high statistical heterogeneity (chi-square=70.4%).

Study details. Three studies (n=2,718) randomized community-dwelling older adults to home hazard modification interventions (Table 12). All participants were aged 70 years or older. Trials primarily included women, with the proportion of women ranging from 52% to 70%. No trials reported race/ethnicity or socioeconomic status of the included participants. One study was restricted to a high-risk population, defined as people with visual impairment.63

Table 12 Study Characteristics of Home Hazard Modification Interventions to Prevent Falls (KQ 2)

For more details of each study see Appendix C Table 4

Study reference, Setting, USPSTF quality rating | N patients randomized, Age | Intervention and control description, Length of followup | Risk category, % high risk | # (%) fallers # (%) frequent fallers | High risk status | Adverse effects
Campbell 2005^63^ New Zealand Fair (study also located in Exercise/PT) | Randomized: 391 (3 IGs) IG: 100 CG: 96 Mean age (SD): IG: 83.1 (4.5) CG: 84.0 (4.9) | Intervention: Home safety assessment and modification Control: Social visits Followup: 1 year | Risk category: Eye disease, visual impairment Proportion: 100% | # (%) fallers: IG: 36 (36) CG: 59 (61) # (%) frequent fallers (2+ falls): IG: 16 (16) CG: 29 (30) | All are high risk | NR
Day 2002^61^ Australia Fair (study also located in Clinical Mgmt, Exercise/PT) | Randomized: 1,107 Continued: 1,090 (7 IGs) IG: 136 CG: 137 Mean age (SD): All: 76.1 (5.0) | Intervention: Home hazards removed or modified Control: Waitlist control Followup: 1 year | Risk category: NR Proportion: NA | # (%) fallers: IG: 78 (57.4) CG: 87 (63.5) # (%) frequent fallers (2+ falls): NR | NA | NR
Stevens 2001^70^ Australia Fair | Randomized: 1,879 IG: 635 CG: 1,244 Mean age: IG: 76 CG: 76 | Intervention: Home hazard assessment, education, and installation of safety devices Control: Home visits Followup: 1 year | Risk category: NR Proportion: NA | # (%) fallers: NR Only reported Adjusted OR: 0.97 (0.74 to 1.28) # (%) frequent fallers (2+ falls): NR Reported OR for fall rate: 1.02 (0.83 to 1.27) | NA | NR

N – number; # – number; % – percent; USPSTF – U.S. Preventive Services Task Force; IG – intervention group; CG – control group; SD – standard deviation; NR – not reported; NA – not applicable

Trial characteristics are listed in Table 12. All three trials evaluated an assessment of the home and modification of any identified hazards (e.g., adding nonslip tape to rugs and steps) and/or provision of free safety devices (e.g., grab bars). Two interventions also provided intervention participants with behavioral counseling.63,70 Occupational therapists conducted the assessment and oversaw modifications in only one trial,63 and the remaining two trials used trained assessors/research nurses. We evaluated a total of six treatment arms. In addition to evaluating home hazard modification separately, two of the trials evaluated home hazard assessment in combination with physical activity61,63 or vision assessment and correction.61 Two trials provided the control participants with social visits,63,70 while the third provided nothing to the control group.61

Only one home-hazard modification trial (n=196) conducted in New Zealand reported a significant beneficial effect on risk for falling compared with controls.63 Modification of home hazards and behavioral counseling among vision-impaired adults with an average age of 84 years was associated with a significant reduction in the percentage that fell at least once during the 12-month intervention (36% vs. 61% [p<0.05]).63 Notably, the process of assessment and modification was guided by the Canadian Model of Occupational Performance and conducted by occupational therapists, whereas the assessment was conducted by research nurses in the remaining two trials and modification was conducted by participants themselves and the same nurses70 or by a city maintenance worker.61 The other two home-hazard modification trials that did not demonstrate significant results were conducted in Australia among unselected adults with an average age of 76 years.

Two of these trials also evaluated intervention arms that combined home hazard modification with exercise61,63 or vision correction.61 The results from the combination arms were generally similar to the results in the home hazard modification only arm. When these combination intervention arms were added to the home hazard modification only arms, the results of the meta-analysis were unchanged.

Study quality. The three studies were rated as fair quality. Falls were recorded prospectively in all three studies. Only one study reported blinded assessment of outcomes.61 All three studies reported attrition less than 10%, although attrition was differential in one study.70 Compliance with the intervention ranged from 83%^70^ to 90%.63 One study also reported crossover, such that 16% of the control group also made home safety modifications.70 Two of these studies were conducted before 2005,^61,70^ and all were conducted outside of the United States. One of the studies conducted in an unselected population was restricted to healthier older adults.61

### Clinical Education and Behavioral Counseling

Summary of findings. Only one good-quality trial (n=310) evaluated the influence of an intervention that was primarily educational.103 This study reported no evidence of a reduced risk for falling associated with behavioral counseling. We conducted a meta-analysis including all twelve trials providing minimal education or counseling in conjunction with other interventions.62,69–71,75,77,78,80,83,101,103,112 One of these trials included two intervention arms (exercise and medication assessment/withdrawal) and shared a single control group.112 To address the lack of independence, two meta-analyses were conducted: the first with the physical activity arm and the second with the medication assessment/withdrawal arm. The pooled estimates from these meta-analyses were consistent with reduced risk for falling, but were not informative because of high statistical heterogeneity (I^2^=84.0% and 80.1%, respectively). These additional nine studies have been described previously and thus are not discussed further in this section.

Study details. A multifaceted community-based learning program was conducted among adults selected to be higher risk for falling (Table 13). The majority of participants were female (74%) and 65% had fallen at least once during the previous year. Those who had not fallen during the past year but were afraid of falling were also included. The average age of participants was 78 years; race/ethnicity and socioeconomic status were not reported. The intervention group received seven weekly group sessions of 2 hours duration and a single booster session held 3 months after the final group session. All sessions were conducted by an occupational therapist. The control group received two social visits conducted by an occupational therapist. Among the intervention group, 52% fell during the 14-month followup, compared with 58% among the control group. This difference was not statistically significant.

Table 13 Study Characteristics of Clinical Education/Behavioral Counseling Interventions to Prevent Falls (KQ 2)

For more details of each study see Appendix C Table 4

Study reference, Setting, USPSTF quality rating | N patients randomized, Age | Intervention and control description, Length of followup | Risk category, % high risk | # (%) fallers, # (%) frequent fallers | High risk status | Adverse effects
Clemson 2004^103^ United Kingdom Good | Randomized: 310 IG: 157 CG: 153 Mean age (SD): IG: 78.31 (5.26) CG: 78.47 (5.66) | Intervention: Community-based falls education and a home visit Control: Social visits Followup: 14 months | Risk category: Other (fall history or concern about falling) Proportion: 100% | # (%) fallers: IG: 82 (52) CG: 89 (58) # (%) frequent fallers (2+ falls): IG: 40 (26) CG: 53 (35) | All are high risk | NR

N – number; # – number; % – percent; USPSTF – U.S. Preventive Services Task Force; IG – intervention group; CG – control group; SD – standard deviation; NR – not reported

Attrition was low (<10%). Falls were reported monthly using diaries; 90% of intervention participants attended at least five educational sessions. Homebound individuals and those with cognitive problems were excluded.

## KQ 1a Do These Interventions Reduce Injury, Improve Quality of Life, Reduce Disability, or Reduce Mortality in Older Adults Specifically Identified as High Risk for Falls?

## KQ 2a Do These Interventions Reduce Falls in Older Adults Specifically Identified as High Risk for Falls?

A variety of methods were used to select higher-risk populations in the interventions included in this review (Table 14). The evidence for improved health outcomes other than falling among high-risk populations was insufficient to evaluate, and thus is not further discussed. Meta-regression analyses were conducted to evaluate the association between study characteristics related to risk status and estimates of the effect of the intervention on risk for falling. Risk status characteristics included in meta-regressions included history of a fall at baseline (percent), average age (≥80 years vs. <80 years), percent female subjects, high-risk selection (history of falls, gait and balance limitations, other, none), and fall risk in the control group during followup. When possible, we conducted the meta-regression by type of intervention.

Table 14 Selection of High-Risk Populations for Interventions to Prevent Falls

Study | Fall history | | | | | | | | | Disease history | | | Gait/balance impairment | Mobility limitation | Environmental falls hazards | 1+ hip fracture risk factors | Medication | | Visual impairment | | | Age, yrs | | | Female (all female) | Frail | Vitamin D deficient | Recent hospital admit, bed rest >2 days in last month | Involuntary weight loss | Other | Notes
Study | ED visit, fall 1° diagnosis | ≥ 1 last year | Reported concern about falling | ≥ 1 last 8 wks | ≥ 2 last 6 mos | ≥ 2, or 1 requiring hospital admit, in last year | ≥ 1 last 6 mos | ≥ 2 in last year | ≥ 1 last 3 mos | Parkinson’s Disease | Postural hypertension | Stroke in last year | Gait/balance impairment | Mobility limitation | Environmental falls hazards | 1+ hip fracture risk factors | ≥ 4 meds | Current psychotropics | Distance visual acuity | Poor vision | Cataract | 70+ | 75+ | 80+ | Female (all female) | Frail | Vitamin D deficient | Recent hospital admit, bed rest >2 days in last month | Involuntary weight loss | Other | Notes
Ashburn 2007^96^ | | | | | | | | | | X
Barnett 2003^104^ | | | | | | | | | | | | | X | | | | | | | | | | | | | | | | | | Gait/balance impairment: lower limb weakness, poor balance, or slow reaction time (inability to stand from a chair in <2 sec; inability to maintain balance in near-tandem balance test; or inability to catch a rod dropped from above in 300 msec).
Birks 2004^85^ | | | | | | | | | | | | | | | | X | | | | | | X | | | X | | | | | | Hip fracture risk factors: low body weight, smoking, prior fracture, family history of hip fracture.
Buchner 1997^105^, 1993^106^ | | | | | | | | | | | | | X | | | | | | | | | | | | | | | | | | Mobility limitation: unable to do 8-step tandem gait w/out errors, <50th percentile in knee extensor strength for age, sex, height, or weight.
Cameron 2003^66^ | | | | | | X | | | | | | | | | | | | | | | | X | | | X
Campbell 1997^97^ | | | | | | | | | | | | | | | | | | | | | | | | X | X
Campbell 1999^112^ | | | | | | | | | | | | | | | | | | X
Campbell 2005^63^ | | | | | | | | | | | | | | | | | | | X | | | | X
Clemson 2004^103^ | | X | X | | | | | | | | | | | | | | | | | | | X | | | | | | | | | Either checked factor considered.
Close 1999^80^ | X
Cumming 2007^90^ | | | | | | | | | | | | | | | | | | | | | | X | | | | X
Day 2002^61^ | | | | | | | | | | | | | | | | | | | | | | X
Dhesi 2004^102^ | | | | X | | | | | | | | | | | | | | | | | | | | | | | X | | | | Required both recent fall AND vitamin D deficient (25-hydroxyvitamin D ≤12μg/l).
Dukas 2004^92^ | | | | | | | | | | | | | | | | | | | | | | X
Elley 2008^79^ | | X | | | | | | | | | | | | | | | | | | | | | X
Foss 2006^91^ | | | | | | | | | | | | | | | | | | | | | X | X | | | X
Gray-Donald 1995^88^ | | | | | | | | | | | | | | | | | | | | | | | | | | | | | X | | Involuntary loss >5% of weight in last month, >7.5% last 3 months, or >10% last 6 months + BMI <27; or BMI <24.
Green 2002^94^ | | | | | | | | | | | | X
Harwood 2005^87^ | | | | | | | | | | | | | | | | | | | | | X | X | | | X
Hendriks 2008^84^ | X
Hogan 2001^82^ | | | | | | | | | X
Li 2005^116^ | | | | | | | | | | | | | | | | | | | | | | X
Lightbody 2002^77^ | X
Lord 2005^62^ | | | | | | | | | | | | | X | | | | | | | | | | X | | | | | | | | Gait/balance impairment: physiological profile assessment falls risk scores < −1.
Luukinen 2007^93^ | | | | | | | | X | | | | | X | | | | | | | X | | | | X | | | | | | X | Any checked factors considered. Gait/balance impairment: impaired balance or chair rise or slow walking speed; Other: loneliness, depression, or poor self-rated health, hearing, or cognition.
Morgan 2004^113^ | | | | | | | | | | | | | | | | | | | | | | | | | | | | X
Newbury 2001^81^ | | | | | | | | | | | | | | | | | | | | | | | X
Pfeifer 2000^98^ | | | | | | | | | | | | | | | | | | | | | | X | | | X | | X | | | | 25-hydroxycholecalciferol < 50 nmol/liter.
Porthouse 2005^67^ | | | | | | | | | | | | | | | | | | | | | | X
Prince 2008^89^ | | X | | | | | | | | | | | | | | | | | | | | X | | | X | | X | | | | 25-hydroxyvitamin D concentration <24.0 ng/mL.
Robertson 2001^95^ | | | | | | | | | | | | | | | | | | | | | | | X
Rubenstein 2000^100^ | | | | | | | X | | | | | | X | | | | | | | | | | | | | | | | | | Any checked risk factors considered. Gait/balance impairment: lower extremity weakness, impaired gait, or impaired balance.
Stevens 2001^70^ | | | | | | | | | | | | | | | | | | | | | | X
Tinetti 1994^69^ Buchner 1993^110^ | | | | | | | | | | | X | | X | X | X | | X | X | | | | X | | | | | | | | | Any checked risk factors considered. Mobility limitation: unsafe toilet or tub transfer, impaired leg/arm muscle strength, or impaired range of motion.
van Haastregt 2000^71^ | | | | | X | | | | | | | | | X | | | | | | | | X | | | | | | | | | Mobility limitation: score of 3+ on mobility control scale (short version of Sickness Impact Profile).
Wolf 1996^107^ | | | | | | | | | | | | | | | | | | | | | | X

In meta-regression analyses with all included studies, none of the risk status characteristics explained a significant amount of the intervention effect. Evidence related to risk for falling within each intervention category is described below.

### Multifactorial Assessment and Management

There was sufficient variability to evaluate the influence of age, history of falls, and high-risk selection on the effect of multifactorial assessment and management programs on fall risk via meta-regression. None of these risk characteristics could explain the significant between-study variability in effect sizes.

Twelve of the 14 trials were conducted in populations selected for falls risk. One trial, conducted entirely among women, reported no significant reduction of fall risk overall. Post-hoc analyses were restricted to those participants with more than two falls during the 3 months prior to the study, and this subgroup analysis supported a significant difference between the intervention and control groups (p=0.046).82 Another study that conducted a similar post-hoc analysis reported no differences in fall risk between the intervention and control groups by history of one or more falls during the past 3 months at baseline.83 A third study also found no significant difference in post-hoc analyses on fall outcomes among participants at higher fall risk: people with history of two or more falls during the previous year, people with mobility impairments, and people with limitations in activities of daily living.84

### Single Clinical Treatment

Two of the Vitamin D trials in unselected populations conducted post-hoc analyses to evaluate fall outcomes separately for high-risk populations: people with low dietary calcium intake or low serum 25-hydroxyvitamin D levels92,111 and women.111 The effect of vitamin D alone on risk for falling was larger among participants with less than 512 mg/d calcium intake.92 The study’s authors, however, do not provide the statistical significance of the interaction term. In the second study, fall reduction was not enhanced among individuals with low serum 25-hydroxyvitamin D levels (p=0.71) or in women (p=0.25).111

One of the four vision-correction trials conducted a subgroup analysis of those with a history of falls during the past year at baseline and found no significant differences in effect.90

### Exercise and Physical Therapy

Ten of the 17 trials were conducted in populations selected to be high risk; none identified a high-risk population based solely on history of falls. There was sufficient variability to evaluate the influence of age, history of falls, and high-risk selection (selected vs. unselected) on the effect of exercise and physical therapy programs on fall risk through meta-regression. None of these risk characteristics explained a significant amount of between-study variability in effect sizes.

Differences in results, however, were found when the observed fall risk among the control group after randomization (>35% vs. <35%) was used as a measure of risk status. This stratification roughly represents the groups above and below the average fall risk among older adults. Meta-analyses stratified by fall risk in the control group support the qualitative observation. The pooled risk from 10 studies conducted among high-risk populations was 0.84 (95% CI, 0.78 to 0.91) (I^2^=1.1%), while the pooled relative risk was no longer significant (RR, 0.98 [95% CI, 0.82 to 1.17]) (I^2^=0%) among the five studies conducted in a low-risk population (Figure 9).

None of the physical-activity trials conducted post-hoc subgroup analyses to evaluate the influence of high-risk characteristics.

### Home Hazard Modification

The only home-hazard modification trial conducted among a selected population—older adults aged 75 years or older with reduced distance visual acuity—reported a significant reduction in fall risk. None of the trials with unselected populations conducted subgroup analyses to evaluate specific risk factors.

### Clinical Education/Behavioral Counseling

The single trial solely evaluating a clinical education/behavioral counseling intervention was conducted in a high-risk population and did not evaluate subgroups.

## KQ 2b Are There Positive Outcomes Other Than Reduced Falls and Related Morbidity and Mortality That Result From Primary Care Falls Interventions?

The main outcomes assessed by included trials were fear of falling or falls efficacy67,69,71,76,80,85,87,91,103,114,116,118 and balance, gait, and mobility measures.75,83,94,96,114,116,118 Additional positive outcomes assessed in trials, but not reported as part of this report, are described in Appendix H Table 2.

### Multifactorial Assessment and Management

Five trials evaluated other positive outcomes, including falls efficacy69,71,76 and neuromuscular performance measures.75,83 Three multifactorial assessment and management trials (n=930) reported a significant difference in 12-month change in fear of falling using the falls efficacy scale favoring the intervention group.69,71 The differences in the mean change score ranged from 1.4 to 7.5 and were consistent with a decline in falls efficacy in the control group, compared with no change in the intervention group. One moderate-intensity trial (n=453) reported significantly different 12-month improvements in the timed Get Up and Go test and the Berg balance scale in intervention participants compared with controls.83 This trial provided all intervention group participants with a referral to a physical activity intervention. Another trial reported a significantly greater percentage of intervention participants who completed the timed Get Up and Go test in less than 30 seconds (82%) compared with the control group (72%).75

### Single Clinical Treatment

One vitamin D trial reported a significant decrease in time to complete the timed Get Up and Go test in the intervention group compared with the control group (p<0.001).99

Two vision correction trials (n=545) reported a significant difference in 6-month change in falls efficacy favoring the intervention group.87,91 The differences in the mean change score were consistent with reduced falls efficacy in the control group, accompanied by stable or slightly increased falls efficacy in the intervention group (differences ranged from 3.6 to 5.4).

One of the two trials of hip protectors evaluated differences in fear of falling between the intervention and control groups at 12 months and reported significantly less fear of falling in the intervention group (p=0.003).85

### Exercise and Physical Therapy

Four trials (n=1,000) evaluated other positive outcomes, including the timed Get Up and Go test,96 functional reach,96,116 Berg balance scale,96,104,114,116 timed walk,94,104 and falls efficacy.114,116 One study reported significantly better falls efficacy, functional reach, and balance in the intervention group compared with the control groups at 12 months (p<0.05). All the measures were balanced at baseline.116 Only one other trial reported significantly different mean change in functional reach after 6 months (adjusted difference in change, 5.7 [95% CI, 0.47 to 11.0]), although no differences were found in the timed Get Up and Go test or the Berg balance score.96 The remaining studies reported no significantly different changes in these positive outcomes.

### Home Hazard Modification

None of the studies evaluated other positive outcomes.

### Clinical Education/Behavioral Counseling

The community-based group behavioral counseling intervention was not associated with a significantly greater improvement in falls efficacy when comparing the intervention group with the control group over the 14-month followup (mean difference, 1.74 [95% CI, −6.1 to 2.7]).

## KQ 3 What Are the Adverse Effects Associated With Interventions to Reduce Falls?

In addition to reviewing the trials included in KQs 1 and 2, we conducted additional searches for evidence addressing significant clinical harms (i.e., intervention-related events requiring medical services) for each intervention type. Due to both practical limitations and the availability of recent AHRQ-funded evidence reports, we did not systematically review the evidence of harms of vitamin D supplementation, vision screening, or early vision correction in older adults. These topics are briefly addressed in the Discussion section. For KQ 3, we included harms reported in 44 trials from KQs 1 and 2 (Appendix C Tables 1–5), two additional trials on exercise interventions,119 and one systematic review on protein and energy supplementation in older adults120(Appendix D Tables 1 and 2). We found no observational studies examining clinically significant harms of fall prevention interventions.

Summary of findings. Based on the meta-analyses conducted for KQ 2, there was limited evidence of paradoxical effects of the falls prevention interventions resulting in an increased number of fallers, fall-related fractures, or increased rate of falls. A few physical activity interventions94,100,114 and multifactorial assessment and management interventions62,71,75,79 reported increased falls in the intervention group, but only one of these was statistically significant.79 In addition, there does not appear to be an increase in all-cause mortality or disability or decrease in self-reported quality of life with falls prevention interventions (Figure 2). We found no evidence to suggest serious harms of hip protectors, medication withdrawal, liquid protein-energy supplementation, vitamin D supplementation, clinical education and counseling, home hazard modification, or exercise and physical therapy interventions. In one trial (n=312) conducted in New Zealand, a group randomized to receive a nurse-conducted multifactorial clinical assessment plus referral intervention had more fallers than the control group.79 Based on one fair-quality trial (n=616) in Australia, vision assessment and correction in frail older adults may have increased fallers.90 Overall, trials were primarily designed to evaluate the intervention’s efficacy or effectiveness, and therefore did not report adverse outcomes other than falls outcomes.

Minor adverse outcomes associated with specific interventions include: increased fall-related outpatient visits after comprehensive falls assessment, self-reported musculoskeletal complaints (but not outpatient visits or hospitalizations) with exercise interventions, increased outpatient visits for abnormal heart rhythm with exercise intervention, minor local skin irritation or infection with use of hip protectors, gastrointestinal side effects with liquid protein-energy supplementation, and transient or asymptomatic hypercalcemia and hypercalciuria with vitamin D supplementation.

Study details. We found 12 fair- to good-quality trials (n=5,099) that evaluated the effectiveness of multifactorial assessment interventions.62,69,71,75,77–84 Overall, there was no evidence for clinically significant harms. One good-quality trial (n=312) in New Zealand evaluating a nurse-conducted multifactorial clinical assessment with referral had a slightly higher proportion of fallers and frequent fallers at 12 months (i.e., 2 or more falls) in the intervention group compared with the control group (68.4% vs. 62.4% [p=0.040] and 44.5% vs. 34.4% [p=0.067], respectively).79 Only three of the 12 trials explicitly reported on additional adverse effects.69,77,84 In one fair-quality trial (n=348) evaluating a nurse-conducted multifactorial assessment and referral in the United Kingdom, persons in the intervention group had more fall-related outpatient visits to their general practitioner than persons receiving usual care.77 In another fair-quality trial (n=301) evaluating a comprehensive multifactorial assessment with management, persons in the intervention group self-reported more musculoskeletal symptoms, which were probably related to the exercise program according to the study investigators. However, there was no increase in falls, hospitalizations, or deaths.69

There were 15 fair- to good-quality trials (n=12,133) evaluating different single clinical treatments. Two fair-quality trials (n=4,769) evaluated hip protectors in older community-dwelling adults.66,85 In these two trials, there was no statistically significant increase in falls or frequent fallers. In one trial, the investigators reported that 5% of persons in the intervention group had minor local complications, including skin irritation or infection due to wearing hip protectors.66 In one fair-quality trial (n=93) of persons receiving medication management and medication withdrawal to prevent falls, no adverse effects were reported.112

Four fair- and good-quality trials (n=1,437) included interventions to correct vision to prevent falls.61,87,90,91 In one fair-quality trial (n=616) in Australia, frail older adults received a comprehensive eye exam with subsequent treatment of vision problems. Approximately 44% of participants received some sort of vision-related intervention. Persons in the intervention group, compared with those in the control group, had a higher proportion of fallers (65.0% vs. 49.8% [p=0.0001]) and frequent fallers (37.9% vs. 30.6% [p=0.003]).90 There was also a nonsignificant trend in fall-related fractures. The trial investigators hypothesized that corrected vision may have increased the level of activity of these frail older adults, thereby increasing their risk for falls. In the two trials (n=545) evaluating expedited cataract surgery, complication rates from the cataract surgery were reported for the intervention group (cataract surgery at approximately 4 weeks) but not for the control group (surgery at approximately 12 months). Complications included iris damage, anterior vitrectomy performed, and posterior capsular opacification noted 6 months afterward. Harms for vision assessment and early treatment are addressed in the discussion.

Only one fair-quality trial (n=50) evaluated liquid protein and energy supplementation in frail older adults.88 This trial did not report any adverse effects. One good-quality systematic review designed to evaluate the effectiveness of oral protein and energy supplementation for older adults found 18 trials that reported adverse effects.120 Ten of the 18 trials found some problems with tolerance and gastrointestinal side effects (e.g., nausea, vomiting, and diarrhea). Most of these trials, however, were conducted in hospitals or nursing homes. Only two trials were conducted among community-dwelling adults: one trial in persons with diabetic foot ulcers and one trial in undernourished persons recently discharged from the hospital. Most of these trials did not report methods for assessing harms or for conducting comparisons with the control group.

Based on eight fair-quality trials (n=5,216) evaluating vitamin D supplementation for the prevention of falls in older adults, there is no evidence of an increase in falls or fallers or other significant clinical harms. Most of the trials, however, did not report adverse effects.67,89,92,98,99,102,111 Three trials (n=926) reported transient and asymptomatic hypercalciuria or hypercalcemia in the intervention group but no differences in side effects or significant harms, such as incident kidney stones, cancer, ischemic heart disease, or stroke.86,89,92 Harms of vitamin D supplementation are addressed in the Discussion section.

In one good-quality trial (n=310) evaluating primarily clinical education and behavioral counseling to prevent falls, there was no increase in falls or fallers. However, no additional adverse effects were reported.103

Based on the three fair-quality trials (n=2,348) that included home hazard modification interventions, there was no evidence of increased falls or fallers.61,63,70 None of these trials reported additional adverse events.

There is no evidence of an increase in falls or fallers due to exercising, based on 17 fair- to good-quality trials (n=3,985) examining exercise and physical therapy interventions to prevent falls61,63,93–97,100,104,105,107,108,112–116 plus two additional fair-quality trials (n=496) identified in our search for harms.119,121 Few of these trials report additional adverse effects. Two trials (n=312) reported one fall while exercising as instructed, although there was no increased number of fallers in the intervention group overall.95,119 One fair-quality trial (n=424) that explicitly evaluated adverse effects found that persons in the exercise group had more physician visits for abnormal heart rhythm compared with those in the control group (20.2% vs. 11.4% [p=0.016]), but not for other problems, including syncope, shortness of breath, or musculoskeletal complaints.121 There were also no statistically significant differences between the two groups for serious harms, including clinically significant abnormal laboratory or other diagnostic testing, hospitalization, or life-threatening event.

## KQ 4 How Are Community-Dwelling Older Adults Identified for Primary Care Interventions to Prevent Falls?

Summary of findings. The intervention studies that focused on higher-risk community-dwelling older adults considered different, noncomparable sets of self-reported or measured risk factors to identify those at risk for falling. These risk factor assessment approaches included from one to six different risk factors (some with multiple measures for a single risk factor, such as balance). Few studies used the same set of risk factors or used a formal battery (risk assessment tool). To complicate matters further, the measured risk factors (e.g., balance, gait speed, mobility) used several different measures across studies and many studies used measures that would not be feasible for use in routine primary care. Other reviewers have noted similar challenges in addressing the falls epidemiology and intervention literature.122

Study details. Most of the fall prevention interventions selected participants considered high risk for reasons in addition to age. Nine of the trials, however, defined high risk only as an age of 70 years or older,61,67,70,92,99 75 years or older,63,81,95 or 80 years or older97 (Table 14). Five trials78,83,108,111,115 were unselected for falls risk. Of the 32 interventions that selected participants based on risk factors for falls, seven trials 66,85,87,89,91,97,98 included only women, although female gender was not the only selection criteria.

Twelve of the 32 interventions that selected participants based on other risk factors for falls defined high risk according to fall history. A history of at least one fall in the last 2 to 12 months was required for participation in seven studies75,79,82,89,100,102,103 and a history of more serious falls (e.g., falls leading to hospitalization or urgent/emergency/specialty health care services, multiple falls) was required in another seven studies.66,71,76,77,80,84,93

Even within these studies, few used the same method to assess fall history. Several studies used fall history as one of several risk factors assessed to qualify participants for interventions.66,71,79,89,93,100,102,103,114 In two of these studies, people who had fallen during the past year represented less than half of the selected participants.71,93

Eight studies included participants at high risk as defined by measures of gait or balance impairment or mobility limitation.62,69,71,93,100,104,105,114 While some of these studies used similar measures to define gait, balance, or mobility impairment, none were precisely the same, and most would not be feasible in the primary care setting.