# Risk Categories and Other Outcome Measures

Appendix H Table 1 Profane Risk Categories: Chronic Diseases, Symptoms, Impairments

Category | Description
Osteoporosis/osteoporotic (bone fragility) fractures (A500) | Osteoporosis: Reduction of bone mass without alteration in the composition of bone, leading to fractures. Primary osteoporosis can be of two major types: postmenopausal osteoporosis (OSTEOPOROSIS, POSTMENOPAUSAL) and age-related or senile osteoporosis. [MeSH D010024] Osteoporosis, postmenopausal: Metabolic disorder associated with fractures of the femoral neck, vertebrae, and distal forearm. It occurs commonly in women within 15–20 years after menopause, and is caused by factors associated with menopause, including estrogen deficiency. [MeSH D015663]
Parkinson’s disease syndrome (A501) | Parkinson’s disease: A progressive, degenerative neurologic disease characterized by a TREMOR that is maximal at rest, retropulsion (i.e., a tendency to fall backwards), rigidity, stooped posture, slowness of voluntary movements, and a masklike facial expression. Pathologic features include loss of melanin containing neurons in the substantia nigra and other pigmented nuclei of the brainstem. LEWY BODIES are present in the substantia nigra and locus coeruleus but may also be found in a related condition (LEWY BODY DISEASE, DIFFUSE) characterized by dementia in combination with varying degrees of parkinsonism. (From Adams RD, Victor M, Ropper AH, eds. Principles of Neurology. 6th ed. New York: McGraw-Hill; 1997.) [MeSH D010300]
Cerebrovascular disorders (A502) | A broad category of disorders characterized by impairment of blood flow in the arteries and veins which supply the brain. These include CEREBRAL INFARCTION; BRAIN ISCHEMIA; HYPOXIA, BRAIN; INTRACRANIAL EMBOLISM AND THROMBOSIS; INTRACRANIAL ARTERIOVENOUS MALFORMATIONS; and VASCULITIS, CENTRAL NERVOUS SYSTEM. In common usage, the term cerebrovascular disorders is not limited to conditions that affect the cerebrum, but refers to vascular disorders of the entire brain, including the DIENCEPHALON; BRAIN STEM; and CEREBELLUM. [MeSH D002561]
Eye diseases, visual impairments (A503) | Eye diseases. [MeSH D005128] Vision disorders: Visual impairments limiting one or more of the basic functions of the eye: visual acuity, dark adaptation, color vision, or peripheral vision. These may result from EYE DISEASES; OPTIC NERVE DISEASES; VISUAL PATHWAY diseases; OCCIPITAL LOBE diseases; OCULAR MOTILITY DISORDERS; and other conditions. Visual disability refers to inability of the individual to perform specific visual tasks, such as reading, writing, orientation, or travelling unaided. (From Newell FW. Ophthalmology: Principles and Concepts. 7th ed. St. Louis: Mosby; 1992.) [MeSH D014786]
Dementia, cognitive impairment (A504) | Dementia, cognitive dementia: An acquired organic mental disorder with loss of intellectual abilities of sufficient severity to interfere with social or occupational functioning. The dysfunction is multifaceted and involves memory, behavior, personality, judgment, attention, spatial relations, language, abstract thought, and other executive functions. The intellectual decline is usually progressive, and initially spares the level of consciousness. [MeSH D003704] This category includes also less severe cognitive impairments affecting the ability to think, concentrate, formulate ideas, reason, and remember.
Depression symptoms (A505) | Depression: Depressive states usually of moderate intensity, in contrast with major depression present in neurotic and psychotic disorders. [MeSH D003863] Depressive disorder: An affective disorder manifested by either a dysphoric mood or loss of interest or pleasure in usual activities. The mood disturbance is prominent and relatively persistent. [MeSH D003866] Dysthymic disorder: Chronically depressed mood that occurs for most of the day, more days than not, for at least 2 years. The required minimum duration in children to make this diagnosis is 1 year. During periods of depressed mood, at least two of the following additional symptoms are present: poor appetite or overeating, insomnia or hypersomnia, low energy or fatigue, low self-esteem, poor concentration or difficulty making decisions, and feelings of hopelessness. [MeSH D019263]
Syncope (A506) | A transient loss of consciousness and postural tone caused by diminished blood flow to the brain (i.e., BRAIN ISCHEMIA). Presyncope refers to the sensation of lightheadedness and loss of strength that precedes a syncopal event or accompanies an incomplete syncope. (From Adams RD, Victor M, Ropper AH, eds. Principles of Neurology. 6th ed. New York: McGraw-Hill; 1997.) [MeSH D013575].
Gait and/or balance impairment (A507) | Gait is the way one locomotes or walks [MeSH D005684]. Examples include walking patterns and running patterns; impairments such as spastic gait, hemiplegic gait, paraplegic gait, asymmetric gait, limping. and stiff gait pattern. [ICF b770] Postural balance or musculoskeletal equilibrium: A state of the body being evenly balanced in POSTURE. The biomechanical responses of the MUSCULOSKELETAL SYSTEM during standing, walking, sitting, and other movements. [MeSH D004856] Balance impairments include impairments of sitting, static standing, or dynamic balance. In the context of falls, gait and balance impairments are often detected with timed or qualitative performance tests, such as the Get Up & Go test.
Urinary incontinence (A508) various | Involuntary loss of URINE, such as leaking of urine. It is a symptom of various underlying pathological processes. Major types of incontinence include URINARY URGE INCONTINENCE and URINARY STRESS INCONTINENCE. [MeSH D014549]
Screening tool (A509) | A fall screening tool is a short test intended to determine an older person’s risk for falling in order to determine eligibility for a fall risk intervention. It is not usually used to determine treatment received. Examples are the FRAT and AGS/BGS fall screening algorithms.
Others (A599/A599A) | Not described under A500–A509. A599A: Brief description (free text).
Medication specific (A600) | Individuals have been selected because they are taking specified classes of medication with a known association with fall risk (e.g., selective serotonin reuptake inhibitors, sedatives, or hypnotics) or as identified by the authors of the paper.

Appendix H Table 2 Other Positive Outcome Measures Audited From Studies Included for Key Questions 1 and 2

Category | Studies
Aerobic capacity | Buchner 1997^105^ Buchner 1993^106^
Blood pressure | Luukinen 2007^93^, Dukas 2004^92^, Wolf 1996^107^
Body mass index and skin fold caliper | Luukinen 2007^93^, Gray-Donald 1995^88^
Body sway | Voukelatos 2007^115^, Lord 1995^108^, Day 2002^61^, Barnett 2003^104^, Pfeifer 2000^98^
Bone measures | Pfeifer 2000^98^, Dukas 2004^92^
Chair stand/sit-to-stand | Rubenstein 2000^100^, Luukinen 2007^93^, Campbell 1997^97^, Barnett 2003^104^, Ashburn 2007^96^, Greenspan 2005, Dhesi 2004^102^, Shumway-Cook 2007^83^, Lord 2005^62^, Elley 2008^79^
Cognitive status | Luukinen 2007^93^, Van Haastregt 2000^71^, Newbury 2001^81^, Greenspan 2005
Dietary intake | Gray-Donald 1995^88^, Dukas 2004^92^, Dhesi 2004^102^
Falls Behavioral Scale | Clemson 2004^103^
Fear of falling | Hendriks 2008^84^
Hip protector adherence | Cameron 2003^66^
Hormonal measures | Pfeifer 2000^98^, Dukas 2004^92^, Dhesi 2004^102^
Medical visits | Hogan 2001^82^, Newbury 2001^81^, Lightbody 2002^77^
Mood | Clemson 2004^103^, Green 2002^94^, Foss 2006^91^, Van Haastregt 2000^71^, Newbury 2001^81^, Lightbody 2002^77^, Hendriks 2008^84^, Harwood 2005^87^
Muscle strength | Wolf 1996^107^, Luukinen 2007^93^, Lord 1995^108^, Day 2002^61^, Campbell 1997^97^, Buchner 1997^105^, Buchner 1993^106^, Barnett 2003^104^, Gray-Donald 1995^88^, Dukas 2004^92^, Dhesi 2004^102^, Green 2002^94^
Number of medications | Luukinen 2007^93^, Lightbody 2002^77^
One-leg balance and tandem leg balance | Rubenstein 2000^100^, Li 2005^116^, Greenspan 2005
Other activity scales | Rubenstein 2000^100^, Green 2002^94^, Clemson 2004^103^, Greenspan 2005, Hendriks 2008^84^, Elley 2008^79^, Van Haastregt 2000^71^
Other balance and stability measures | Voukelatos 2007^115^, Luukinen 2007^93^, Day 2002^61^, Campbell 1997^97^, Buchner 1997^105^, Buchner 1993^106^, Barnett 2003^104^, Greenspan 2005, Dukas 2004^92^, Dhesi 2004^102^, Elley 2008^79^, Lord 1995^108^
Other disability scales | Harwood 2005^87^
Other gait and mobility measures | Rubenstein 2000^100^, Li 2005^116^, Green 2002^94^, Buchner 1997^105^, Buchner 1993^106^, Voukelatos 2007^115^
Other general health questionnaires | Green 2002^94^, Gray-Donald 1995^88^, Buchner 1997^105^, Buchner 1993^106^, Van Haastregt 2000^71^, Newbury 2001^81^, Hendriks 2008^84^
Other timed walks | Wolf 1996^107^, Rubenstein 2000^100^, Luukinen 2007^93^, Li 2005^116^, Campbell 1997^97^, Greenspan 2005, Buchner 1997^105^, Buchner 1993^106^, Dhesi 2004^102^
Parkinson’s Disease Disability Scale | Ashburn 2007^96^
Reaction time | Lord 1995^108^, Barnett 2003^104^, Dhesi 2004^102^
Risk factor reassessment | Tinetti 1994^131^, Buchner 1993^106^
Visual acuity | Day 2002^61^, Harwood 2005^87^, Foss 2006^91^, Cumming 2007^90^

Appendix H Table 3 Other Fall-Related Injury Outcome Measures Audited From Studies Included for Key Questions 1 and 2

Category | Studies
Bruises, strains, cuts and abrasions, back pain, and fractures | Lord 20056^62^
Fracture, dislocation, sprains, strains, bruises, lacerations, scrapes, and others | Wolf 1996^107^
Fractures, dislocations, and soft tissue injuries needing suturing and even more severe injuries | Luukinen 2007^93^
Fractures, head injuries, sprains, bruises, scrapes, or other serious joint injuries, or fall resulting in medical care | Li 2005^116^
Incidence of other injury besides hip fracture | Cameron 2003^66^
Injuries requiring medical attention | Close 1999^80^, Elley 2008^79^, Hendriks 2008^84^, Hogan 2001^82^, Lightbody 2002^77^, Shumway-Cook 2007^83^
Injurious fall or fall resulting in medical care (no further detail) | Van Haastregt 2000^71^, Wagner 1994^78^, Stevens 2001^70^
Moderate injury (bruising, sprains, cuts, abrasions, seeking medical attention, or decrease in physical function for 3 days or more) | Elley 2008^79^
Serious injury (fracture or admission to hospital or wounds needing stitches) or Moderate injury (bruising, sprains, cuts, abrasions, or a reduction in physical function for 3 days or more) | Campbell 1997^97^
Serious injury (fracture or admission to hospital or wounds needing stitches) or Moderate injury (bruising, sprains, cuts, abrasions, or reduction in physical function for 3 days or more or if the participant sought medical help) | Robertson 2001^95^
Serious injury (fractures, head injuries, joint dislocations, severe sprains, lacerations requiring suturing) | Tinetti 1994^131^
Serious injury (no further detail) | Close 1999^80^, Rubenstein 2000^100^