# Trials

Appendix G Table 1 Pending and Ongoing Trials

Principal investigators | Location | Population | Approximate size | Investigations | Outcomes | Status as of 2009
KQ1: Interventions to prevent fall-related injury, improve quality of life, reduce disability, or reduce mortality when used to reduce falls
Susan E. Carter | Wales | Aged >70 years | NR | Brief intervention: Home hazard assessment and pamphlet on home safety and use of medications Intensive intervention: Same as above plus development of home hazard modification action plan with follow-up prompts and medication review Control group: no intervention | Falls and falls resulting in medical attention | Unknown
Tahir Masud | UK | Aged >70 years and at high risk for falling | NR | Intervention: Attend day hospital for assessment and subsequent multifactorial intervention to decrease rate of falls Control: Usual care | Rate of falling over 12 months Fall-related injuries, disability and mortality over 12 months | Analyzing data
N.M. Sjösten | Finland | Aged ≥65 years, ≥1 fall in past year, and moderate to high physical and cognitive abilities | n=591 | Multifactorial fall prevention intervention consisting of seven parts | Risk factors for falling, incidence of falls and injurious falls Health habits, physical function, psychosocial and cognitive function, social function | Baseline results published in 2007, results not yet published
KQ2: Interventions to reduce risk for or rate of falls
Susan E. Carter | Wales | Aged >70 years | NR | Brief intervention: Home hazard assessment and pamphlet on home safety and use of medications Intensive intervention: Same as above plus development of home hazard modification action plan with follow-up prompts and medication review Control group: No intervention | Falls and falls resulting in medical attention | Unknown
Kay Cerny | Long Beach, CA | Community-dwelling seniors | n=28 | Community-based group exercise program | Gait, balance, strength, and range of motion | Never published, data thrown out in early 2008
Carol E. Coogler | Atlanta, GA | Aged 65–99 years, from independent living communities | n=86 | Balance biofeedback training in fallers and nonfallers | Falls and postural control | Unknown
Catherine Dean | Australia | Community dwellers post stroke | Unknown | Exercise intervention, no further information | Falls | Trial under way, results not yet available
Stefanie Ferreri | Chapel Hill, NC | Aged ≥65 years and at high risk for falls | n=186 | Medication consultation, report recommendations to physician, implement any authorized changes | Time to first fall and number of fallers | Plan to submit for publication by May 2009
Maria A. Fiatarone | Boston | Mean age 82 years, 94% female | n=34 | Intervention: High-intensity resistance training program; 16 weeks, 3 days/week in home Control: Wait list | Falls, health care visits, bed days | Published abstract
Keith Hill | Australia | Stroke patients | Uknown | Multifactorial falls prevention program | Falls | Unknown
Tahir Masud | UK | Aged >70 years and at high risk for falling | NR | Intervention: Attend day hospital for assessment and subsequent multifactorial intervention to decrease rate of falls Control: Usual care | Rate of falling over 12 months Fall-related injuries, disability, and mortality over 12 months | Analyzing data
N.M. Sjösten | Finland | Aged ≥65 years, ≥1 fall in past year, and moderate to high physical and cognitive abilities | n=591 | Multifactorial fall prevention intervention consisting of seven parts | Risk factors for falling, incidence of falls and injurious falls Health habits, physical function, psychosocial and cognitive function, social function | Baseline results published in 2007, results not yet published
Martin J. Spink | Australia | Aged ≥65 years, with foot pain and at high risk for falling | n=300 | Footwear advice and provision, foot orthoses, home-based exercise program, and falls prevention education | Incidence and rate of falling | Results expected 2011
KQ3: Adverse effects of interventions to reduce falls
None
KQ4: Identification of high-risk older adults
None

Appendix G Table 2 Trials Included in the Cochrane Review

Study ID | Inclusion decision for USPSTF review
Ashburn 2007^1^ | Included in the review
Assantachai 2002^2^ | Out of scope at abstract review
Ballard 2004^3^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
Barnett 2003^4^ | Included in the review
Bischoff-Ferrari 2006^5^ | Included in the review
Brown 2002 & Brown 1999^6^ | Not reviewed (Brown 2002), reviewed bibliography of systematic evidence review (Brown 1999)
Buchner 1997a7 | Included in the review
Bunout 2005^8^ | Out of scope at abstract review
Campbell 1997^9^ | Included in the review
Campbell 1999^10^ | Included in the review
Campbell 2005^11^ | Included in the review
Carpenter 1990^12^ | Excluded for lack of focus on reducing risk for or rate of fallers
Carter 1997 | Unpublished data, not included
Carter 2002^13^ | Excluded for lack of focus on reducing risk for or rate of fallers
Cerny 1998^14^ | Excluded for not reporting desired outcomes
Clemson 2004^15^ | Included in the review
Close 1999^16^ | Included in the review
Coleman 1999^17^ | Included in the review
Cornillon 2002^18^ | Excluded for nonEnglish language
Cumming 1999^19^ | Excluded for being conducted in a population that is not comparable with primary care (e.g., persons in hospitals, nursing homes, rehabilitation centers, or other long-term care facilities)
Cumming 2007^20^ | Included in the review
Davison 2005^21^ | Included in the review
Day 2002^22^ | Included in the review
Dhesi 2004^23^ | Included in the review
Dukas 2004^24^ | Included in the review
Elley 2008^25^ | Included in the review
Fabacher 1994^26^ | Excluded for unblinded outcome assessment
Fiatrone 1997^27^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
Foss 2006^28^ | Included in the review
Gallagher 1996^29^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
Grant 2005^31^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
Gray-Donald 1995^32^ | Included in the review
Green 2002^33^ | Included in the review
Greenspan 2005^34^ | Excluded for comparative effectiveness study design
Harwood 2004^35^ | Out of scope at abstract review
Harwood 2005^36^ | Included in the review
Hauer 2001^37^ | Excluded for intervention not conducted in primary care or other setting with primary care-comparable population (hospital, nursing home, rehabilitation center, or other long-term care facility)
Helbostad 2004^38^ | Excluded for comparative effectiveness study design
Hendriks 2008^39^ | Out of scope at abstract review
Hill 2000 & Crome 2000^40^ | Primary paper used did not come up in our literature search (Hill 2000), other paper excluded for not reporting desired outcomes (Crome 2000)
Hogan 2001^41^ | Included in the review
Hornbrook 1994^42^ | Excluded for not reporting desired outcomes
Huang 2004^43^ | Out of scope at abstract review
Huang 2005^44^ | Out of scope at abstract review
Jitapunkul 1998^45^ | Excluded for intervention not conducted in primary care or other setting with primary care-comparable population (hospital, nursing home, rehabilitation center, or other long-term care facility)
Kenny 2001^46^ | Excluded for being conducted in a population that is not comparable with primary care (e.g., persons in hospitals, nursing homes, rehabilitation centers, or other long-term care facilities)
Kingston 2001^47^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
Korpelainen 2006^48^ | Out of scope at abstract review
Lannin 2007^49^ | Out of scope at abstract review
Latham 2003^50^ | Excluded for being conducted in a population that is not comparable with primary care (e.g., persons in hospitals, nursing homes, rehabilitation centers, or other long-term care facilities)
Li 2005^51^ | Included in the review
Lightbody 2005^52^ | Included in the review
Lin 2007^53^ | Excluded for study design (not a randomized controlled trial)
Liu-Ambrose 2004^54^ | Excluded for lack of focus on reducing risk for or rate of fallers
Lord 1995^55^ | Included in the review
Lord 2003^56^ | Excluded for intervention not conducted in primary care or other setting with primary care-comparable population (hospital, nursing home, rehabilitation center, or other long-term care facility)
Lord 2005^57^ | Included in the review
Luukinen 2007^58^ | Included in the review
Mahoney 2007^59^ | Excluded for comparative effectiveness study design
McKiernan 2005^60^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
McMurdo 1997^61^ | Excluded for being conducted in a population that is not comparable with primary care (e.g., persons in hospitals, nursing homes, rehabilitation centers, or other long-term care facilities)
Means 2005^62^ | Excluded for high or differential attrition
Meredith 2002 | Not reviewed
Morgan 2004^63^ | Included in the review
Newbury 2001^64^ | Included in the review
Nikolaus 2003^65^ | Excluded for being conducted in a population that is not comparable with primary care (e.g., persons in hospitals, nursing homes, rehabilitation centers, or other long-term care facilities)
Nitz 2004^66^ | Excluded for comparative effectiveness study design
Pardessus 2002^67^ | Excluded for being conducted in a population that is not comparable with primary care (e.g., persons in hospitals, nursing homes, rehabilitation centers, or other long-term care facilities)
Pereira 1998^68^ | Excluded for lack of focus on reducing risk for or rate of fallers
Pfeifer 2000^69^ | Included in the review
Pit 2007^70^ | Excluded for lack of focus on reducing risk for or rate of fallers
Porthouse 2005^71^ | Included in the review
Reinsch 1992^72^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
Resnick 2002^73^ | Excluded for intervention not conducted in primary care or other setting with primary care-comparable population (hospital, nursing home, rehabilitation center, or other long-term care facility)
Robertson 2001a74 | Included in the review
Robson 2003^75^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
Rubenstein 2000^76^ | Included in the review
Rubenstein 2007^77^ | Excluded for study design (not randomized controlled trial)
Ryan 1996^78^ | Excluded for poor reporting (missing information needed to evaluate quality, inconsistent data)
Salminen 2008 | Unpublished data
Sato 1999^79^ | Excluded for lack of focus on reducing risk for or rate of fallers
Schrijnemaekers 1995 | Not reviewed
Sherrington 2004^80^ | Out of scope at abstract review
Shigematsu 2008^81^ | Excluded for comparative effectiveness study design
Shumway-Cook 2007^82^ | Included in the review
Skelton 2005^83^ | Excluded for comparative effectiveness study design
Smith 2007^84^ | Excluded for lack of focus on reducing risk for or rate of fallers
Speechley 2008 | Unpublished data
Spice 2009^85^ | Included in the review
Steadman 2003^86^ | Out of scope at abstract review
Steinberg 2000^87^ | Excluded for comparative effectiveness study design
Stevens 2001^88^ | Included in the review
Suzuki 2004^89^ | Excluded for high or differential attrition
Swanenburg 2007^90^ | Excluded for comparative effectiveness study design
Tinetti 1994^91^ | Included in the review
Trivedi 2003^92^ | Excluded for outcome assessment (did not report cumulative falls)
Van Haastregt 2000^93^ | Included in the review
Van Rossum 1993^94^ | Excluded for lack of focus on reducing risk for or rate of fallers
Vellas 1991^95^ | Out of scope at abstract review
Vetter 1992^96^ | Excluded for high or differential attrition
Voukelatos 2007^97^ | Included in the review
Wagner 1994^98^ | Included in the review
Weerdesteyn 2006^99^ | Excluded for problems with baseline comparability between groups
Whitehead 2003^100^ | Out of scope at abstract
Wilder 2001 | Not reviewed
Wolf 1996^101^ | Included in the review
Wolf 2003^102^ | Excluded for intervention not conducted in primary care or other setting with primary care-comparable population (hospital, nursing home, rehabilitation center, or other long-term care facility)
Woo 2007^103^ | Excluded for lack of focus on reducing risk for or rate of fallers
Wyman 2005 & Wyman 2007^104^ | Not reviewed (Wyman 2005) and excluded for not reporting desired outcomes (Wyman 2007)

## References

1 Ashburn A, Fazakarley L, Ballinger C, Pickering R, McLellan LD, Fitton C. A randomised controlled trial of a home based exercise programme to reduce the risk of falling among people with Parkinson’s disease. Journal of Neurology, Neurosurgery & Psychiatry. 2007;78:678-684.
2 Assantachai P, Chatthanawaree W, Thamlikitkul V, Praditsuwan R, Pisalsarakij D. Strategy to prevent falls in the Thai elderly: a controlled study integrated health research program for the Thai elderly. Journal of the Medical Association of Thailand. 2002;85:215-222. [pmid: 12081122].
3 Ballard JE, McFarland C, Wallace LS, Holiday DB, Roberson G. The effect of 15 weeks of exercise on balance, leg strength, and reduction in falls in 40 women aged 65 to 89 years. Journal of the American Medical Womens Association. 2004;59:255-261.
4 Barnett A, Smith B, Lord SR, Williams M, Baumand A. Community-based group exercise improves balance and reduces falls in at-risk older people: a randomised controlled trial. Age & Ageing. 2003;32:407-414. [pmid: 12851185].
5 Bischoff-Ferrari HA, Orav EJ, wson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Archives of Internal Medicine. 2006;166:424-430. [pmid: 16505262].
6 Brown AP. Reducing falls in elderly people: a review of exercise interventions. Physiotherapy Theory and Practice. 1999;15:59-68.
7 Buchner DM, Cress ME, de Lateur BJ, et al. The effect of strength and endurance training on gait, balance, fall risk, and health services use in community-living older adults. J Gerontol A Biol Sci Med Sci. 1997;52:M218-M224. [pmid: 9224433].
8 Bunout D, Barrera G, Avendano M, et al. Results of a community-based weight-bearing resistance training programme for healthy Chilean elderly subjects. Age Ageing. 2005;34:80-83. [pmid: 15591487].
9 Campbell AJ, Robertson MC, Gardner MM, Norton RN, Tilyard MW, Buchner DM. Randomised controlled trial of a general practice programme of home based exercise to prevent falls in elderly women. BMJ. 1997;315:1065-1069. [pmid: 9366737].
10 Campbell AJ, Robertson MC, Gardner MM, Norton RN, Buchner DM. Psychotropic medication withdrawal and a home-based exercise program to prevent falls: a randomized, controlled trial. J Am Geriatr Soc. 1999;47:850-853. [pmid: 10404930].
11 Campbell AJ, Robertson MC, La Grow SJ, et al. Randomised controlled trial of prevention of falls in people aged > or =75 with severe visual impairment: the VIP trial. BMJ. 2005;331:817. [pmid: 16183652].
12 Carpenter GI, Demopoulos GR. Screening the elderly in the community: controlled trial of dependency surveillance using a questionnaire administered by volunteers. BMJ. 1990;300:1253-1256. [pmid: 2354297].
13 Carter ND, Khan KM, McKay HA, et al. Community-based exercise program reduces risk factors for falls in 65- to 75-year-old women with osteoporosis: randomized controlled trial.[see comment][erratum appears in CMAJ. 2003 Jan 21;168(2):152.]. CMAJ Canadian Medical Association Journal. 2002;167:997-1004.
14 Cerny K. The effect of a multidimensional exercise program on strength, range of motion, balance and gait in the well elderly. Gait & Posture. 1998;7:185-186.
15 Clemson L, Cumming RG, Kendig H, Swann M, Heard R, Taylor K. The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52:1487-1494. [pmid: 15341550].
16 Close J, Ellis M, Hooper R, Glucksman E, Jackson S, Swift C. Prevention of falls in the elderly trial (PROFET): a randomised controlled trial. Lancet. 1999;353:93-97. [pmid: 10023893].
17 Coleman EA, Grothaus LC, Sandhu N, Wagner EH. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. 1999;47:775-783. [pmid: 10404919].
18 Cornillon E, Blanchon MA, Ramboatsisetraina P, et al. [Effectiveness of falls prevention strategies for elderly subjects who live in the community with performance assessment of physical activities (before-after)]. Ann Readapt Med Phys. 2002;45:493-504. [pmid: 12495822].
19 Cumming RG, Thomas M, Szonyi G, et al. Home visits by an occupational therapist for assessment and modification of environmental hazards: A randomized trial of falls prevention. J Am Geriatr Soc. 1999;47:1397-1402. [pmid: 10591231].
20 Cumming RG, Ivers R, Clemson L, et al. Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55:175-181. [pmid: 17302652].
21 Davison J, Bond J, Dawson P, Steen IN, Kenny RA. Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention--a randomised controlled trial.[see comment]. Age & Ageing. 2005;34:162-168. [pmid: 15716246].
22 Day L, Fildes B, Gordon I, Fitzharris M, Flamer H, Lord S. Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325:128. [pmid: 12130606].
23 Dhesi JK, Jackson SH, Bearne LM, et al. Vitamin D supplementation improves neuromuscular function in older people who fall. Age & Ageing. 2004;33:589-595. [pmid: 15501836].
24 Dukas L, Bischoff HA, Lindpaintner LS, et al. Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc. 2004;52:230-236. [pmid: 14728632].
25 Elley CR, Robertson MC, Garrett S, et al. Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56:1383-1389. [pmid: 18808597].
26 Fabacher D, Josephson K, Pietruszka F, Linderborn K, Morley JE, Rubenstein LZ. An in-home preventive assessment program for independent older adults: a randomized controlled trial. J Am Geriatr Soc. 1994;42:630-638. [pmid: 8201149].
27 Fiatarone MA, ‘Neil EF, oyle R. Efficacy of home-based resistance training in frail elders [abstract]. The 16th Congress of the International Association of Gerontology, Book of Abstracts. Andrews GR, et al., editors. 1997.
28 Foss AJ, Harwood RH, Osborn F, Gregson RM, Zaman A, Masud T. Falls and health status in elderly women following second eye cataract surgery: a randomised controlled trial. Age & Ageing. 2006;35:66-71. [pmid: 16364936].
29 Gallagher EM, Brunt H. Head over heels: Impact of a health promotion program to reduce falls in the elderly. Canadian Journal on Aging. 1996;15:84-96.
30 Gallagher JC, Fowler SE, Detter JR, Sherman SS. Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 2001;86:3618-3628. [pmid: 11502787].
31 Grant AM, Avenell A, Campbell MK, et al. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial.[see comment]. Lancet. 2005;365:1621-1628. [pmid: 15885294].
32 Gray-Donald K, Payette H, Boutier V. Randomized clinical trial of nutritional supplementation shows little effect on functional status among free-living frail elderly. J Nutr. 1995;125:2965-2971. [pmid: 7500174].
33 Green J, Forster A, Bogle S, Young J. Physiotherapy for patients with mobility problems more than 1 year after stroke: a randomised controlled trial. Lancet. 2002;359:199-203. [pmid: 11812553].
34 Greenspan SL, Resnick NM, Parker RA. The effect of hormone replacement on physical performance in community-dwelling elderly women. American Journal of Medicine. 2005;118:1232-1239. [pmid: 16271907].
35 Harwood RH, Sahota O, Gaynor K, Masud T, Hosking DJ. The Nottingham Neck of Femur (NONOF) Study. A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age & Ageing. 2004;33:45-51. [pmid: 14695863].
36 Harwood RH, Foss AJ, Osborn F, Gregson RM, Zaman A, Masud T. Falls and health status in elderly women following first eye cataract surgery: a randomised controlled trial. British Journal of Ophthalmology. 2005;89:53-59. [pmid: 15615747].
37 Hauer K, Rost B, Rutschle K, et al. Exercise training for rehabilitation and secondary prevention of falls in geriatric patients with a history of injurious falls. J Am Geriatr Soc. 2001;49:10-20. [pmid: 11207837].
38 Helbostad JL, Sletvold O, Moe-Nilssen R. Effects of home exercises and group training on functional abilities in home-dwelling older persons with mobility and balance problems. A randomized study. Aging-Clinical & Experimental Research. 2004;16:113-121. [pmid: 15195985].
39 Hendriks MR, Evers SM, Bleijlevens MH, van-Haastregt JC, Crebolder HF, van-Eijk JT. Cost-effectiveness of a multidisciplinary fall prevention program in community-dwelling elderly people: a randomized controlled trial (ISRCTN 64716113). SO: International journal of technology assessment in health care. 2008;24:193-202.
40 Crome P. A randomised controlled trial of a nurse led falls prevention clinic [abstract]. J Am Geriatr Soc. 2000;48:S78.
41 Hogan DB, MacDonald FA, Betts J, et al. A randomized controlled trial of a community-based consultation service to prevent falls. CMAJ. 2001;165:537-543. [pmid: 11563205].
42 Hornbrook MC, Stevens VJ, Wingfield DJ, Hollis JF, Greenlick MR, Ory MG. Preventing falls among community-dwelling older persons: results from a randomized trial. Gerontologist. 1994;34:16-23. [pmid: 8150304].
43 Huang TT, Acton GJ. Effectiveness of home visit falls prevention strategy for Taiwanese community-dwelling elders: randomized trial. Public Health Nursing. 2004;21:247-256. [pmid: 15144369].
44 Huang TT, Liang SH. A randomized clinical trial of the effectiveness of a discharge planning intervention in hospitalized elders with hip fracture due to falling.[see comment]. Journal of Clinical Nursing. 2005;14:1193-1201. [pmid: 16238765].
45 Jitapunkul S. A randomised controlled trial of regular surveillance in Thai elderly using a simple questionnaire administered by non-professional personnel. J Med Assoc Thai. 1998;81:352-356. [pmid: 9623035].
46 Kenny RA, Richardson DA, Steen N, Bexton RS, Shaw FE, Bond J. Carotid sinus syndrome: a modifiable risk factor for nonaccidental falls in older adults (SAFE PACE). J Am Coll Cardiol. 2001;38:1491-1496. [pmid: 11691528].
47 Kingston P. Older people and falls: A randomized controlled trial of a health visitor (HV) intervention. Reviews in Clinical Gerontology. 2001;11:209-214.
48 Korpelainen R, Keinanen-Kiukaanniemi S, Heikkinen J, Vaananen K, Korpelainen J. Effect of impact exercise on bone mineral density in elderly women with low BMD: a population-based randomized controlled 30-month intervention. Osteoporosis International. 2006;17:109-118. [pmid: 15889312].
49 Lannin NA, Clemson L, McCluskey A, Lin CW, Cameron ID, Barras S. Feasibility and results of a randomised pilot-study of pre-discharge occupational therapy home visits. BMC Health Services Research. 2007;7:42. [pmid: 17355644].
50 Latham NK, Anderson CS, Lee A, Bennett DA, Moseley A, Cameron ID. A randomized, controlled trial of quadriceps resistance exercise and vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). J Am Geriatr Soc. 2003;51:291-299. [pmid: 12588571].
51 Li F, Harmer P, Fisher KJ, et al. Tai Chi and fall reductions in older adults: a randomized controlled trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005;60:187-194.
52 Lightbody E, Watkins C, Leathley M, Sharma A, Lye M. Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age & Ageing. 2002;31:203-210. [pmid: 12006310].
53 Lin MR, Wolf SL, Hwang HF, Gong SY, Chen CY. A randomized, controlled trial of fall prevention programs and quality of life in older fallers. J Am Geriatr Soc. 2007;55:499-506. [pmid: 17397426].
54 Liu-Ambrose T, Khan KM, Eng JJ, Janssen PA, Lord SR, McKay HA. Resistance and agility training reduce fall risk in women aged 75 to 85 with low bone mass: a 6-month randomized, controlled trial. J Am Geriatr Soc. 2004;52:657-665. [pmid: 15086643].
55 Lord SR, Ward JA, Williams P, Strudwick M. The effect of a 12-month exercise trial on balance, strength, and falls in older women: a randomized controlled trial. J Am Geriatr Soc. 1995;43:1198-1206. [pmid: 7594152].
56 Lord SR, Castell S, Corcoran J, et al. The effect of group exercise on physical functioning and falls in frail older people living in retirement villages: a randomized, controlled trial. J Am Geriatr Soc. 2003;51:1685-1692. [pmid: 14687345].
57 Lord SR, Tiedemann A, Chapman K, et al. The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53:1296-1304. [pmid: 16078954].
58 Luukinen H, Lehtola S, Jokelainen J, Vaananen-Sainio R, Lotvonen S, Koistinen P. Pragmatic exercise-oriented prevention of falls among the elderly: a population-based, randomized, controlled trial. Preventive Medicine. 2007;44:265-271. [pmid: 17174387].
59 Mahoney JE, Shea TA, Przybelski R, et al. Kenosha County falls prevention study: a randomized, controlled trial of an intermediate-intensity, community-based multifactorial falls intervention. J Am Geriatr Soc. 2007;55:489-498. [pmid: 17397425].
60 McKiernan FE. A simple gait-stabilizing device reduces outdoor falls and nonserious injurious falls in fall-prone older people during the winter. J Am Geriatr Soc. 2005;53:943-947. [pmid: 15935015].
61 McMurdo ME, ole PA, aterson CR. Controlled trial of weight bearing exercise in older women in relation to bone density and falls. BMJ. 1997;314:569. [pmid: 9055716].
62 Means KM, Rodell DE, O’Sullivan PS. Balance, mobility, and falls among community-dwelling elderly persons: effects of a rehabilitation exercise program. American Journal of Physical Medicine & Rehabilitation. 2005;84:238-250. [pmid: 15785256].
63 Morgan RO, Virnig BA, Duque M, Abdel ME, DeVito CA. Low-intensity exercise and reduction of the risk for falls among at-risk elders. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2004;59:1062-1067.
64 Newbury JW, Marley JE, Beilby JJ. A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 2001;175:104-107. [pmid: 11556409].
65 Nikolaus T, Bach M. Preventing falls in community-dwelling frail older people using a home intervention team (HIT): results from the randomized Falls-HIT trial. J Am Geriatr Soc. 2003;51:300-305. [pmid: 12588572].
66 Nitz JC, Choy NL. The efficacy of a specific balance-strategy training programme for preventing falls among older people: a pilot randomised controlled trial. Age & Ageing. 2004;33:52-58. [pmid: 14695864].
67 Pardessus V, Puisieux F, Di PC, Gaudefroy C, Thevenon A, Dewailly P. Benefits of home visits for falls and autonomy in the elderly: A randomized trial study. Am J Phys Med Rehabil. 2002;81:247-252. [pmid: 11953541].
68 Pereira MA, Kriska AM, Day RD, Cauley JA, LaPorte RE, Kuller LH. A randomized walking trial in postmenopausal women: effects on physical activity and health 10 years later. Arch Intern Med. 1998;158:1695-1701. [pmid: 9701104].
69 Pfeifer M, Begerow B, Minne HW, Abrams C, Nachtigall D, Hansen C. Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res. 2000;15:1113-1118. [pmid: 10841179].
70 Pit SW, Byles JE, Henry DA, Holt L, Hansen V, Bowman DA. A Quality Use of Medicines program for general practitioners and older people: a cluster randomised controlled trial. Medical Journal of Australia. 2007;187:23-30. [pmid: 17605699].
71 Porthouse J, Cockayne S, King C, et al. Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 2005;330:1003. [pmid: 15860827].
72 Reinsch S, MacRae P, Lachenbruch PA, Tobis JS. Attempts to prevent falls and injury: a prospective community study. Gerontologist. 1992;32:450-456. [pmid: 1427246].
73 Resnick B. Testing the effect of the WALC intervention on exercise adherence in older adults. Journal of Gerontological Nursing. 2002;28:40-49. [pmid: 12071273].
74 Robertson MC, Devlin N, Gardner MM, Campbell AJ. Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls. 1: Randomised controlled trial. BMJ. 2001;322:697-701. [pmid: 11264206].
75 Robson E, Edwards J, Gallagher E, Baker D. Steady as you go (SAYGO): a falls-prevention program for seniors living in the community. SO: Canadian Journal on Aging. 2003;22:207-216.
76 Rubenstein LZ, Josephson KR, Trueblood PR, et al. Effects of a group exercise program on strength, mobility, and falls among fall-prone elderly men. J Gerontol A Biol Sci Med Sci. 2000;55:M317-M321. [pmid: 10843351].
77 Rubenstein LZ, Alessi CA, Josephson KR, Trinidad HM, Harker JO, Pietruszka FM. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. 2007;55:166-174. [pmid: 17302651].
78 Ryan JW, Spellbring AM. Implementing strategies to decrease risk of falls in older women. J Gerontol Nurs. 1996;22:25-31. [pmid: 9060344].
79 Sato Y, Manabe S, Kuno H, Oizumi K. Amelioration of osteopenia and hypovitaminosis D by 1alpha-hydroxyvitamin D3 in elderly patients with Parkinson’s disease. J Neurol Neurosurg Psychiatry. 1999;66:64-68. [pmid: 9886454].
80 Sherrington C, Lord SR, Finch CF. Physical activity interventions to prevent falls among older people: update of the evidence. J Sci Med Sport. 2004;7:43-51. [pmid: 15214601].
81 Shigematsu R, Okura T, Nakagaichi M, et al. Square-stepping exercise and fall risk factors in older adults: a single-blind, randomized controlled trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2008;63:76-82.
82 Shumway-Cook A, Silver I, Mary L, York S, Cummings P, Koepsell T. Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. Journal of Gerontology. 2007;62:1420-1427.
83 Skelton D, Dinan S, Campbell M, Rutherford O. Tailored group exercise (Falls Management Exercise -- FaME) reduces falls in community-dwelling older frequent fallers (an RCT). Age & Ageing. 2005;34:636-639. [pmid: 16267192].
84 Smith H, Anderson F, Raphael H, Maslin P, Crozier S, Cooper C. Effect of annual intramuscular vitamin D on fracture risk in elderly men and women--a population-based, randomized, double-blind, placebo-controlled trial.[see comment]. Rheumatology. 2007;46:1852-1857. [pmid: 17998225].
85 Spice CL, Morotti W, George S, et al. The Winchester falls project: a randomised controlled trial of secondary prevention of falls in older people. Age & Ageing. 2009;38:33-40. [pmid: 18829689].
86 Steadman J, Donaldson N, Kalra L. A randomized controlled trial of an enhanced balance training program to improve mobility and reduce falls in elderly patients. J Am Geriatr Soc. 2003;51:847-852. [pmid: 12757574].
87 Steinberg M, Cartwright C, Peel N, Williams G. A sustainable programme to prevent falls and near falls in community dwelling older people: results of a randomised trial. J Epidemiol Community Health. 2000;54:227-232. [pmid: 10746118].
88 Stevens M, Holman CD, Bennett N, de Klerk N. Preventing falls in older people: outcome evaluation of a randomized controlled trial. J Am Geriatr Soc. 2001;49:1448-1455. [pmid: 11890582].
89 Suzuki T, Kim H, Yoshida H, Ishizaki T. Randomized controlled trial of exercise intervention for the prevention of falls in community-dwelling elderly Japanese women. Journal of Bone & Mineral Metabolism. 2004;22:602-611. [pmid: 15490272].
90 Swanenburg J, de-Bruin ED, Stauffacher M, Mulder T, Uebelhart D. Effects of exercise and nutrition on postural balance and risk of falling in elderly people with decreased bone mineral density: randomized controlled trial pilot study. SO: Clinical rehabilitation. 2007;21:523-534.
91 Tinetti ME, Baker DI, McAvay G, et al. A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331:821-827. [pmid: 8078528].
92 Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ. 2003;326:469. [pmid: 12609940].
93 van Haastregt JC, Diederiks JP, van Rossum E, de Witte LP, Voorhoeve PM, Crebolder HF. Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321:994-998. [pmid: 11039967].
94 van Rossum E, Frederiks CM, Philipsen H, Portengen K, Wiskerke J, Knipschild P. Effects of preventive home visits to elderly people. BMJ. 1993;307:27-32. [pmid: 8343668].
95 Vellas B, Albarede JL. A randomized clinical trial on the value of raubasine-dihytdroergocristine (Iskedyl™) in the prevention of post fall syndrome. Psychologie Medicale. 1991;23(7):831-839.
96 Vetter NJ, Lewis PA, Ford D. Can health visitors prevent fractures in elderly people?. BMJ. 1992;304:888-890. [pmid: 1392755].
97 Voukelatos A, Cumming RG, Lord SR, Rissel C. A randomized, controlled trial of tai chi for the prevention of falls: the Central Sydney tai chi trial. J Am Geriatr Soc. 2007;55:1185-1191. [pmid: 17661956].
98 Wagner EH, LaCroix AZ, Grothaus L, et al. Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84:1800-1806. [pmid: 7977921].
99 Weerdesteyn V, Rijken H, Geurts AC, Smits-Engelsman BC, Mulder T, Duysens J. A five-week exercise program can reduce falls and improve obstacle avoidance in the elderly. Gerontology. 2006;52:131-141. [pmid: 16645293].
100 Whitehead C, Wundke R, Crotty M, Finucane P. Evidence-based clinical practice in falls prevention: a randomised controlled trial of a falls prevention service. Aust Health Rev. 2003;26:88-97. [pmid: 15368824].
101 Wolf SL, Barnhart HX, Kutner NG, McNeely E, Coogler C, Xu T. Reducing frailty and falls in older persons: an investigation of Tai Chi and computerized balance training. Atlanta FICSIT Group. Frailty and Injuries: Cooperative Studies of Intervention Techniques. J Am Geriatr Soc. 1996;44:489-497. [pmid: 8617895].
102 Wolf SL, Sattin RW, Kutner M, O’Grady M, Greenspan AI, Gregor RJ. Intense tai chi exercise training and fall occurrences in older, transitionally frail adults: a randomized, controlled trial. J Am Geriatr Soc. 2003;51:1693-1701. [pmid: 14687346].
103 Woo J, Hong A, Lau E, Lynn H. A randomised controlled trial of Tai Chi and resistance exercise on bone health, muscle strength and balance in community-living elderly people. Age & Ageing. 2007;36:262-268. [pmid: 17356003].
104 Wyman JF, Croghan CF, Nachreiner NM, et al. Effectiveness of education and individualized counseling in reducing environmental hazards in the homes of community-dwelling older women. J Am Geriatr Soc. 2007;55:1548-1556. [pmid: 17908058].