# Meta-Analysis

Appendix F Table 1 Samples of Code Used in Conducting the Meta-Analysis

1. Calculation of log (relative risk) and related standard error (used in analyses of fallers and fractures)
SAS code:
*If raw data is available, use it to calculate log(RR) and SE of log(RR);
if n(n_fallers_ig, totn_ig_fallsanalyzed, n_fallers_cg, totn_cg_fallsanalyzed)=4 then do;
logrr_faller=log((n_fallers_ig /totn_ig_fallsanalyzed) /(n_fallers_cg /totn_cg_fallsanalyzed));
selogrr_faller=sqrt((1/n_fallers_ig)-(1/totn_ig_fallsanalyzed)+
(1/n_fallers_cg)-(1/totn_cg_fallsanalyzed));
end;
*if raw data is not available, use reported RR (or OR) and CI to calculate log(RR) and SE of log(RR);
else if rr_faller ne. then do;
logrr_faller=log(rr_faller);
logrr_faller_lci=log(rr_faller_lci);
logrr_faller_uci=log(rr_faller_uci);
selogrr_faller = (logrr_faller_uci - logrr_faller_lci)/1.96/2;
end;
*only using OR as a substitute for RR because we know the only observation where this is the case has an OR close to 1 (actual value=0.98). If the OR was not close to 1, we would not do this;
else if or_faller ne. then do;
logrr_faller=log(or_faller);
logrr_faller_lci=log(or_faller_lci);
logrr_faller_uci=log(or_faller_uci);
selogrr_faller = (logrr_faller_uci - logrr_faller_lci)/1.96/2;
end;
2. Adjustment for cluster randomization
SAS code:
if idpart1=“Hornbrook 1994” then do;
cluster_size = 3182/2509;
ifactor = 1 + (cluster_size −1) * 0.60;
selogrr_faller = selogrr_faller*sqrt(ifactor);
end;
if idpart1=“Tinetti 1994” then do;
cluster_size = 301/16;
ifactor = 1 + (cluster_size −1) * 0.05;
selogrr_faller = selogrr_faller*sqrt(ifactor);
end;
3. Meta-analysis and forest plot
Stata code:
meta logrr_faller selogrr_faller if iv_type==1, ///
eform graph(r) print cline xline(1) xlab(.25,.5,1,2) id(idcgfallers)
4. Test of publication bias
Stata code:
metabias logrr_faller selogrr_faller if iv_type==1, graph(Begg)
5. Meta-regression
Stata code:
metareg logrr_faller iv_medwithdr if iv_type==1, wsse(selogrr_faller)

Appendix F Table 2 Data for Meta-Analysis

Appendix F Table 3 Meta-Analysis Data Table Coding Key

Type of intervention:; 1. Multifactorial assessment and management; 2. Single clinical treatment; 3. Physical activity; 4. Clinical education/behavioral counseling; 5. Home hazard modification; 6. Combination
High risk categories:; 1. Fall history; 2. Functional limitation; 3. Other high risk; 4. None
Setting:; 1. In United States; 2. Outside of United States
Quality rating:; 1. Good; 2. Fair
Intervention type (fall risk assessment – strength/resistance exercise columns):; 0 No; 1 Yes
Intensity of clinical assessment interventions:; 1. Low: assessment and referral only; 2. Medium: assessment, referral, and targeted intervention or education; 3. High: assessment and multifactorial treatment

Appendix F Table 4 Meta-Regression Analysis Details

A series of meta-regressions were used to examine possible sources of heterogeneity and investigate whether the size of effect measure estimates were associated with various study-level characteristics. In all cases the outcome was the log of the risk ratio for having a fall. Separate models were run for each predictor.
The following predictors were examined among the trials categorized as “Clinical Assessment”: (a) use of medication withdrawal as part of the intervention (yes vs. no); (b) the presence of any educational component as part of the intervention (yes vs. no); (c) intensity of the educational components (moderate- or high-intensity education vs. none or low-intensity education); (d) presence of home hazard assessment or modification as part of the intervention (yes vs. no); (e) comprehensiveness of the intervention (comprehensive vs. not comprehensive); and (f) whether the sample was comprised of high-risk participants. “High risk” was defined in four different ways, each tested in separate regression models: (1) sample selected because of a previous fall; (2) sample selected for functional limitation; (3) either of the previous two definitions or any other specified by the trial; and (4) average age of 80 or older.
Among the trials categorized as “Exercise/Physical Therapy,” predictors included (a) whether the sample was composed of people at high risk for a fall (using the same four definitions as above); (b) proportion of participants with a fall in the previous year (defined using two “dummy” variables indicating 50%–75% or 75%–100% of participants with previous falls, using 0%–49% as the reference group); and (c) intensity of the intervention. Intensity was defined in three different ways: (1) as the estimated hours of intervention (a continuous variable); (2) as a dichotomous variable indicating at least 76 or more hours of intervention vs. 75 or fewer hours; and (3) as two dummy variables indicating 50–75 hours or 76 or more hours, with 0–49 hours as the reference group.
Additional models were run pooling all intervention types and by intervention type, examining the predictors: mean age, average age of 80 or older (yes vs. no), percent female, presence of any educational component as part of the intervention, and percent with a fall in the previous year (defined in two ways, as described above).