# Role of Falls History in Identifying High-Risk Adults

Appendix E Table 1 Role of Falls History in Identifying High-Risk Older Adults

Study ID | High risk selection: fall history | High risk selection: any other factors | Percent in fall risk group | Patient population | CG fall risk during followup | Effect on falls risk
Multifactorial assessment and management - comprehensive
Close 1999^80^ n = 397 | Emergency department visit, fall primary diagnosis | - | 100% | Age, mean: 78.2 (7.5) Female: 68% 30% recurrent fallers | 79% | 0.46 (sig)
Hogan 2001^82^ n = 163 | ≥ 1 falls in last 3 months; fall could not have resulted in fracture | - | 100% | Age, mean: 77.4 (7.3) Female: 74% | 79% | 0.91 (ns)
Multifactorial assessment and management - noncomprehensive
Elley 2008^79^ n = 312 | ≥ 1 in last year | 75+ | 100% | Age, mean: 80.8 (5.0) Female: 69% | 68% | 1.16 (ns)
Hendriks 2008^84^ n = 333 | Emergency department visit, fall primary diagnosis | - | 100% | Age, mean: 74.5 (5.9) Female: 69% | 46% | 0.97 (ns)
Lightbody 2002^77^ n = 348 | Emergency department visit, fall primary diagnosis | - | 100% | Age, median: 75 Female: 77% | 26% | 0.98 (ns)
Van Haastregt 2000^71^ n = 316 | ≥ 2 in last 6 months | Mobility limitation; 70+ | | Age: 77.2 (5.1) Female: 65% | 43% | 1.13 (ns)
Clinical education/behavioral counseling
Clemson 2004^103^ n = 310 | ≥ 1 in last year, or reported concern about falling | 70+ | | Age: IG: 78.31 (5.26) CG: 78.47 (5.66) Female: 74% | 58% | 0.69 (sig)
Single clinical treatment - hip protectors
Cameron 2003^66^ n = 600 | ≥ 2, or 1 requiring hospital admit, in last year | Female gender, 70+ | | Age, mean: IG: 83.2 (5.1) CG: 83.0 (4.9) Female: 100% | % fallers: NR % frequent fallers (2+ falls) (calc): IG: 46% CG: 44% (ns) # falls/person: IG: 2.70/person CG: 2.20/person | 1.23 (ns)
Single clinical treatment - vitamin D
Dhesi 2004^102^ n = 139 | ≥ 1 in last 8 weeks | Vitamin D deficient | | Age: IG: 77.0 (6.3) CG: 76.6 (6.1) Female: IG: 53/70 (76%) CG: 55/69 (80%) | 23% | 0.77 (ns)
Prince 2008^89^ n = 302 | ≥ 1 in last year | Female gender, 70+, vitamin D deficient | | Age: IG: 77.0 (4.2) CG: 77.4 (5.0) Female: 100% | 63% | 0.84 (ns)
Exercise/physical therapy
Luukinen 2007^93^ n = 486 | ≥ 2 in last year | Gait/balance impairment, poor vision, 80+; or loneliness, depression, poor self-rated health, hearing, or cognition | | Age: 88 (3) Female: IG: 78% CG: 80% | 62% | 0.94 (ns)
Rubenstein 2000^100^ n = 59 | ≥ 1 in last 6 months | Gait/balance impairment | | Age: IG: 76.4 (4.9) CG: 74.4 (4.3) Female: 0% | 32% | 1.20 (ns)

IG - intervention group; CG - control group; sig - significant; ns - not significant