# Evidence Tables (KQ3)

Appendix D Table 1 Harms of Interventions to Prevent Falls in Older Adults: Meta-Analyses

Appendix D Table 2 Harms of Interventions to Prevent Falls in Older Adults: Randomized Controlled Trials

Appendix D Table 3 Studies Excluded From the Review for Key Question 3

Reference | Reason for exclusion
Beard K. Are drugs really toxic for older people? Expert Opin Drug Saf. 2003;2:211–213. | Does not report outcomes listed in inclusion criteria
Binder EF, Schechtman KB, Ehsani AA, et al. Effects of exercise training on frailty in community-dwelling older adults: results of a randomized, controlled trial. J Am Geriatr Soc. 2002;50:1921–1928. | Comparative effectiveness study design
Bircher AJ, Stern WB. Allergic contact dermatitis from “titanium” spectacle frames. Contact Dermatitis. 2001;45:244–245. | Editorial, letter, non-systematic reviews, opinion
Brukner PD, Brown WJ. Is exercise good for you? Med J Aust. 2005;183:538–541. | Editorial, letter, non-systematic reviews, opinion
Bulat T, Castle SC, Rutledge M, Quigley P. Clinical practice algorithms: medication management to reduce fall risk in the elderly, 3: benzodiazepines, cardiovascular agents, and antidepressants. J Am Acad Nurs Pract. 2008;20:55–62. | Editorial, letter, non-systematic reviews, opinion
Clarke J, Newsom R, Canning C. Ocular trauma with small framed spectacles. Br J Ophthalmol. 2002;86:484. | Editorial, letter, non-systematic reviews, opinion
Dukas L, Schacht E, Mazor Z, Stahelin HB. Treatment with alfacalcidol in elderly people significantly decreases the high risk of falls associated with a low creatinine clearance of <65 ml/min. Osteoporos Int. 2005;16:198–203. | Provides no data not otherwise included in other articles for this study
Gardner MM, Buchner DM, Robertson MC, Campbell AJ. Practical implementation of an exercise-based falls prevention programme. Age Ageing. 2001;30:77–83. | Editorial, letter, non-systematic reviews, opinion
Gault JA, Vichnin MC, Jaeger EA, Jeffers JB. Ocular injuries associated with eyeglass wear and airbag inflation. J Trauma. 1995;38:494–497. | Editorial, letter, non-systematic reviews, opinion
Gloth FM III. An adverse event associated with hip protectors. J Am Geriatr Soc. 2005;53:553. | Editorial, letter, non-systematic reviews, opinion
Greenspan SL, Resnick NM, Parker RA. The effect of hormone replacement on physical performance in community-dwelling elderly women. Am J Med. 2005;118:1232–1239. | Comparative effectiveness study design
Hathcock JN, Shao A, Vieth R, Heaney R. Risk assessment for vitamin D. Am J Clin Nutr. 2007;85:6–18. | Does not focus on reducing risk or rate of falls or fallers
Hill KD, Moore KJ, Dorevitch MI, Day LM. Effectiveness of falls clinics: an evaluation of outcomes and client adherence to recommended interventions. J Am Geriatr Soc. 2008;56:600–608. | Does not report outcomes listed in inclusion criteria
Holick MF. High prevalence of vitamin D inadequacy and implications for health. Mayo Clin Proc. 2006;81:353–373. | Does not focus on reducing risk or rate of falls or fallers
Iwamoto J, Otaka Y, Kudo K, Takeda T, Uzawa M, Hirabayashi K. Efficacy of training program for ambulatory competence in elderly women. Keio J Med. 2004;53:85–89. | Editorial, letter, non-systematic reviews, opinion
Katoh N, Ono M, Fujisawa K, Kojima M, Sakamoto Y, Sasaki K. Relationship between pure cortical cataract appearance and the wearing of glasses: a preliminary report of a case-control study performed on the subjects in the Noto area, Japan. Dev Ophthalmol. 1997;27:56–62. | Does not report outcomes listed in inclusion criteria
Kiel DP, Magaziner J, Zimmerman S, et al. Efficacy of a hip protector to prevent hip fracture in nursing home residents: the HIP PRO randomized controlled trial. JAMA. 2007;298:413–422. | Conducted in population that is not comparable to primary care
Lamberg-Allardt C. Vitamin D in foods and as supplements. Prog Biophys Mol Biol. 2006;92:33–38. | Does not focus on reducing risk or rate of falls or fallers
Laybourne AH, Biggs S, Martin FC. Falls exercise interventions and reduced falls rate: always in the patient’s interest? Age Ageing. 2008;37:10–13. | Editorial, letter, non-systematic reviews, opinion
Li W, Keegan TH, Sternfeld B, Sidney S, Quesenberry CP Jr, Kelsey JL. Outdoor falls among middle-aged and older adults: a neglected public health problem. Am J Public Health. 2006;96:1192–1200. | Does not report outcomes listed in inclusion criteria
Nitz JC, Choy NL. The efficacy of a specific balance-strategy training programme for preventing falls among older people: a pilot randomised controlled trial. Age Ageing. 2004;33:52–58. | Comparative effectiveness study design
Parker MJ, Gillespie WJ, Gillespie LD. Hip protectors for preventing hip fractures in older people. Cochrane Database Syst Rev. 2005;CD001255. | Poor reporting
Periodic health examination, 1995 update: 3. Screening for visual problems among elderly patients. Canadian Task Force on the Periodic Health Examination. CMAJ. 1995;152:1211–1222. | Editorial, letter, non-systematic reviews, opinion
Reddy B. Prescribing in older people. Nurse Prescrib. 2006;4:378–381. | Does not report outcomes listed in inclusion criteria
Ringe JD, Farahmand P, Schacht E, Rozehnal A. Superiority of a combined treatment of alendronate and alfacalcidol compared to the combination of alendronate and plain vitamin D or alfacalcidol alone in established postmenopausal or male osteoporosis (AAC-Trial). Rheumatol Int. 2007;27:425–434. | Comparative effectiveness study design
Rudolph JL, Salow MJ, Angelini MC, McGlinchey RE. The anticholinergic risk scale and anticholinergic adverse effects in older persons. Arch Intern Med. 2008;168:508–513. | Does not focus on reducing risk or rate of falls or fallers
Shigematsu R, Chang M, Yabushita N, et al. Dance-based aerobic exercise may improve indices of falling risk in older women. Age Ageing. 2002;31:261–266. | Other quality issues
Shigematsu R, Okura T, Sakai T, Rantanen T. Square-stepping exercise versus strength and balance training for fall risk factors. Aging Clin Exp Res. 2008;20:19–24. | Comparative effectiveness study design
Shono M, Kaniwa MA. Allergic contact dermatitis from a perinone-type dye C.I. Solvent Orange 60 in spectacle frames. Contact Dermatitis. 1999;41:181–184. | Editorial, letter, non-systematic reviews, opinion
Skelton D, Dinan S, Campbell M, Rutherford O. Tailored group exercise (Falls Management Exercise—FaME) reduces falls in community-dwelling older frequent fallers (an RCT). Age Ageing. 2005;34:636–639. | Comparative effectiveness study design
Skelton DA, Beyer N. Exercise and injury prevention in older people. Scand J Med Sci Sports. 2003;13:77–85. | Editorial, letter, non-systematic reviews, opinion
Skelton DA, Dinan SM. Exercise for falls management: rationale for an exercise programme to reduce postural instability. Physio Theory Pract. 1999;15:105–120. | Provides no data not otherwise covered in other articles for this study
Soung DY, Patade A, Khalil DA, et al. Soy protein supplementation does not cause lymphocytopenia in postmenopausal women. Nutrition J. 2006;5:12. | Does not report outcomes listed in inclusion criteria
Willford CH, Kisner C, Glenn TM, Sachs L. The interaction of wearing multifocal lenses with head posture and pain. J Orthop Sports Phys Ther. 1996;23:194–199. | Conducted in a population that does not have an average age of 65 or older
Sjösten N, Vaapio S, Kivelä SL. The effects of fall prevention trials on depressive symptoms and fear of falling among the aged: a systematic review. Aging Ment Health. 2008;12:30–46. | Does not focus on reducing risk or rate of falls or fallers
Zinnecker L. Safe patient movement for therapists. Rehab Manag. 2007;20:32–37. | Does not report outcomes listed in inclusion criteria