# Evidence Tables (KQs 1, 2, 4)

Appendix C Table 1 Effectiveness of Multifactorial Assessment and Management Interventions to Prevent Falls in Older Adults

Appendix C Table 2 Effectiveness of Single Clinical Treatment Interventions to Prevent Falls in Older Adults

Appendix C Table 3 Effectiveness of Clinical Education and Behavioral Counseling Interventions to Prevent Falls in Older Adults

Appendix C Table 4 Effectiveness of Home Hazard Modification Interventions to Prevent Falls in Older Adults

Appendix C Table 5 Effectiveness of Exercise and Physical Therapy Interventions to Prevent Falls in Older Adults

Appendix C Table 6 Studies Excluded From the Review for Key Question 1

Reference | Reason for exclusion
Study finds little evidence of benefit from NHS falls clinics. Guidelines in Practice. 2008;11:10. | Provides no data not otherwise covered in other articles for this study
Alp A, Kanat E, Yurtkuran M. Efficacy of a self-management program for osteoporotic subjects. Am J Phys Med Rehabil. 2007;86:633–640. | Not conducted in primary care or other setting with a primary care-comparable population
Anstey KJ, Burns R, von Sanden C, Luszcz MA. Psychological well-being is an independent predictor of falling in an 8-year follow-up of older adults. J Gerontol B Psychol Sci Soc Sci. 2008;63B:249–257. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
Armstrong AL, Oborne J, Coupland CA, Macpherson MB, Bassey EJ, Wallace WA. Effects of hormone replacement therapy on muscle performance and balance in post-menopausal women. Clin Sci (Lond). 1996;91:685–690. | Population does not have an average age of 65 and older
Armstrong AL. Hormone replacement therapy - effects on strength, balance, and bone density [MD Thesis]. Nottingham: University of Nottingham, 1996. | Provides no data not otherwise covered in other articles for this study
Baker MK, Atlantis E, Fiatarone Singh MA. Multi-modal exercise programs for older adults. Age Ageing. 2007;36:375–381. | Used only as a source document
Barr RJ, Stewart A, Torgerson DJ, Seymour DG, Reid DM. Screening elderly women for risk of future fractures--participation rates and impact on incidence of falls and fractures. Calcif Tissue Int. 2005;76:243–248. | Poor reporting
Batchelor F, Hill K, Mackintosh S, Said C, Whitehead C. The FLASSH study: protocol for a randomised controlled trial evaluating falls prevention after stroke and two sub-studies. BMC Neurology. 2009;9:14. | No relevant outcomes
Becker C, Walter-Jung B, Nikolaus T. The other side of hip protectors. Age Ageing. 2000;29:186. | Not conducted in primary care or other setting with a primary care-comparable population
Becker C, Lindemann U, Nikolaus T. Multifactorial intervention on falls and fractures in nursing homes. Age Ageing. 2000;29(Suppl 2):18. | Provides no data not otherwise covered in other articles for this study
Ben IR, Giladi N, Gruendlinger L. Methylphenidate may reduce risk of falling in the elderly. Brown University Geriatr Psychopharmacol Update. 2008;12:3. | Does not focus on reducing risk or rate of falls or fallers
Berggren M, Stenvall M, Olofsson B, Gustafson Y. Evaluation of a fall-prevention program in older people after femoral neck fracture: a one-year follow-up. Osteoporos Int. 2008;19:801–809. | Not conducted in primary care or other setting with a primary care-comparable population
Bernabei R, Landi F, Gambassi G, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. BMJ. 1998;316:1348–1351. | Does not focus on reducing risk or rate of falls or fallers
Beswick AD, Rees K, Dieppe P, et al. Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis. Lancet. 2008;371:725–735. | Used only as a source document
Birks YF, Hildreth R, Campbell P, Sharpe C, Torgerson DJ, Watt I. Randomised controlled trial of hip protectors for the prevention of second hip fractures. Age Ageing. 2003;32:442–444. | Poor reporting
Bischoff HA, Stahelin HB, Dick W, et al. Effects of vitamin D and calcium supplementation on falls: a randomized controlled trial. J Bone Mineral Res. 2003;18:343–351. | Population not comparable to primary care
Bischoff-Ferrari HA, Orav JE, Dawson HB. Effect of vitamin D3 plus calcium on fall risk in older men and women: a 3-year randomized controlled trial [abstract]. J Bone Mineral Res. 2004;19:S57. | Provides no data not otherwise covered in other articles for this study
Bischoff-Ferrari HA, Willett WC, Wong JB, Giovannucci E, Dietrich T, Dawson-Hughes B. Fracture prevention with vitamin D supplementation: a meta-analysis of randomized controlled trials. JAMA. 2005;293:2257–2264. | Used only as a source document
Bleijlevens MH, Hendriks MR, van-Haastregt JC, et al. Process factors explaining the ineffectiveness of a multidisciplinary fall prevention programme: a process evaluation. BMC Pub Health. 2008;8:332. | Provides no data not otherwise covered in other articles for this study
Boonen S, Bischoff-Ferrari HA, Cooper C, et al. Addressing the musculoskeletal components of fracture risk with calcium and vitamin D: a review of the evidence. Calc Tissue Int. 2006;78:257–270. | Does not focus on reducing risk or rate of falls or fallers
Bourke N, Persson UM. Effects of an exercise and education based falls prevention programme for community dwelling older people with and without computerised visual feedback training -- a randomised controlled pilot study. Phys Ther Rev. 2008;13:200–201. | No relevant outcomes
Bowling A, Formby J, Grant K. Accidents in elderly care: a randomised controlled trial (Part 2). Nurs Stand. 1992;6:28–31. | Not conducted in primary care or other setting with a primary care-comparable population
Brouwer BJ, Walker C, Rydahl SJ, Culham EG. Reducing fear of falling in seniors through education and activity programs: a randomized trial. J Am Geriatr Soc. 2003;51:829–834. | Does not focus on reducing risk or rate of falls or fallers
Brownsell S, Hawley MS. Automatic fall detectors and the fear of falling. J Telemed Telecare. 2004;10:262–266. | Does not focus on reducing risk or rate of falls or fallers
Buchner DM, Cress ME, de Lateur BJ, et al. A comparison of the effects of three types of endurance training on balance and other fall risk factors in older adults. Aging (Milano). 1997;9:112–119. | Does not focus on reducing risk or rate of falls or fallers
Buchner DM, Cress ME, Wagner EH, deLateur BJ. The role of exercise in fall prevention: developing targeting criteria for exercise programs. In: Vesllas B, Toupet M, Rubenstein L, et al (eds). Falls, Balance, and Gait Disorders in the Elderly. Amsterdam: Elsevier; 1992:55–68. | Not a randomized controlled trial
Buettner LL. Focus on caregiving. Falls prevention in dementia populations: following a trial program of recreation therapy, falls were reduced by 164 percent. Provider. 2002;28:41–43. | Population not comparable to primary care
van Schoor NM, Smit JH, Twisk JW, et al. Prevention of hip fractures by external hip protectors: a randomized controlled trial. JAMA. 2003;289:1957–1962. | Population not comparable to primary care
Burton LC, Paglia MJ, German PS, Shapiro S, Damiano AM. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. Prev Med. 1995;24:492–497. | Does not focus on reducing risk or rate of falls or fallers
Byles JE, Tavener M, O'Connell RL, et al. Randomised controlled trial of health assessments for older Australian veterans and war widows. Med J Aust. 2004;181:186–190. | Does not focus on reducing risk or rate of falls or fallers
Cameron ID, Venman J, Kurrle SE et al. Hip protectors in aged-care facilities: a randomized trial of use by individual higher-risk residents. Age Ageing. 2001;30:477–481. | Population not comparable to primary care
Campbell AJ, Robertson MC, Gardner MM, Norton RN, Buchner DM. Falls prevention over 2 years: a randomized controlled trial in women 80 years and older. Age Ageing. 1999;28:513–518. | High or differential attrition
Caplan GA, Ward JA, Brennan NJ, Coconis J, Board N, Brown A. Hospital in the home: a randomised controlled trial. Med J Aust. 1999;170:156–160. | Not conducted in primary care or other setting with a primary care-comparable population
Carpenter GI, Demopoulos GR. Screening the elderly in the community: controlled trial of dependency surveillance using a questionnaire administered by volunteers. BMJ. 1990;300:1253–1256. | Does not focus on reducing risk or rate of falls or fallers
Carter S, Campbell E, Sanson FR, Corkrey R, Gillespie W. A trial of two strategies aimed at reducing falls through home hazard modification and medication review. Unpublished information (permission to quote granted). 2002. | No relevant outcomes
Carter SE, Campbell EM, Sanson-Fisher RW, Redman S, Gillespie WJ. Environmental hazards in the homes of eldery people. Age Ageing. 1997;26:195–202. | No relevant outcomes
Cauley JA, Robbins J, Chen Z, et al. Effects of estrogen plus progestin on risk of fracture and bone mineral density: the Women’s Health Initiative randomized trial. JAMA. 2003;290:1729–1738. | Does not focus on reducing risk or rate of falls or fallers
Chandler JM, Duncan PW, Kochersberger G, Studenski S. Is lower extremity strength gain associated with improvement in physical performance and disability in frail, community-dwelling elders? Arch Phys Med Rehabil. 1998;79:24–30. | Does not focus on reducing risk or rate of falls or fallers
Chapuy MC, Arlot ME, Duboeuf F, et al. Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med. 1992;327:1637–1642. | Does not focus on reducing risk or rate of falls or fallers
Cheng PT, Wu SH, Liaw MY, Wong AM, Tang FT. Symmetrical body-weight distribution training in stroke patients and its effect on fall prevention. Arch Phys Med Rehabil. 2001;82:1650–1654. | Not conducted in primary care or other setting with a primary care-comparable population
Chin a Paw MJ, de Jong N, Schouten EG, Hiddink GJ, Kok FJ. Physical exercise and/or enriched foods for functional improvement in frail, independently living elderly: a randomized controlled trial. Arch Phys Med Rehabil. 2001;82:811–817. | Does not focus on reducing risk or rate of falls or fallers
Clarke M, Clarke SJ, Jagger C. Social intervention and the elderly: a randomized controlled trial. Am J Epidemiol. 1992;136:1517–1523. | Does not focus on reducing risk or rate of falls or fallers
Close JC, Patel A, Hooper R, Glucksman E, Jackson SH, Swift CG. PROFET : improved clinical outcomes at no additional cost [abstract]. J Am Geriatr Soc. 2000;29(Suppl 1):48. | Provides no data not otherwise covered in other articles for this study
Close J. Can the incidence of falls in the elderly be reduced by a secondary prevention protocol? Oxford: National Research Register; 2003. | Not a randomized controlled trial
Close J, Hooper R, Glucksman E, Jackson S, Swift C. Predictors of falls in a high risk population: results from the Prevention of Falls in the Elderly Trial (PROFET). J Am Geriatr Soc. 2000;48:S79. | Not a randomized controlled trial
Coleman EA, Wagner EH, Grothaus LC, Hecht J, Savarino J, Buchner DM. Predicting hospitalization and functional decline in older health plan enrollees: are administrative data as accurate as self-report? J Am Geriatr Soc. 1998;46:419–425. | Does not focus on reducing risk or rate of falls or fallers
Coogler CE, Wolf SL. Balance training in elderly fallers and nonfallers. Rehabil Rd Prog Rep. 1994;96–97. | No relevant outcomes
Counsell SR, Callahan CM, Clark DO, et al. Geriatric care management for low-income seniors: a randomized controlled trial. JAMA. 2007;298:2623–2633. | Population-based or community, non-referral population
Crome P. A randomised controlled trial of a nurse-led falls prevention clinic. J Am Geriatr Soc. 2000;48:S78. | No relevant outcomes
Dalby DM, Sellors JW, Fraser FD, Fraser C, van IC, Howard M. Effect of preventive home visits by a nurse on the outcomes of frail elderly people in the community: a randomized controlled trial. CMAJ. 2000;162:497–500. | Does not focus on reducing risk or rate of falls or fallers
Dawson P, Chapman KL, Shaw FE, Kenny RA. Measuring the outcome of physiotherapy in cognitively impaired elderly patients who fall. Physiotherapy. 1997;83:352. | Does not focus on reducing risk or rate of falls or fallers
Dean CM, Rissel C, Sharkey M, et al. Exercise intervention to prevent falls and enhance mobility in community dwellers after stroke: a protocol for a randomised controlled trial. BMC Neurol. 2009;9:38. | No relevant outcomes
Devereux K, Robertson D, Briffa NK. Effects of a water-based program on women 65 years and over: a randomised controlled trial. Aust J Physiother. 2005;51:102–108. | Does not focus on reducing risk or rate of falls or fallers
Dhesi JK, Allain TJ, Mangoni AA, Jackson SH. The implications of a growing evidence base for drug use in elderly patients, 4: vitamin D and bisphosphonates for fractures and osteoporosis. Br J Clin Pharmacol. 2006;61:521–528. | Not a randomized controlled trial
Di Monaco M, Vallero F, De Toma E, De Lauso L, Tappero R, Cavanna A. A single home visit by an occupational therapist reduces the risk of falling after hip fracture in elderly women: a quasi-randomized controlled trial. J Rehabil Med. 2008;40:446–450. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
Donald IP, Pitt K, Armstrong E, Shuttleworth H. Preventing falls on an elderly care rehabilitation ward. Clin Rehabil. 2000;14:178–185. | Not conducted in primary care or other setting with a primary care-comparable population
Ebrahim S, Thompson PW, Baskaran V, Evans K. Randomized placebo-controlled trial of brisk walking in the prevention of postmenopausal osteoporosis. Age Ageing. 1997;26:253–260. | Problems with baseline comparability between groups
Edwards N. A home based, nurse delivered exercise programme reduced falls and serious injuries in people ≥80 years of age. Evid Based Nurs. 2002;5:22. | Not a randomized controlled trial
Eekhof J, De Bock G, Schaapveld K, Springer M. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17:329–333. | Does not focus on reducing risk or rate of falls or fallers
Egan M, Jaglal S, Byrne K, Wells J, Stolee P. Factors associated with a second hip fracture: a systematic review. Clin Rehabil. 2008;22:272–282. | Used only as a source document
El-Faizy M, Reinsch S. Home safety intervention for the prevention of falls. Phys Occup Ther Geriatr. 1994;12(3):33–49. | Not a randomized controlled trial
Engelhardt JB, Toseland RW, O’Donnell JC, Richie JT, Jue D, Banks S. The effectiveness and efficiency of outpatient geriatric evaluation and management. J Am Geriatr Soc. 1996;44:847–856. | Does not focus on reducing risk or rate of falls or fallers
Epstein AM, Hall JA, Fretwell M, et al. Consultative geriatric assessment for ambulatory patients: a randomized trial in a health maintenance organization. JAMA. 1990;263:538–544. | Does not focus on reducing risk or rate of falls or fallers
Eriksson BG, Mellstrom D, Svanborg A. Medical-social intervention in a 70-year-old Swedish population: a general presentation of methodological experience. Compr Gerontol [C ]. 1987;1:49–56. | Does not focus on reducing risk or rate of falls or fallers
Fabacher D, Josephson K, Pietruszka F, Linderborn K, Morley JE, Rubenstein LZ. An in-home preventive assessment program for independent older adults: a randomized controlled trial. J Am Geriatr Soc. 1994;42:630–638. | Outcome assessment not blinded
Ferreri S, Roth MT, Casteel C, Demby KB, Blalock SJ. Methodology of an ongoing, randomized controlled trial to prevent falls through enhanced pharmaceutical care. Am J Geriatr Pharmacother. 2008;6:61–81. | No relevant outcomes
Fiatarone MA, O’Neil EF, Doyle RN, Clements K. Efficacy of home-based resistance training in frail elders. In: Andrews GR, ed. Abstracts of the 16th Congress of the International Association of Gerontology. Bedford Park, South Australia: World Congress of Gerontology; 1997:323. | Poor reporting
Fuzhong L, Harmer P, Glasgow R, et al. Translation of an effective Tai Chi intervention into a community-based falls-prevention program. Am J Pub Health. 2008;98:1195–1198. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
Gallagher EM, Brunt H. Head over heels: impact of a health promotion program to reduce falls in the elderly. Can J Aging. 1996;15:84–96. | Poor reporting
Gardner M. Home-based exercises to prevent falls in elderly women. N Z J Physiother. 1998;26:6. | Provides no data not otherwise covered in other articles for this study
Gates S, Fisher JD, Cooke MW, Carter YH, Lamb SE. Multifactorial assessment and targeted intervention for preventing falls and injuries among older people in community and emergency care settings: systematic review and meta-analysis. BMJ. 2008;336:130–133. | Used only as a source document
Gill TM, Baker DI, Gottschalk M, Peduzzi PN, Allore H, Byers A. A program to prevent functional decline in physically frail, elderly persons who live at home. N Engl J Med. 2002;347:1068–1074. | Does not focus on reducing risk or rate of falls or fallers
Gitlin LN, Hauck WW, Winter L, Dennis MP, Schulz R. Effect of an in-home occupational and physical therapy intervention on reducing mortality in functionally vulnerable older people: preliminary findings. J Am Geriatr Soc. 2006;54:950–955. | Does not focus on reducing risk or rate of falls or fallers
Gitlin LN, Winter L, Dennis MP, Corcoran M, Schinfeld S, Hauck WW. A randomized trial of a multicomponent home intervention to reduce functional difficulties in older adults. J Am Geriatr Soc. 2006;54:809–816. | Does not focus on reducing risk or rate of falls or fallers
Grant AM, Avenell A, Campbell MK, et al. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium or Vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 2005;365:1621–1628. | Poor reporting
Greenspan AI, Wolf SL, Kelley ME, O’Grady M. Tai Chi and perceived health status in older adults who are transitionally frail: a randomized controlled trial. Phys Ther. 2007;87:525–535. | Does not focus on reducing risk or rate of falls or fallers
Greenspan SL, Resnick NM, Parker RA. The effect of hormone replacement on physical performance in community-dwelling elderly women. Am J Med. 2005;118:1232–1239. | Comparative effectiveness design
Gunner-Svensson F, Ipsen J, Olsen J, Waldstrom B. Prevention of relocation of the aged in nursing homes. Scand J Prim Health Care. 1984;2:49–56. | Does not focus on reducing risk or rate of falls or fallers
Hakim RM, Roginski A, Walker J. Comparison of fall risk education methods for primary prevention with community-dwelling older adults in a senior center setting. J Geriatr Phys Ther. 2007;30:60–68. | No relevant outcomes
Hall N, De Beck P, Johnson D, Mackinnon K, Gutman G, Glick N. Randomized trial of a health promotion program for frail elders. Can J Aging. 1992;11:72–91. | Does not focus on reducing risk or rate of falls or fallers
Harling A, Simpson JP. A systematic review to determine the effectiveness of Tai Chi in reducing falls and fear of falling in older adults. Phys Ther Rev. 2008;13:237–248. | Used only as a source document
Hauer K, Rost B, Rutschle K, et al. Exercise training for rehabilitation and secondary prevention of falls in geriatric patients with a history of injurious falls. J Am Geriatr Soc. 2001;49:10–20. | Not conducted in primary care or other setting with a primary care-comparable population
Hebert R, Robichaud L, Roy PM, Bravo G, Voyer L. Efficacy of a nurse-led multidimensional preventive programme for older people at risk of functional decline: a randomized controlled trial. Age Ageing. 2001;30:147–153. | Does not focus on reducing risk or rate of falls or fallers
Hendriksen C, Lund E, Stromgard E. Consequences of assessment and intervention among elderly people: a three year randomised controlled trial. Br Med J (Clin Res Ed). 1984;289:1522–1524. | Does not focus on reducing risk or rate of falls or fallers
Hien le TT, Cumming RG, Cameron ID, et al. Atypical antipsychotic medications and risk of falls in residents of aged care facilities. J Am Geriatr Soc. 2005;53:1290–1295. | Not conducted in primary care or other setting with a primary care-comparable population
Hornbrook MC, Stevens VJ, Wingfield DJ, Hollis JF, Greenlick MR, Ory MG. Preventing falls among community-dwelling older persons: results from a randomized trial. Gerontologist. 1994;34:16–23. | Comparative effectiveness design
Hourigan SR, Nitz JC, Brauer SG, O’Neill S, Wong J, Richardson CA. Positive effects of exercise on falls and fracture risk in osteopenic women. Osteoporos Int. 2008;19:1077–1086. | Population does not have an average age of 65 and older
Inokuchi S, Matsusaka N, Hayashi T, Shindo H. Feasibility and effectiveness of a nurse-led community exercise programme for prevention of falls among frail elderly people: a multi-centre controlled trial. J Rehabil Med. 2007;39:479–485. | Not a randomized controlled trial
Iyer S, Naganathan V, McLachlan AJ, Le Couteur DG. Medication withdrawal trials in people aged 65 years and older: a systematic review. Drugs Aging. 2008;25:1021–1031. | Not conducted in primary care or other setting with a primary care-comparable population
Campbell AJ, Robertson MC, La Grow SJ, et al. Randomized controlled trial of prevention of falls in people aged ≥75 with severe visual impairment: the VIP trial. BMJ. 2005;331:817. | Provides no data not otherwise covered in other articles for this study
Jensen J, Lundin-Olsson L, Nyberg L, Gustafson Y. Fall and injury prevention in older people living in residential care facilities: a cluster randomized trial. Ann Intern Med. 2002;136:733–741. | Not conducted in primary care or other setting with a primary care-comparable population
Jitapunkul S. A randomised controlled trial of regular surveillance in Thai elderly using a simple questionnaire administered by non-professional personnel. J Med Assoc Thai. 1998;81:352–356. | Setting: country below 0.90 on Human Development Index
Jones CJ, Robichaux J, Williams P, Rikli R. The effects of a 16-week exercise program on the dynamic balance of older adults. J Clin Exp Gerontol. 1992;14:165–182. | Does not focus on reducing risk or rate of falls or fallers
Karachalios T, Lyritis GP, Kaloudis J, Roidis N, Katsiri M. The effects of calcitonin on acute bone loss after pertrochanteric fractures. A prospective, randomised trial. J Bone Joint Surg Br. 2004;86:350–358. | Does not focus on reducing risk or rate of falls or fallers
Kenny RA, Seifer C. Brief report: SAFE PACE 2 (Syncope and Falls in the Elderly Pacing and Carotid Sinus Evaluation): a randomized control trial of cardiac pacing in older patients with falls and carotid sinus hypersensitivity. Am J Geriatr Cardiol. 1999;8:87. | Provides no data not otherwise covered in other articles for this study
Kerse NM, Flicker L, Jolley D, Arroll B, Young D. Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme. BMJ. 1999;319:683–687. | Does not focus on reducing risk or rate of falls or fallers
King MB, Tinetti ME. A multifactorial approach to reducing injurious falls. Clin Geriatr Med. 1996;12:745–759. | Provides no data not otherwise covered in other articles for this study
Kingston P. Older people and falls: a randomized controlled trial of a health visitor (HV) intervention. Rev Clin Gerontol. 2001;11:209–214. | Poor reporting
Kingston P. Elderly people and accidents: a prospective analysis of accidental causation among elderly populations and their post discharge requirements. Oxford: National Research Register; 2000. | Poor reporting
Kingston P. RCT of health visitor (HV) intervention in falls. Age Ageing. 2001;30(Suppl 1):40. | Poor reporting
Kono A, Kai I, Sakato C, Harker JO, Rubenstein LZ. Effect of preventive home visits for ambulatory housebound elders in Japan: a pilot study. Aging Clin Exp Res. 2004;16:293–299. | Does not focus on reducing risk or rate of falls or fallers
Kriska AM, Bayles C. A randomized exercise trial in older women: increased activity over two years and the factors associated with compliance. Med Sci Sports Exerc. 1986;18:557–562. | Population does not have an average age of 65 and older
Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents severe falls in elderly community-dwelling women: a pragmatic population-based 3-year intervention study. Aging Clin Exp Res. 2005;17:125–132. | No relevant outcomes
Latham N, Anderson C, Bennett D, Stretton C. Progressive resistance strength training for physical disability in older people. Cochrane Database Syst Rev. 2003;CD002759. | Used only as a source document
Latham NK, Anderson CS, Lee A, Bennett DA, Moseley A, Cameron ID. A randomized, controlled trial of quadriceps resistance exercise and vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). J Am Geriatr Soc. 2003;51:291–299. | Population not comparable to primary care
Lawton BA, Rose SB, Elley CR, Dowell AC, Fenton A, Moyes SA. Exercise on prescription for women aged 40–74 recruited through primary care: two year randomised controlled trial. BMJ. 2008;337:a2509. | Population does not have an average age of 65 and older
Leathley M. Fallers attending casualty. Oxford: National Research Register; 2001. | Provides no data not otherwise covered in other articles for this study
Leveille SG, Wagner EH, Davis C, et al. Preventing disability and managing chronic illness in frail older adults: a randomized trial of a community-based partnership with primary care. J Am Geriatr Soc. 1998;46:1191–1198. | Does not focus on reducing risk or rate of falls or fallers
Li F, Harmer P, Fisher KJ, et al. Tai Chi and fall reductions in older adults: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2005;60:187–194. | No relevant outcomes
Li F, Harmer P, McAuley E, et al. An evaluation of the effects of Tai Chi exercise on physical function among older persons: a randomized contolled trial. Ann Behav Med. 2001;23:139–146. | Does not focus on reducing risk or rate of falls or fallers
Lichtenstein MJ, Shields SL, Shiavi RG, Burger C. Exercise and balance in aged women: a pilot controlled clinical trial. Arch Phys Med Rehabil. 1989;70:138–143. | Does not focus on reducing risk or rate of falls or fallers
Lin MR, Wolf SL, Hwang HF, Gong SY, Chen CY. A randomized, controlled trial of fall prevention programs and quality of life in older fallers. J Am Geriatr Soc. 2007;55:499–506. | Not a randomized controlled trial
Lips P, Graafmans WC, Ooms ME, Bezemer PD, Bouter LM. Vitamin D supplementation and fracture incidence in elderly persons: a randomized, placebo-controlled clinical trial. Ann Intern Med. 1996;124:400–406. | Does not focus on reducing risk or rate of falls or fallers
Liu-Ambrose T, Khan KM, Eng JJ, Janssen PA, Lord SR, McKay HA. Resistance and agility training reduce fall risk in women aged 75 to 85 with low bone mass: a 6-month randomized, controlled trial. J Am Geriatr Soc. 2004;52:657–665. | Does not focus on reducing risk or rate of falls or fallers
Liu-Ambrose T, Khan KM, Eng JJ, Lord SR, McKay HA. Balance confidence improves with resistance or agility training: increase is not correlated with objective changes in fall risk and physical abilities. Gerontology. 2004;50:373–382. | Does not focus on reducing risk or rate of falls or fallers
Liu-Ambrose T, Donaldson MG, Ahamed Y, et al. Otago home-based strength and balance retraining improves executive functioning in older fallers: a randomized controlled trial. J Am Geriatr Soc. 2008;56:1821–1830. | Comparative effectiveness study design
Logghe IH, Zeeuwe PE, Verhagen AP, et al. Lack of effect of Tai Chi Chuan in preventing falls in elderly people living at home: a randomized clinical trial. J Am Geriatr Soc. 2009;57:70–75. | No relevant outcomes
Lord SR, Lloyd DG, Nirui M, Raymond J, Williams P, Stewart RA. The effect of exercise on gait patterns in older women: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 1996;51:M64–M70. | Does not focus on reducing risk or rate of falls or fallers
Lord SR, Ward JA, Williams P, Strudwick M. The effect of a 12-month exercise trial on balance, strength, and falls in older women: a randomized controlled trial. J Am Geriatr Soc. 1995;43:1198–1206. | Does not focus on reducing risk or rate of falls or fallers
Lord SR, Ward JA, Williams P, Zivanovic E. The effects of a community exercise program on fracture risk factors in older women. Osteoporos Int. 1996;6:361–367. | No relevant outcomes
Luukinen H, Lehtola S, Jokelainen J, Vaananen-Sainio R, Lotvonen S, Koistinen P. Prevention of disability by exercise among the elderly: a population-based, randomized, controlled trial. Scand J Prim Health Care. 2006;24:199–205. | Does not focus on reducing risk or rate of falls or fallers
Lyons RA, John A, Brophy S, et al. Modification of the home environment for the reduction of injuries. Cochrane Database Syst Rev. 2006:CD003600. | Used only as a source document
MacRae PG, Feltner ME, Reinsch S. A 1-year exercise program for older women: effects on falls, injuries, and physical performance. J Aging Phys Activ. 1994;2:127–142. | High or differential attrition
Mansfield A, Peters AL, Liu BA, Maki BE. A perturbation-based balance training program for older adults: study protocol for a randomised controlled trial. BMC Geriatrics. 2007;7:12. | Does not focus on reducing risk or rate of falls or fallers
Mariano C. A 16-week Tai Chi programme prevented falls in healthy older adults. Evid Based Nurs. 2008;11:60. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
Marston A. Can the type of walking stick issued effect mobility, confidence or fear of falling? Int J Ther Rehabil. 2007;14:229–234. | Does not focus on reducing risk or rate of falls or fallers
Masud T, Coupland C, Drummond A, et al. Multifactorial day hospital intervention to reduce falls in high risk older people in primary care: a multi-centre randomised controlled trial. Trials. 2006;7:5. | Provides no data not otherwise covered in other articles for this study
Mayo NE, Gloutney L, Levy AR. A randomized trial of identification bracelets to prevent falls among patients in a rehabilitation hospital. Arch Phys Med Rehabil. 1994;75:1302–1308. | Not conducted in primary care or other setting with a primary care-comparable population
McEwan RT, Davison N, Forster DP, Pearson P, Stirling E. Screening elderly people in primary care: a randomized controlled trial. Br J Gen Pract. 1990;40:94–97. | Does not focus on reducing risk or rate of falls or fallers
McMurdo ME, Millar AM, Daly F. A randomized controlled trial of fall prevention strategies in old peoples’ homes. Gerontology. 2000;46:83–87. | Not conducted in primary care or other setting with a primary care-comparable population
McNeely E, Clements SD, Wolf SL. A program to reduce frailty in the elderly. In: Funk SG, Tornquist EM, Champagne MT, Wiese RA, eds. Key Aspects of Elder Care: Managing Falls, Incontinence, and Cognitive Impairment. New York: Springer; 1992:89–92. | Provides no data not otherwise covered in other articles for this study
Means KM, Rodell DE, O’Sullivan PS, Cranford LA. Rehabilitation of elderly fallers: pilot study of a low to moderate intensity exercise program. Arch Phys Med Rehabil. 1996;77:1030–1036. | Not a randomized controlled trial
Millar AM, McMurdo ME. A trial of falls prevention. Age Ageing 1999;28(Suppl 1):15. | Not conducted in primary care or other setting with a primary care-comparable population
Mulrow CD, Gerety MB, Kanten D, et al. A randomized trial of physical rehabilitation for very frail nursing home residents. JAMA. 1994;271:519–524. | Not conducted in primary care or other setting with a primary care-comparable population
Mulrow CD, Gerety MB, Kanten D, DeNino LA, Cornell JE. Effects of physical therapy on functional status of nursing home residents. J Am Geriatr Soc. 1993;41:326–328. | Not conducted in primary care or other setting with a primary care-comparable population
Nakamura T, Meguro K, Sasaki H. Relationship between falls and stride length variability in senile dementia of the Alzheimer type. Gerontology. 1996;42:108–113. | Not conducted in primary care or other setting with a primary care-comparable population
Newbury J, Marley J. Preventive home visits to elderly people in the community: visits are most useful for people aged ≥75. BMJ. 2000;321:512. | Not a randomized controlled trial
Newbury J, Marley J. Functional assessment of the elderly (letter). BMJ. 1999:Oct 5. | Does not focus on reducing risk or rate of falls or fallers
Newcomer R, Maravilla V, Faculjak P, Graves MT. Outcomes of preventive case management among high-risk elderly in three medical groups: a randomized clinical trial. Eval Health Prof. 2004;27:323–348. | Does not focus on reducing risk or rate of falls or fallers
Nichols JF, Hitzelberger LM, Sherman JG, Patterson P. Effects of resistance training on muscular strength and funcational abilities of community-dwelling older adults. J Aging Phys Activ. 1995;3:238–250. | Does not focus on reducing risk or rate of falls or fallers
Nieuwboer A, Kwakkel G, Rochester L, et al. Cueing training in the home improves gait-related mobility in Parkinson’s disease: the RESCUE trial. J Neurol Neurosurg Psych. 2007;78:134–140. | Does not focus on reducing risk or rate of falls or fallers
Nowalk MP, Prendergast JM, Bayles CM, D’Amico FJ, Colvin GC. A randomized trial of exercise programs among older individuals living in two long-term care facilities: the FallsFREE program. J Am Geriatr Soc. 2001;49:859–865. | Not conducted in primary care or other setting with a primary care-comparable population
O’Donnell S, Moher D, Thomas K, Hanley DA, Cranney A. Systematic review of the benefits and harms of calcitriol and alfacalcidol for fractures and falls. J Bone Mineral Metab. 2008;26:531–542. | Used only as a source document
Papaioannou A, Adachi JD, Winegard K, et al. Efficacy of home-based exercise for improving quality of life among elderly women with symptomatic osteoporosis-related vertebral fractures. Osteoporos Int. 2003;14:677–682. | Does not focus on reducing risk or rate of falls or fallers
Pardessus V, Puisieux F, Di Pompeo C, Gaudefroy C, Thevenon A, Dewailly P. Benefits of home visits for falls and autonomy in the elderly: a randomized trial study. Am J Phys Med Rehabil. 2002;81:247–252. | Population not comparable to primary care
Parker MJ, Gillespie LD, Gillespie WJ. Hip protectors for preventing hip fractures in the elderly. Cochrane Database Syst Rev. 2004;CD001255. | Used only as a source document
Parker MJ, Gillespie WJ, Gillespie LD. Effectiveness of hip protectors for preventing hip fractures in elderly people: systematic review. BMJ. 2006;332:571–574. | Article covered by an included systematic review
Pathy MS, Bayer A, Harding K, Dibble A. Randomised trial of case finding and surveillance of elderly people at home. Lancet. 1992;340:890–893. | Does not focus on reducing risk or rate of falls or fallers
Peel N, Cartwright C, Steinberg M. Monitoring slips, trips and falls in the older community: preliminary results. Health Promot J Australia. 1998;148–150. | Does not focus on reducing risk or rate of falls or fallers
Peel N, Steinberg M, Williams G. Home safety assessment in the prevention of falls among older people. Aust N Z J Public Health. 2000;24:536–539. | Not a randomized controlled trial
Peeters GM, de Vries OJ, Elders PJ, Pluijm SM, Bouter LM, Lips P. Prevention of fall incidents in patients with a high risk of falling: design of a randomised controlled trial with an economic evaluation of the effect of multidisciplinary transmural care. BMC Geriatrics. 2007;7:15. | Provides no data not otherwise covered in other articles for this study
Pereira MA, Kriska AM, Day RD, Cauley JA, LaPorte RE, Kuller LH. A randomized walking trial in postmenopausal women: effects on physical activity and health 10 years later. Arch Intern Med. 1998;158:1695–1701. | Does not focus on reducing risk or rate of falls or fallers
Pereira MA. Ten Year Follow-Up of a Randomized Exercise Trial in Post-Menopausal Women [Phd Thesis]. Pittsburgh: University of Pittsburgh; 1996. | Does not focus on reducing risk or rate of falls or fallers
Perry SD, Radtke A, McIlroy WE, Fernie GR, Maki BE. Efficacy and effectiveness of a balance-enhancing insole. J Gerontol A Biol Sci Med Sci. 2008;63:595–602. | Population-based or community, non-referral population
Peterson JF, Kuperman GJ, Shek C, Patel M, Avorn J, Bates DW. Guided prescription of psychotropic medications for geriatric inpatients. Arch Intern Med. 2005;165:802–807. | Not conducted in primary care or other setting with a primary care-comparable population
Peterson JF, Rosenbaum BP, Waitman LR et al. Physicians’ response to guided geriatric dosing: initial results from a randomized trial. Medinfo. 2007;12:2–40. | No relevant outcomes
Pfeifer M, Begerow B, Minne HW, Suppan K, Fahrleitner-Pammer A, Dobnig H. Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int. 2009;20:315–322. | No relevant outcomes
Pit SW, Byles JE, Henry DA, Holt L, Hansen V, Bowman DA. A Quality Use of Medicines program for general practitioners and older people: a cluster randomised controlled trial. Med J Aust. 2007;187:23–30. | Does not focus on reducing risk or rate of falls or fallers
Pynoos J, Rose D, Rubenstein L, Choi IH, Sabata D. Evidence-based interventions in fall prevention. Home Health Care Serv Q. 2006;25:55–73. | Not a randomized controlled trial
Ray WA, Taylor JA, Meador KG, et al. A randomized trial of a consultation service to reduce falls in nursing homes. JAMA. 1997;278:557–562. | Not conducted in primary care or other setting with a primary care-comparable population
Reinsch S, MacRae P, Lachenbruch PA, Tobis JS. Attempts to prevent falls and injury: a prospective community study. Gerontologist. 1992;32:450–456. | Poor reporting
Resnick B. Testing the effect of the WALC intervention on exercise adherence in older adults. J Gerontol Nurs. 2002;28:40–49. | Not conducted in primary care or other setting with a primary care-comparable population
Reuben DB, Frank JC, Hirsch SH, McGuigan KA, Maly RC. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc. 1999;47:269–276. | Does not focus on reducing risk or rate of falls or fallers
Ringe JD, Farahmand P, Schacht E, Rozehnal A. Superiority of a combined treatment of alendronate and alfacalcidol compared to the combination of alendronate and plain vitamin D or alfacalcidol alone in established postmenopausal or male osteoporosis (AAC-Trial). Rheumatol Int. 2007;27:425–434. | Not a randomized controlled trial
Rizzo JA, Baker DI, McAvay G, Tinetti ME. The cost-effectiveness of a multifactorial targeted prevention program for falls among community elderly persons. Med Care. 1996;34:954–969. | Provides no data not otherwise covered in other articles for this study
Ro OC, Hjort PF. Interventional research in primary health care for the elderly. Scand J Prim Health Care. 1985;3:133–136. | Not a randomized controlled trial
Robertson MC, Devlin N, Scuffham P, Gardner MM, Buchner DM, Campbell AJ. Economic evaluation of a community based exercise programme to prevent falls. J Epidemiol Community Health. 2001;55:600–606. | Provides no data not otherwise covered in other articles for this study
Robertson MC, Gardner MM, Devlin N, McGee R, Campbell AJ. Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls, 2: controlled trial in multiple centres. BMJ. 2001;322:701–704. | Not a randomized controlled trial
Robertson MC. Development of a Falls Prevention Programme for Elderly People: Evaluation of Efficacy, Effectiveness, and Efficiency. Dunedin, New Zealand: University of Otago; 2001. | Provides no data not otherwise covered in other articles for this study
Rockwood K, Stadnyk K, Carver D, et al. A clinimetric evaluation of specialized geriatric care for rural dwelling, frail older people. J Am Geriatr Soc. 2000;48:1080–1085. | Does not focus on reducing risk or rate of falls or fallers
Rooks DS, Ransil BJ, Hayes WC. Self-paced exercise and neuromotor performance in community-dwelling older adults. J Aging Phys Activity. 1997;135–149. | Does not focus on reducing risk or rate of falls or fallers
Rubenstein LZ, Alessi CA, Josephson KR, Trinidad HM, Harker JO, Pietruszka FM. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. 2007;55:166–174. | Not a randomized controlled trial
Ryan JW, Spellbring AM. Implementing strategies to decrease risk of falls in older women. J Gerontol Nurs. 1996;22:25–31. | Poor reporting
Sakamoto K, Nakamura T, Hagino H, et al. Effects of unipedal standing balance exercise on the prevention of falls and hip fracture among clinically defined high-risk elderly individuals: a randomized controlled trial. J Orthop Sci. 2006;11:467–472. | Population not comparable to primary care
Salkeld G, Cumming RG, O’Neill E, Thomas M, Szonyi G, Westbury C. The cost effectiveness of a home hazard reduction program to reduce falls among older persons. Aust N Z J Public Health. 2000;24:265–271. | Population not comparable to primary care
Santana-Sosa E, Barriopedro MI, Lopez-Mojares LM, Perez M, Lucia A. Exercise training is beneficial for Alzheimer’s patients. Int J Sports Med. 2008;29:845–850. | Not conducted in primary care or other setting with a primary care-comparable population
Sato T, Ebihara S, Kudo H, Fujii M, Sasaki H, Butler JP. Toe clearance rehabilitative slipper for gait disorder in the elderly. Geriatr Gerontol Int. 2007;7:310–311. | Does not focus on reducing risk or rate of falls or fallers
Sato Y, Iwamoto J, Kanoko T, Satoh K. Amelioration of osteoporosis and hypovitaminosis D by sunlight exposure in hospitalized, elderly women with Alzheimer’s disease: a randomized controlled trial. J Bone Mineral Res. 2005;20:1327–1333. | Does not focus on reducing risk or rate of falls or fallers
Sato Y, Iwamoto J, Kanoko T, Satoh K. Low-dose vitamin D prevents muscular atrophy and reduces falls and hip fractures in women after stroke: a randomized controlled trial. Cerebrovasc Dis. 2005;20:187–192. | Not conducted in primary care or other setting with a primary care-comparable population
Sato Y, Iwamoto J, Kanoko T, Satoh K. Risedronate sodium therapy for prevention of hip fracture in men 65 years or older after stroke. Arch Intern Med. 2005;165:1743–1748. | Does not focus on reducing risk or rate of falls or fallers
Sato Y, Iwamoto J, Kanoko T, Satoh K. Risedronate therapy for prevention of hip fracture after stroke in elderly women. Neurology. 2005;64:811–816. | Population not comparable to primary care
Sato Y, Kanoko T, Satoh K, Iwamoto J. Menatetrenone and vitamin D2 with calcium supplements prevent nonvertebral fracture in elderly women with Alzheimer’s disease. Bone. 2005;36:61–68. | Does not focus on reducing risk or rate of falls or fallers
Sato Y, Kanoko T, Satoh K, Iwamoto J. The prevention of hip fracture with risedronate and ergocalciferol plus calcium supplementation in elderly women with Alzheimer disease: a randomized controlled trial. Arch Intern Med. 2005;165:1737–1742. | Does not focus on reducing risk or rate of falls or fallers
Sawka AM, Boulos P, Beattie K, et al. Do hip protectors decrease the risk of hip fracture in institutional and community-dwelling elderly? A systematic review and meta-analysis of randomized controlled trials. Osteoporos Int. 2005;16:1461–1474. | Used only as a source document
Schnelle JF, Alessi CA, Simmons SF, Al-Samarrai NR, Beck JC, Ouslander JG. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. J Am Geriatr Soc. 2002;50:1476–1483. | Not conducted in primary care or other setting with a primary care-comparable population
Schoenfelder DP. A fall prevention program for elderly individuals: exercise in long-term care settings. J Gerontol Nurs. 2000;26:43–51. | Population not comparable to primary care
Shapiro A, Taylor M. Effects of a community-based early intervention program on the subjective well-being, institutionalization, and mortality of low-income elders. Gerontologist. 2002;42:334–341. | Does not focus on reducing risk or rate of falls or fallers
Shaw FE, Bond J, Richardson DA, et al. Multifactorial intervention after a fall in older people with cognitive impairment and dementia presenting to the accident and emergency department: randomised controlled trial. BMJ. 2003;326:73. | Population not comparable to primary care
Shaw FE. Can multidisciplinary intervention prevent falls in patients with cognitive impairment and dementia attending a casualty department? Age Ageing. 2000;29(Suppl 1):47. | Population not comparable to primary care
Shaw F. Physiotherapy intervention for cognitively impaired elderly fallers attending casualty. Oxford: National Research Register; 2003. | Population not comparable to primary care
Shaw F. Risk modiication of falls in cognitively impaired elderly patients attending a casualty department: a randomised controlled explanatory study. Oxford: National Research Register; 2003. | Population not comparable to primary care
Shekelle PG, Maglione M, Chang JT, et al. Falls Prevention Interventions in the Medicare Population. Baltimore, MD: Centers for Medicare and Medicaid Services; 2004. | Used only as a source document
Shigematsu R, Okura T, Sakai T, Rantanen T. Square-stepping exercise versus strength and balance training for fall risk factors. Aging Clin Exp Res. 2008;20:19–24. | Comparative effectiveness design
Shigematsu R, Okura T, Nakagaichi M, et al. Square-stepping exercise and fall risk factors in older adults: a single-blind, randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2008;63:76–82. | Comparative effectiveness design
Silverman M, Musa D, Martin DC, Lave JR, Adams J, Ricci EM. Evaluation of outpatient geriatric assessment: a randomized multi-site trial. J Am Geriatr Soc. 1995;43:733–740. | Does not focus on reducing risk or rate of falls or fallers
Sjösten N, Vaapio S, Kivelä S. The effects of fall prevention trials on depressive symptoms and fear of falling among the aged: a systematic review. Aging Ment Health. 2008;12:30–46. | Does not focus on reducing risk or rate of falls or fallers
Skelton DA, Beyer N. Exercise and injury prevention in older people. Scand J Med Sci Sports. 2003;13:77–85. | Not a randomized controlled trial
Skelton DA, Stranzinger K, Dinan SM, Rutherford OM. BMD improvements following FaME (Falls Management Exercise) in frequently falling women age 65 and over: an RCT. J Aging Phys Activ. 2008;16:S89–S90. | No relevant outcomes
Smith H, Anderson F, Raphael H, Maslin P, Crozier S, Cooper C. Effect of annual intramuscular vitamin D on fracture risk in elderly men and women—a population-based, randomized, double-blind, placebo-controlled trial. Rheumatology. 2007;46:1852–1857. | Does not focus on reducing risk or rate of falls or fallers
Sohng KY, Moon JS, Song HH, Lee KS, Kim YS. Fall prevention exercise program for fall risk factor reduction of the community-dwelling elderly in Korea. Yonsei Med J. 2003;44:883–891. | Does not focus on reducing risk or rate of falls or fallers
Sorensen KH, Sivertsen J. Follow-up three years after intervention to relieve unmet medical and social needs of old people. Compr Gerontol [B]. 1988;2:85–91. | Does not focus on reducing risk or rate of falls or fallers
Spink MJ, Menz HB, Lord SR. Efficacy of a multifaceted podiatry intervention to improve balance and prevent falls in older people: study protocol for a randomised trial. BMC Geriatrics. 2008;8:30. | No relevant outcomes
Steultjens E, Clemson L. A preventative home safety programme for community-dwelling older people with low vision reduced falls and was more cost-effective than an exercise programme: commentary. Aust Occup Ther J. 2006;53:243–244. | Provides no data not otherwise covered in other articles for this study
Stevens VJ, Hornbrook MC, Wingfield DJ, Hollis JF, Greenlick MR, Ory MG. Design and implementation of a falls prevention intervention for community-dwelling older persons. Behav Health Ageing. 1991;2:57–73. | No relevant outcomes
Stevens M, Holman CD, Bennett N, de Klerk N. Preventing falls in older people: outcome evaluation of a randomized controlled trial. J Am Geriatr Soc. 2001;49:1448–1455. | No relevant outcomes
Stuck AE, Aronow HU, Steiner A, et al. A trial of annual in-home comprehensive geriatric assessments for elderly people living in the community. N Engl J Med. 1995;333:1184–1189. | Does not focus on reducing risk or rate of falls or fallers
Stuck AE, Egger M, Hammer A, Minder CE, Beck JC. Home visits to prevent nursing home a Admission and functional decline in elderly people. JAMA. 2002;287:1022–1028. | Used only as a source document
Stuck AE, Minder CE, Peter-Wuest I, et al. A randomized trial of in-home visits for disability prevention in community-dwelling older people at low and high risk for nursing home admission. Arch Intern Med. 2000;160:977–986. | Does not focus on reducing risk or rate of falls or fallers
Suzuki T, Kim H, Yoshida H, Ishizaki T. Randomized controlled trial of exercise intervention for the prevention of falls in community-dwelling elderly Japanese women. J Bone Mineral Metab. 2004;22:602–611. | High or differential attrition
Swanenburg J, de Bruin ED, Stauffacher M, Mulder T, Uebelhart D. Effects of exercise and nutrition on postural balance and risk of falling in elderly people with decreased bone mineral density: randomized controlled trial pilot study. Clin Rehabil. 2007;21:523–534. | Comparative effectiveness design
Tennstedt S, Howland J, Lachman M, Peterson E, Kasten L, Jette A. A randomized, controlled trial of a group intervention to reduce fear of falling and associated activity restriction in older adults. J Gerontol B Psychol Sci Soc Sci. 1998;53:384–392. | Does not focus on reducing risk or rate of falls or fallers
Tinetti ME, Baker DI, Gottschalk M, et al. Home-based multicomponent rehabilitation program for older persons after hip fracture: a randomized trial. Arch Phys Med Rehabil. 1999;80:916–922. | Not conducted in primary care or other setting with a primary care-comparable population
Tinetti ME, Mendes de Leon CF, Doucette JT, Baker DI. Fear of falling and fall-related efficacy in relationship to functioning among community-living elders. J Gerontol. 1994;49:M140–M147. | Not a randomized controlled trial
Tinetti ME. Prevention of falls and fall injuries in elderly persons: a research agenda. Prev Med. 1994;23:756–762. | Not a randomized controlled trial
Tobis J, Reinsch S, MacRae P, Lachenbruch T. Experimental intervention at senior centres for the prevention of falls. J Am Geriatr Soc. 1990;38:A28. | Provides no data not otherwise covered in other articles for this study
Tulloch AJ, Moore V. A randomized controlled trial of geriatric screening and surveillance in general practice. J R Coll Gen Pract. 1979;29:733–740. | Does not focus on reducing risk or rate of falls or fallers
Vaapio S, Salminen M, Vahlberg T, et al. Effects of risk-based multifactorial fall prevention on health-related quality of life among the community-dwelling aged: a randomized controlled trial. Health Qual Life Outcomes. 2007;5:20. | No relevant outcomes
Vaapio SS, Salminen MJ, Ojanlatva A, Kivela SL. Quality of life as an outcome of fall prevention interventions among the aged: a systematic review. Eur J Pub Health. 2009;19:7–15. | Used only as a source document
van der Velde N, Meerding WJ, Looman CW, Pols HA, van der Cammen TJ. Cost effectiveness of withdrawal of fall-risk-increasing drugs in geriatric outpatients. Drugs Aging. 2008;25:521–529. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
van Haastregt JC, Diederiks JP, van Rossum E, de Witte LP, Voorhoeve PM, Crebolder HF. Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321:994–998. | No relevant outcomes
van Rossum E, Frederiks CM, Philipsen H, Portengen K, Wiskerke J, Knipschild P. Effects of preventive home visits to elderly people. BMJ. 1993;307:27–32. | Does not focus on reducing risk or rate of falls or fallers
van Schoor NM, Smit JH, Twisk JW, Bouter LM, Lips P. Prevention of hip fractures by external hip protectors: a randomized controlled trial. JAMA. 2003;289:1957–1962. | Not conducted in primary care or other setting with a primary care-comparable population
Vass M, Avlund K, Kvist K, Hendriksen C, Andersen CK, Keiding N. Structured home visits to older people. Are they only of benefit for women? A randomised controlled trial. Scand J Prim Health Care. 2004;22:106–111. | Does not focus on reducing risk or rate of falls or fallers
Vassallo M, Vignaraja R, Sharma JC, Briggs RS, Allen SC. Can intervention prevent falls and injury in geriatric wards? Hospital Injury Prevention (HIP) study. Age Ageing 2001;30(Suppl 2):15. | Not conducted in primary care or other setting with a primary care-comparable population
Verfaillie DF, Nichols JF, Turkel E, Hovell MF. Effects of resistance, balance, and gait training on reduction of risk factors leading to falls in elders. J Aging Phys Activity. 1997;213–228. | Does not focus on reducing risk or rate of falls or fallers
Vetter NJ, Jones DA, Victor CR. Effect of health visitors working with elderly patients in general practice: a randomised controlled trial. Br Med J (Clin Res Ed). 1984;288:369–372. | Does not focus on reducing risk or rate of falls or fallers
Vetter NJ, Lewis PA, Ford D. Can health visitors prevent fractures in elderly people? BMJ. 1992;304:888–890. | High or differential attrition
Wallace JI, Buchner DM, Grothaus L, et al. Implementation and effectiveness of a community-based health promotion program for older adults. J Gerontol A Biol Sci Med Sci. 1998;53:M301–M306. | Does not focus on reducing risk or rate of falls or fallers
Widen HL, von Koch L, Kostulas V, et al. A randomized controlled trial of rehabilitation at home after stroke in southwest Stockholm. Stroke. 1998;29:591–597. | Population not comparable to primary care
Wilkins S, Jung B, Wishart L, Edwards M, Norton SG. The effectiveness of community-based occupational therapy education and functional training programs for older adults: a critical literature review. Can J Occup Ther. 2003;70:214–225. | Used only as a source document
Williams ME, Williams TF, Zimmer JG, Hall WJ, Podgorski CA. How does the team approach to outpatient geriatric evaluation compare with traditional care: a report of a randomized controlled trial. J Am Geriatr Soc. 1987;35:1071–1078. | Does not focus on reducing risk or rate of falls or fallers
Wolf B, Feys H, De Weerdt W, et al. Effect of a physical therapeutic intervention for balance problems in the elderly: a single-blind, randomized, controlled multicentre trial. Clin Rehabil. 2001;15:624–636. | Does not focus on reducing risk or rate of falls or fallers
Wolf SL, Barnhart HX, Ellison GL, Coogler CE. The effect of Tai Chi Quan and computerized balance training on postural stability in older subjects. Phys Ther. 1997;77:371–381. | No relevant outcomes
Wolf SL, Kutner NG, Green RC, McNeely E. The Atlanta FICSIT study: two exercise interventions to reduce frailty in elders. J Am Geriatr Soc. 1993;41:329–332. | Provides no data not otherwise covered in other articles for this study
Wolfson L, Whipple R, Derby C, et al. Balance and strength training in older adults: intervention gains and Tai Chi maintenance. J Am Geriatr Soc. 1996;44:498–506. | Does not focus on reducing risk or rate of falls or fallers
Yates SM, Dunnagan TA. Evaluating the effectiveness of a home-based fall risk reduction program for rural community-dwelling older adults. J Gerontol A Biol Sci Med Sci. 2001;56:M226–M230. | Does not focus on reducing risk or rate of falls or fallers
Zimmer JG, Groth-Juncker A, McCusker J. A randomized controlled study of a home health care team. Am J Public Health. 1985;75:134–141. | Does not focus on reducing risk or rate of falls or fallers

Appendix C Table 7 Studies Excluded From the Review for Key Questions 2 and 4

Study reference | Reason for exclusion
Study finds little evidence of benefit from NHS falls clinics. Guidelines in Practice. 2008;11:10. | Provides no data not otherwise covered in other articles for this study
Arai T, Obuchi S, Inaba Y, et al. The effects of short-term exercise intervention on falls self-efficacy and the relationship between changes in physical function and falls self-efficacy in Japanese older people: a randomized controlled trial. Am J Phys Med Rehabil. 2007;86:133–141. | No relevant outcomes
Arden NK, Crozier S, Smith H, et al. Knee pain, knee osteoarthritis, and the risk of fracture. Arthritis Rheum. 2006;55:610–615. | Not a randomized controlled trial
Armstrong AL, Oborne J, Coupland CA, Macpherson MB, Bassey EJ, Wallace WA. Effects of hormone replacement therapy on muscle performance and balance in post-menopausal women. Clin Sci (Lond). 1996;91:685–690. | Population does not have an average age of 65 and older
Armstrong AL. Hormone Replacement Therapy: Effects on Strength, Balance, and Bone Density [MD Thesis]. Nottingham: University of Nottingham; 1996. | Provides no data not otherwise covered in other articles for this study
Baker MK, Atlantis E, Fiatarone Singh MA. Multi-modal exercise programs for older adults. Age Ageing. 2007;36:375–381. | Used only as source document
Ballard JE, McFarland C, Wallace LS, Holiday DB, Roberson G. The effect of 15 weeks of exercise on balance, leg strength, and reduction in falls in 40 women aged 65 to 89 years. J Am Med Womens Assoc. 2004;59:255–261. | Poor reporting
Barr RJ, Stewart A, Torgerson DJ, Seymour DG, Reid DM. Screening elderly women for risk of future fractures—participation rates and impact on incidence of falls and fractures. Calcif Tissue Int. 2005;76:243–248. | Poor reporting
Barry H. Can strengthening exercises prevent falls in community-living elders? Evid Based Pract. 2002;5:4. | Provides no data not otherwise covered in other articles for this study
Batchelor F, Hill K, Mackintosh S, Said C, Whitehead C. The FLASSH study: protocol for a randomised controlled trial evaluating falls prevention after stroke and two sub-studies. BMC Neurology. 2009;9:14. | No relevant outcomes
Becker C, Kron M, Lindemann U, et al. Effectiveness of a multifaceted intervention on falls in nursing home residents. J Am Geriatr Soc. 2003;51:306–313. | Not conducted in primary care or other setting with primary care-comparable population
Becker C, Walter-Jung B, Nikolaus T. The other side of hip protectors. Age Ageing. 2000;29:186. | Not conducted in primary care or other setting with primary care-comparable population
Becker C, Lindemann U, Nikolaus T. Multifactorial intervention on falls and fractures in nursing homes. Age Ageing. 2000; 29(Suppl 2):18. | Provides no data not otherwise covered in other articles for this study
Ben IR, Giladi N, Gruendlinger L. Methylphenidate may reduce risk of falling in the elderly. Brown Univ Geriatr Psychopharmacol Update. 2008;12:3. | Does not focus on reducing the risk or rate of falls or fallers
Berggren M, Stenvall M, Olofsson B, Gustafson Y. Evaluation of a fall-prevention program in older people after femoral neck fracture: a one-year follow-up. Osteoporos Int. 2008;19:801–809. | Not conducted in primary care or other setting with primary care-comparable population
Bernabei R, Landi F, Gambassi G, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. BMJ. 1998;316:1348–1351. | Does not focus on reducing the risk or rate of falls or fallers
Beswick AD, Rees K, Dieppe P, et al. Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis. Lancet. 2008;371:725–735. | Used only as source document
Binder EF, Schechtman KB, Ehsani AA, et al. Effects of exercise training on frailty in community-dwelling older adults: results of a randomized, controlled trial. J Am Geriatr Soc. 2002;50:1921–1928. | Does not focus on reducing the risk or rate of falls or fallers
Birks Y. A multifactorial intervention after a fall did not prevent falls in elderly patients with cognitive impairment and dementia. Evid Based Nurs. 2003;6:114–115. | Provides no data not otherwise covered in other articles for this study
Birks YF, Hildreth R, Campbell P, Sharpe C, Torgerson DJ, Watt I. Randomised controlled trial of hip protectors for the prevention of second hip fractures. Age Ageing. 2003;32:442–444. | Poor reporting
Bischoff HA, Stahelin HB, Dick W, et al. Effects of vitamin D and calcium supplementation on falls: a randomized controlled trial. J Bone Mineral Res. 2003;18:343–351. | Population is not comparable to primary care
Bischoff-Ferrari HA, Orav JE, Dawson HB. Effect of vitamin D3 plus calcium on fall risk in older men and women: a 3-year randomized controlled trial. J Bone Mineral Res. 2004;19:S57. | Provides no data not otherwise covered in other articles for this study
Bleijlevens MH, Hendriks MR, van-Haastregt JC, et al. Process factors explaining the ineffectiveness of a multidisciplinary fall prevention programme: a process evaluation. BMC Pub Health. 2008;8:332. | Provides no data not otherwise covered in other articles for this study
Bogaerts A, Verschueren S, Delecluse C, Claessens AL, Boonen S. Effects of whole body vibration training on postural control in older individuals: a 1 year randomized controlled trial. Gait Posture. 2007;26:309–316. | No relevant outcomes
Boonen S, Bischoff-Ferrari HA, Cooper C, et al. Addressing the musculoskeletal components of fracture risk with calcium and vitamin D: a review of the evidence. Calcif Tissue Int. 2006;78:257–270. | Does not focus on reducing the risk or rate of falls or fallers
Bourke N, Persson UM. Effects of an exercise and education based falls prevention programme for community dwelling older people with and without computerised visual feedback training—a randomised controlled pilot study. Phys Ther Rev. 2008;13:200–201. | No relevant outcomes
Bowling A, Formby J, Grant K. Accidents in elderly care: a randomised controlled trial (Part 2). Nurs Stand. 1992;6:28–31. | Not conducted in primary care or other setting with primary care-comparable population
Brown C. Systematic review of the literature concluded that there is an evidence base for occupational therapy interventions with people aged 60+ living independently in the community. Occup Ther Now. 2006;8:13–14. | Not a randomized controlled trial
Buchner DM, Cress ME, de Lateur BJ, et al. A comparison of the effects of three types of endurance training on balance and other fall risk factors in older adults. Aging (Milano). 1997;9:112–119. | Does not focus on reducing the risk or rate of falls or fallers
Buchner DM, Cress ME, Wagner EH, de Lateur BJ. The role of exercise in fall prevention: developing targeting criteria for exercise programs. In: Vesllas B, Toupet M, Rubenstein L, et al, eds. Falls, Balance, and Gait Disorders in the Elderly. Amsterdam: Elsevier; 1992:55–68. | Not a randomized controlled trial
Buettner LL. Falls prevention in dementia populations: following a trial program of recreation therapy, falls were reduced by 164 percent. Provider. 2002;28:41–43. | Population is not comparable to primary care
Burton LC, Paglia MJ, German PS, Shapiro S, Damiano AM. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. Prev Med. 1995;24:492–497. | Does not focus on reducing the risk or rate of falls or fallers
Byles JE, Tavener M, O’Connell RL, et al. Randomised controlled trial of health assessments for older Australian veterans and war widows. Med J Aust. 2004;181:186–190. | Does not focus on reducing the risk or rate of falls or fallers
Cameron ID, Stafford B, Cumming RG, et al. Hip protectors improve falls self-efficacy. Age Ageing. 2000;29:57–62. | Does not focus on reducing the risk or rate of falls or fallers
Cameron ID, Venman J, Kurrle SE, et al. Hip protectors in aged-care facilities: a randomized trial of use by individual higher-risk residents. Age Ageing. 2001;30:477–481. | Population is not comparable to primary care
Campbell AJ, Robertson MC, Gardner MM, Norton RN, Buchner DM. Falls prevention over 2 years: a randomized controlled trial in women 80 years and older. Age Ageing. 1999;28:513–518. | High or differential attrition
Campbell AJ, Robertson MC. Rethinking individual and community fall prevention strategies: a meta-regression comparing single and multifactorial interventions. Age Ageing. 2007;36:656–662. | Used only as source document
Caplan GA, Ward JA, Brennan NJ, Coconis J, Board N, Brown A. Hospital in the home: a randomised controlled trial. Med J Aust. 1999;170:156–160. | Not conducted in primary care or other setting with primary care-comparable population
Carpenter GI, Demopoulos GR. Screening the elderly in the community: controlled trial of dependency surveillance using a questionnaire administered by volunteers. BMJ. 1990;300:1253–1256. | Does not focus on reducing the risk or rate of falls or fallers
Carter ND, Khan KM, McKay HA, et al. Community-based exercise program reduces risk factors for falls in 65- to 75-year-old women with osteoporosis: randomized controlled trial. CMAJ. 2002;167:997–1004. | Does not focus on reducing the risk or rate of falls or fallers
Carter ND, Khan KM, Petit MA, et al. Results of a 10 week community based strength and balance training programme to reduce fall risk factors: a randomised controlled trial in 65–75 year old women with osteoporosis. Br J Sports Med. 2001;35:348–351. | Does not focus on reducing the risk or rate of falls or fallers
Carter S, Campbell E, Sanson FR, Corkrey R, Gillespie W. A trial of two strategies aimed at reducing falls through home hazard modification and medication review. Unpublished information. 2002. | No relevant outcomes
Carter SE, Campbell EM, Sanson-Fisher RW, Redman S, Gillespie WJ. Environmental hazards in the homes of eldery people. Age Ageing. 1997;26:195–202. | No relevant outcomes
Cerny K. The effect of a multidimensional exercise program on strength, range of motion, balance, and gait in the well elderly. Gait Posture. 1998;7:185–186. | No relevant outcomes
Chandler JM, Duncan PW, Kochersberger G, Studenski S. Is lower extremity strength gain associated with improvement in physical performance and disability in frail, community-dwelling elders? Arch Phys Med Rehabil. 1998;79:24–30. | Does not focus on reducing the risk or rate of falls or fallers
Chapuy MC, Arlot ME, Duboeuf F, et al. Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med. 1992;327:1637–1642. | Does not focus on reducing the risk or rate of falls or fallers
Cheng PT, Wu SH, Liaw MY, Wong AM, Tang FT. Symmetrical body-weight distribution training in stroke patients and its effect on fall prevention. Arch Phys Med Rehabil. 2001;82:1650–1654. | Not conducted in primary care or other setting with primary care-comparable population
Choi JH, Moon J, Song R. Effects of Sun-style Tai Chi exercise on physical fitness and fall prevention in fall-prone older adults. J Adv Nurs. 2005;51:150–157. | Not a randomized controlled trial
Clarke M, Clarke SJ, Jagger C. Social intervention and the elderly: a randomized controlled trial. Am J Epidemiol. 1992;136:1517–1523. | Does not focus on reducing the risk or rate of falls or fallers
Close J. Prevention of Falls in the Elderly Trial (PROFET): a randomised controlled trial. Curr Control Trials. 2003. | Provides no data not otherwise covered in other articles for this study
Close JC, Patel A, Hooper R, Glucksman E, Jackson SH, Swift CG. PROFET : improved clinical outcomes at no additional cost. J Am Geriatr Soc. 2000;29(Suppl 1):48. | Provides no data not otherwise covered in other articles for this study
Close J. Can the incidence of falls in the elderly be reduced by a secondary prevention protocol? Oxford: National Research Register; 2003. | Not a randomized controlled trial
Close J, Hooper R, Glucksman E, Jackson S, Swift C. Predictors of falls in a high risk population: results from the Prevention of Falls in the Elderly Trial (PROFET). J Am Geriatr Soc. 2000;48:S79. | Not a randomized controlled trial
Coleman EA, Wagner EH, Grothaus LC, Hecht J, Savarino J, Buchner DM. Predicting hospitalization and functional decline in older health plan enrollees: are administrative data as accurate as self-report? J Am Geriatr Soc. 1998;46:419–425. | Does not focus on reducing the risk or rate of falls or fallers
Coogler CE, Wolf SL. Balance training in elderly fallers and nonfallers. Rehabil Rd Prog Rep. 1994;96–97. | No relevant outcomes
Cranney A, Hanley D, Horsley T, et al. Effectiveness and Safety of Vitamin D in Relation to Bone Health. Rockville, MD: Agency for Healthcare Research and Quality; 2007. | Used only as source document
Crome P. A randomised controlled trial of a nurse led falls prevention clinic. J Am Geriatr Soc. 2000;48:S78. | No relevant outcomes
Cumming RG, Thomas M, Szonyi G, et al. Home visits by an occupational therapist for assessment and modification of environmental hazards: a randomized trial of falls prevention. J Am Geriatr Soc. 1999;47:1397–1402. | Population is not comparable to primary care
Cumming RG, Thomas M, Szonyi G, Frampton G, Salkeld G, Clemson L. Adherence to occupational therapist recommendations for home modifications for falls prevention. Am J Occup Ther. 2001;55:641–648. | Not a randomized controlled trial
Dalby DM, Sellors JW, Fraser FD, Fraser C, van IC, Howard M. Effect of preventive home visits by a nurse on the outcomes of frail elderly people in the community: a randomized controlled trial. CMAJ. 2000;162:497–500. | Does not focus on reducing the risk or rate of falls or fallers
Davis JC, Donaldson MG, Ashe MC, Khan KM. The role of balance and agility training in fall reduction: a comprehensive review. Europa Medicophysica. 2004;40:211–221. | Used only as source document
Dawson P, Chapman KL, Shaw FE, Kenny RA. Measuring the outcome of physiotherapy in cognitively impaired elderly patients who fall. Physiotherapy. 1997;83:352. | Does not focus on reducing the risk or rate of falls or fallers
Dean CM, Rissel C, Sharkey M, et al. Exercise intervention to prevent falls and enhance mobility in community dwellers after stroke: a protocol for a randomised controlled trial. BMC Neurol. 2009;9:38. | No relevant outcomes
Di Monaco M, Vallero F, De Toma E, De Lauso L, Tappero R, Cavanna A. A single home visit by an occupational therapist reduces the risk of falling after hip fracture in elderly women: a quasi-randomized controlled trial. J Rehabil Med. 2008;40:446–450. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
Donald IP, Pitt K, Armstrong E, Shuttleworth H. Preventing falls on an elderly care rehabilitation ward. Clin Rehabil. 2000;14:178–185. | Not conducted in primary care or other setting with primary care-comparable population
Dukas L, Bischoff HA, Lindpaintner LS, Schacht E, Birkner BD, Thalmann B. Alfacalcidol reduces the number of fallers and falls in community-dwelling elderly provided a mainimum total daily intake of 500mg calcium. Calcif Tissue Int. 2003;72:371. | Provides no data not otherwise covered in other articles for this study
Dukas L, Schacht E, Mazor Z, Stahelin HB. Treatment with alfacalcidol in elderly people significantly decreases the high risk of falls associated with a low creatinine clearance of <65 ml/min. Osteoporos Int. 2005;16:198–203. | Provides no data not otherwise covered in other articles for this study
Dyer CA, Taylor GJ, Halpin M, Dyer CA, Robertson DR, Harrington R. Falls prevention in residential homes: a randomised controlled trial. Age Ageing. 2003;32:16. | Not conducted in primary care or other setting with primary care-comparable population
Ebrahim S, Thompson PW, Baskaran V, Evans K. Randomized placebo-controlled trial of brisk walking in the prevention of postmenopausal osteoporosis. Age Ageing. 1997;26:253–260. | Problems with baseline comparability between groups
Edwards N. A home based, nurse delivered exercise programme reduced falls and serious injuries in people ≥80 years of age. Evid Based Nurs. 2002;5:22. | Not a randomized controlled trial
Eekhof J, De Bock G, Schaapveld K, Springer M. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17:329–333. | Does not focus on reducing the risk or rate of falls or fallers
El-Faizy M, Reinsch S. Home safety intervention for the prevention of falls. Phys Occup Ther Geriatr. 1994;12:33–49. | Not a randomized controlled trial
Engelhardt JB, Toseland RW, O’Donnell JC, Richie JT, Jue D, Banks S. The effectiveness and efficiency of outpatient geriatric evaluation and management. J Am Geriatr Soc. 1996;44:847–856. | Does not focus on reducing the risk or rate of falls or fallers
Englund U, Littbrand H, Sondell A, Pettersson U, Bucht G. A 1-year combined weight-bearing training program is beneficial for bone mineral density and neuromuscular function in older women. Osteoporos Int. 2005;16:1117–1123. | Does not focus on reducing the risk or rate of falls or fallers
Epstein AM, Hall JA, Fretwell M, et al. Consultative geriatric assessment for ambulatory patients: a randomized trial in a health maintenance organization. JAMA. 1990;263:538–544. | Does not focus on reducing the risk or rate of falls or fallers
Eriksson BG, Mellstrom D, Svanborg A. Medical-social intervention in a 70-year-old Swedish population: a general presentation of methodological experience. Compr Gerontol [C ]. 1987;1:49–56. | Does not focus on reducing the risk or rate of falls or fallers
Faddis MN, Rich MW. Pacing interventions for falls and syncope in the elderly. Clin Geriatr Med. 2002;18:279–294. | Not a randomized controlled trial
Feder G, Cryer C, Donovan S, Carter Y. Guidelines for the prevention of falls in people over 65. BMJ. 2000;321:1007–1011. | Provides no data not otherwise covered in other articles for this study
Ferreri S, Roth MT, Casteel C, Demby KB, Blalock SJ. Methodology of an ongoing, randomized controlled trial to prevent falls through enhanced pharmaceutical care. Am J Geriatr Pharmacother. 2008;6:61–81. | No relevant outcomes
Fosnight SM, Zafirau WJ, Hazelett SE. Vitamin D supplementation to prevent falls in the elderly: evidence and practical considerations. Pharmacother. 2008;28:225–234. | Not a randomized controlled trial
Freiberger E, Menz HB, bu-Omar K, Rutten A. Preventing falls in physically active community-dwelling older people: a comparison of two intervention techniques. Gerontology. 2007;53:298–305. | Problems with baseline comparability between groups
Fuzhong L, Harmer P, Glasgow R, et al. Translation of an effective Tai Chi intervention into a community-based falls-prevention program. Am J Pub Health. 2008;98:1195–1198. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
Gallagher EM, Brunt H. Head over heels: impact of a health promotion program to reduce falls in the elderly. Can J Aging. 1996;15:84–96. | Poor reporting
Gallagher JC, Haynatski G, Fowler S. Calcitriol therapy reduces falls and fractures in elderly women. Calcif Tissue Int. 2003;72:334. | Provides no data not otherwise covered in other articles for this study
Gallagher JC, Rapuri P, Smith L. Falls are associated with decreased renal function and insufficient calcitriol production by the kidney. J Steroid Biochem Mol Bio. 2007;103:610–613. | Provides no data not otherwise covered in other articles for this study
Gallagher JC, Rapuri PB, Smith LM. An age-related decrease in creatinine clearance is associated with an increase in number of falls in untreated women but not in women receiving calcitriol treatment. J Clin Endocrinol Metab. 2007;92:51–58. | Provides no data not otherwise covered in other articles for this study
Gardner MM, Phty M, Robertson MC, McGee R, Campbell AJ. Application of a falls prevention program for older people to primary health care practice. Prev Med. 2002;34:546–553. | Not a randomized controlled trial
Gardner M. Home-based exercises to prevent falls in elderly women. N Z J Physiother. 1998;26:6. | Provides no data not otherwise covered in other articles for this study
Gates S, Fisher JD, Cooke MW, Carter YH, Lamb SE. Multifactorial assessment and targeted intervention for preventing falls and injuries among older people in community and emergency care settings: systematic review and meta-analysis. BMJ. 2008;336:130–133. | Used only as source document
Grahn Kronhed AC, Blomberg C, Lofman O, Timpka T, Moller M. Evaluation of an osteoporosis and fall risk intervention program for community-dwelling elderly. A quasi-experimental study of behavioral modifications. Aging Clin Exp Res. 2006;18:235–241. | Not a randomized controlled trial
Greenspan SL, Resnick NM, Parker RA. The effect of hormone replacement on physical performance in community-dwelling elderly women. Am J Med. 2005;118:1232–1239. | Comparative effectiveness design
Gunner-Svensson F, Ipsen J, Olsen J, Waldstrom B. Prevention of relocation of the aged in nursing homes. Scand J Prim Health Care. 1984;2:49–56. | Does not focus on reducing the risk or rate of falls or fallers
Healey F, Monro A, Cockram A, et al. Using targeted risk factor reduction to prevent falls in older inpatients: a randomised controlled trial. Age Ageing. 2005;34:311–312. | Not a randomized controlled trial
Hakim RM, Roginski A, Walker J. Comparison of fall risk education methods for primary prevention with community-dwelling older adults in a senior center setting. J Geriatr Phys Ther. 2007;30:60–68. | No relevant outcomes
Hall N, De Beck P, Johnson D, Mackinnon K, Gutman G, Glick N. Randomized trial of a health promotion program for frail elders. Can J Aging. 1992;11:72–91. | Does not focus on reducing the risk or rate of falls or fallers
Harling A, Simpson JP. A systematic review to determine the effectiveness of Tai Chi in reducing falls and fear of falling in older adults. Phys Ther Rev. 2008;13:237–248. | Used only as source document
Hauer K, Rost B, Rutschle K, et al. Exercise training for rehabilitation and secondary prevention of falls in geriatric patients with a history of injurious falls. J Am Geriatr Soc. 2001;49:10–20. | Not conducted in primary care or other setting with primary care-comparable population
Helbostad JL, Sletvold O, Moe-Nilssen R. Effects of home exercises and group training on functional abilities in home-dwelling older persons with mobility and balance problems: a randomized study. Aging Clin Exp Res. 2004;16:113–121. | Not a randomized controlled trial
Hendriks MR, van Haastregt JC, Diederiks JP, Evers SM, Crebolder HF, van Eijk JT. Effectiveness and cost-effectiveness of a multidisciplinary intervention programme to prevent new falls and functional decline among elderly persons at risk: design of a replicated randomised controlled trial. BMC Pub Health. 2005;5:6. | Provides no data not otherwise covered in other articles for this study
Hendriksen C, Lund E, Stromgard E. Consequences of assessment and intervention among elderly people: a three year randomised controlled trial. Br Med J (Clin Res Ed). 1984;289:1522–1524. | Does not focus on reducing the risk or rate of falls or fallers
Hien le TT, Cumming RG, Cameron ID, et al. Atypical antipsychotic medications and risk of falls in residents of aged care facilities. J Am Geriatr Soc. 2005;53:1290–1295. | Not conducted in primary care or other setting with primary care-comparable population
Hill K. Review: intrinsic and environmental risk-factor modification reduces falls in elderly persons. ACP J Club. 2002;137:9. | Used only as source document
Homoud M. Cardiac pacing reduced nonaccidental falls in older adults with cardioinhibitory carotid sinus hypersensitivity. ACP J Club. 2002;137:8. | Provides no data not otherwise covered in other articles for this study
Hornbrook MC, Stevens VJ, Wingfield DJ, Hollis JF, Greenlick MR, Ory MG. Preventing falls among community-dwelling older persons: results from a randomized trial. Gerontologist. 1994;34:16–23. | Comparative effectiveness study design
Hourigan SR, Nitz JC, Brauer SG, O’Neill S, Wong J, Richardson CA. Positive effects of exercise on falls and fracture risk in osteopenic women. Osteoporos Int. 2008;19:1077–1086. | Population does not have an average age of 65 and older
Inokuchi S, Matsusaka N, Hayashi T, Shindo H. Feasibility and effectiveness of a nurse-led community exercise programme for prevention of falls among frail elderly people: a multi-centre controlled trial. J Rehabil Med. 2007;39:479–485. | Not a randomized controlled trial
Iyer S, Naganathan V, McLachlan AJ, Le Couteur DG. Medication withdrawal trials in people aged 65 years and older: a systematic review. Drugs Aging. 2008;25:1021–1031. | Not conducted in primary care or other setting with primary care-comparable population
Jacobs R, Campbell AJ, Robertson MC. Randomized controlled trial of falls prevention in people 75 years and older with severe visual impairment. Am Acad Optom. 2005. | Provides no data not otherwise covered in other articles for this study
Jensen J, Lundin-Olsson L, Nyberg L, Gustafson Y. Fall and injury prevention in older people living in residential care facilities: a cluster randomized trial. Ann Intern Med. 2002;136:733–741. | Not conducted in primary care or other setting with primary care-comparable population
Jessup JV, Horne C, Vishen RK, Wheeler D. Effects of exercise on bone density, balance, and self-efficacy in older women. Biol Res Nurs. 2003;4:171–180. | Does not focus on reducing the risk or rate of falls or fallers
Jitapunkul S. A randomised controlled trial of regular surveillance in Thai elderly using a simple questionnaire administered by non-professional personnel. J Med Assoc Thai. 1998;81:352–356. | Setting: country below 0.90 on Human Development Index
Jones CJ, Robichaux J, Williams P, Rikli R. The effects of a 16-week exercise program on the dynamic balance of older adults. J Clin Exp Gerontol. 1992;14:165–182. | Does not focus on reducing the risk or rate of falls or fallers
Kannus P, Parkkari J, Niemi S, et al. Prevention of hip fracture in elderly people with use of a hip protector. N Engl J Med. 2000;343:1506–1513. | Not conducted in primary care or other setting with primary care-comparable population
Karachalios T, Lyritis GP, Kaloudis J, Roidis N, Katsiri M. The effects of calcitonin on acute bone loss after pertrochanteric fractures: a prospective, randomised trial. J Bone Joint Surg Br. 2004;86:350–358. | Does not focus on reducing the risk or rate of falls or fallers
Karmisholt K, Gyntelberg F, Gotzche PC. Physical activity for primary prevention of disease: systematic reviews of randomised clinical trials. Dan Med Bull. 2005;52:86–89. | Article covered by an included systematic review
Kennedy JS, Young CA, Hoffman VP, Feldman PD, Deberdt W. A placebo-controlled 10-week prospective comparison of the occurrence of falls in dementia: olanzapine versus risperidone. Poster presented at: International College of Geriatric Psychoneuropharmacology; October 10–12, 2002; Barcelona, Spain. | Population is not comparable to primary care
Kenny RA, Richardson DA, Steen N, Bexton RS, Shaw FE, Bond J. Carotid sinus syndrome: a modifiable risk factor for nonaccidental falls in older adults (SAFE PACE). J Am Coll Cardiol. 2001;38:1491–1496. | Population is not comparable to primary care
Kenny RA, Richardson DA. Carotid sinus syndrome and falls in older adults. Am J Geriatr Cardiol. 2001;10:97–99. | Population is not comparable to primary care
Kenny RA, Seifer C. Brief report: SAFE PACE 2 (Syncope and Falls in the Elderly—Pacing and Carotid Sinus Evaluation): a randomized control trial of cardiac pacing in older patients with falls and carotid sinus hypersensitivity. Am J Geriatr Cardiol. 1999;8:87. | Provides no data not otherwise covered in other articles for this study
Kercher BJ, Rubenstein LZ. Home-safety checklists for elders in print and on the Internet. Generations. 2002;26:69–74. | Not a randomized controlled trial
Kerse NM, Flicker L, Jolley D, Arroll B, Young D. Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme. BMJ. 1999;319:683–687. | Does not focus on reducing the risk or rate of falls or fallers
King MB, Tinetti ME. A multifactorial approach to reducing injurious falls. Clin Geriatr Med. 1996;12:745–759. | Provides no data not otherwise covered in other articles for this study
Kingston P. Older people and falls: a randomized controlled trial of a health visitor (HV) intervention. Rev Clin Gerontol. 2001;11:209–214. | Poor reporting
Kingston P. Elderly people and accidents: a prospective analysis of accidental causation among elderly populations and their post discharge requirements. Oxford: National Research Register; 2000. | Poor reporting
Kingston P. RCT of health visitor (HV) intervention in falls. Age Ageing. 2001;30(Suppl 1):40. | Poor reporting
Kinirons MT, Martin F, Lightbody E, et al. Randomised controlled trial of a nurse-led falls prevention programme. Age Ageing. 2003;32:361–363. | Not a randomized controlled trial
Komagata S, Newton R. The effectiveness of Tai Chi on improving balance in older adults: an evidence-based review. J Geriatr Phys Ther. 2003;26:9–16. | Not a randomized controlled trial
Kono A, Kai I, Sakato C, Harker JO, Rubenstein LZ. Effect of preventive home visits for ambulatory housebound elders in Japan: a pilot study. Aging Clin Exp Res. 2004;16:293–299. | Does not focus on reducing the risk or rate of falls or fallers
Kriska AM, Bayles C. A randomized exercise trial in older women: increased activity over two years and the factors associated with compliance. Med Sci Sports Exerc. 1986;18:557–562. | Population does not have an average age of 65 and older
La Grow SJ, Robertson MC, Campbell AJ, Clarke GA, Kerse NM. Reducing hazard related falls in people 75 years and older with significant visual impairment: how did a successful program work? Injury Prev. 2006;12:296–301. | Provides no data not otherwise covered in other articles for this study
Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents severe falls in elderly community-dwelling women: a pragmatic population-based 3-year intervention study. Aging Clin Exp Res. 2005;17:125–132. | No relevant outcomes
Latham NK, Anderson CS, Reid IR. Effects of vitamin D supplementation on strength, physical performance, and falls in older persons: a systematic review. J Am Geriatr Soc. 2003;51:1219–1226. | Used only as source document
Latham NK, Bennett DA, Stretton CM, Anderson CS. Systematic review of progressive resistance strength training in older adults. J Gerontol A Biol Sci Med Sci. 2004;59A:48–61. | Used only as source document
Lawton BA, Rose SB, Elley CR, Dowell AC, Fenton A, Moyes SA. Exercise on prescription for women aged 40–74 recruited through primary care: two year randomised controlled trial. BMJ. 2008;337:a2509. | Population does not have an average age of 65 and older
Leathley M. Fallers attending casualty. Oxford: National Research Register; 2001. | Provides no data not otherwise covered in other articles for this study
Lee MS, Pittler MH, Shin BC, Ernst E. Tai Chi for osteoporosis: a systematic review. Osteoporos Int. 2008;19:139–146. | No relevant outcomes
Leveille SG, Wagner EH, Davis C, et al. Preventing disability and managing chronic illness in frail older adults: a randomized trial of a community-based partnership with primary care. J Am Geriatr Soc. 1998;46:1191–1198. | Does not focus on reducing the risk or rate of falls or fallers
Li F, Harmer P, Fisher KJ, McAuley E. Tai Chi: improving functional balance and predicting subsequent falls in older persons. Med Sci Sports Exerc. 2004;36:2046–2052. | Provides no data not otherwise covered in other articles for this study
Li Y, Devault CN, Van Oteghen S. Effects of extended Tai Chi intervention on balance and selected motor functions of the elderly. Am J Chin Med. 2007;35:383–391. | No relevant outcomes
Lichtenstein MJ, Shields SL, Shiavi RG, Burger C. Exercise and balance in aged women: a pilot controlled clinical trial. Arch Phys Med Rehabil. 1989;70:138–143. | Does not focus on reducing the risk or rate of falls or fallers
Lin MR, Wolf SL, Hwang HF, Gong SY, Chen CY. A randomized, controlled trial of fall prevention programs and quality of life in older fallers. J Am Geriatr Soc. 2007;55:499–506. | Not a randomized controlled trial
Lips P, Graafmans WC, Ooms ME, Bezemer PD, Bouter LM. Vitamin D supplementation and fracture incidence in elderly persons: a randomized, placebo-controlled clinical trial. Ann Intern Med. 1996;124:400–406. | Does not focus on reducing the risk or rate of falls or fallers
Liu-Ambrose T, Donaldson MG, Ahamed Y, et al. Otago home-based strength and balance retraining improves executive functioning in older fallers: a randomized controlled trial. J Am Geriatr Soc. 2008;56:1821–1830. | Comparative effectiveness design
Liu-Ambrose T, Khan KM, Eng JJ, Janssen PA, Lord SR, McKay HA. Resistance and agility training reduce fall risk in women aged 75 to 85 with low bone mass: a 6-month randomized, controlled trial. J Am Geriatr Soc. 2004;52:657–665. | Does not focus on reducing the risk or rate of falls or fallers
Liu PY, Swerdloff RS, Veldhuis JD. The rationale, efficacy and safety of androgen therapy in older men: future research and current practice recommendations. J Clin Endocrinol Metab. 2004;89:4789–4796. | Does not focus on reducing the risk or rate of falls or fallers
Lord SR, Castell S, Corcoran J, et al. The effect of group exercise on physical functioning and falls in frail older people living in retirement villages: a randomized, controlled trial. J Am Geriatr Soc. 2003;51:1685–1692. | Not conducted in primary care or other setting with primary care-comparable population
Lord SR, Lloyd DG, Nirui M, Raymond J, Williams P, Stewart RA. The effect of exercise on gait patterns in older women: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 1996;51:M64–M70. | Does not focus on reducing the risk or rate of falls or fallers
Lord SR, Ward JA, Williams P, Zivanovic E. The effects of a community exercise program on fracture risk factors in older women. Osteoporos Int. 1996;6:361–367. | No relevant outcomes
Lyons RA, John A, Brophy S, et al. Modification of the home environment for the reduction of injuries. Cochrane Database Syst Rev. 2006:CD003600. | Used only as source document
MacRae PG, Feltner ME, Reinsch S. A 1-year exercise program for older women: effects on falls, injuries, and physical performance. J Aging Phys Activ. 1994;2:127–142. | High or differential attrition
Madureira MM, Takayama L, Gallinaro AL, Caparbo VF, Costa RA, Pereira RM. Balance training program is highly effective in improving functional status and reducing the risk of falls in elderly women with osteoporosis: a randomized controlled trial. Osteoporos Int. 2007;18:419–425. | Not conducted in primary care or other setting with primary care-comparable population
Mahoney JE, Shea TA, Przybelski R, et al. Kenosha County falls prevention study: a randomized, controlled trial of an intermediate-intensity, community-based multifactorial falls intervention. J Am Geriatr Soc. 2007;55:489–498. | Not a randomized controlled trial
Mansfield A, Peters AL, Liu BA, Maki BE. A perturbation-based balance training program for older adults: study protocol for a randomised controlled trial. BMC Geriatrics. 2007;7:12. | Does not focus on reducing the risk or rate of falls or fallers
Mariano C. A 16-week Tai Chi programme prevented falls in healthy older adults. Evid Based Nurs. 2008;11:60. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
Marigold DS, Eng JJ, Dawson AS, Inglis JT, Harris JE, Gylfadottir S. Exercise leads to faster postural reflexes, improved balance and mobility, and fewer falls in older persons with chronic stroke. J Am Geriatr Soc. 2005;53:416–423. | Not a randomized controlled trial
Masud T, Coupland C, Drummond A, et al. Multifactorial day hospital intervention to reduce falls in high risk older people in primary care: a multi-centre randomised controlled trial. Trials. 2006;7:5. | Provides no data not otherwise covered in other articles for this study
Mayo NE, Gloutney L, Levy AR. A randomized trial of identification bracelets to prevent falls among patients in a rehabilitation hospital. Arch Phys Med Rehabil. 1994;75:1302–1308. | Not conducted in primary care or other setting with primary care-comparable population
McKiernan FE. A simple gait-stabilizing device reduces outdoor falls and nonserious injurious falls in fall-prone older people during the winter. J Am Geriatr Soc. 2005;53:943–947. | Poor reporting
McMurdo ME, Millar AM, Daly F. A randomized controlled trial of fall prevention strategies in old peoples’ homes. Gerontology. 2000;46:83–87. | Not conducted in primary care or other setting with primary care-comparable population
McMurdo ME, Mole PA, Paterson CR. Controlled trial of weight bearing exercise in older women in relation to bone density and falls. BMJ. 1997;314:569. | Population is not comparable to primary care
McNeely E, Clements SD, Wolf SL. A program to reduce frailty in the elderly. In: Funk SG, Tornquist EM, Champagne MT, Wiese RA, eds. Key Aspects of Elder Care: Managing Falls, Incontinence, and Cognitive Impairment. New York: Springer; 1992:89–92. | Provides no data not otherwise covered in other articles for this study
Means KM, Rodell DE, O’Sullivan PS, Cranford LA. Rehabilitation of elderly fallers: pilot study of a low to moderate intensity exercise program. Arch Phys Med Rehabil. 1996;77:1030–1036. | Not a randomized controlled trial
Means KM, Rodell DE, O’Sullivan PS. Balance, mobility, and falls among community-dwelling elderly persons: effects of a rehabilitation exercise program. Am J Phys Med Rehabil. 2005;84:238–250. | High or differential attrition
Millar AM, McMurdo ME. A trial of falls prevention. Age Ageing. 1999;28(Suppl 1):15. | Not conducted in primary care or other setting with primary care-comparable population
Moreland J, Richardson J, Chan DH, et al. Evidence-based guidelines for the secondary prevention of falls in older adults. Gerontology. 2003;49:93–116. | Used only as source document
Mulrow CD, Gerety MB, Kanten D, DeNino LA, Cornell JE. Effects of physical therapy on functional status of nursing home residents. J Am Geriatr Soc. 1993;41:326–328. | Not conducted in primary care or other setting with primary care-comparable population
Nakamura T, Meguro K, Sasaki H. Relationship between falls and stride length variability in senile dementia of the Alzheimer type. Gerontology. 1996;42:108–113. | Not conducted in primary care or other setting with primary care-comparable population
Nakamura Y, Tanaka K, Yabushita N, Sakai T, Shigematsu R. Effects of exercise frequency on functional fitness in older adult women. Arch Gerontol Geriatr. 2007;44:163–173. | Does not focus on reducing the risk or rate of falls or fallers
Nelson ME, Layne JE, Bernstein MJ, et al. The effects of multidimensional home-based exercise on functional performance in elderly people. J Gerontol A Biol Sci Med Sci. 2004;59:154–160. | Does not focus on reducing the risk or rate of falls or fallers
Newbury J, Marley J. Preventive home visits to elderly people in the community: visits are most useful for people aged ≥75. BMJ. 2000;321:512. | Not a randomized controlled trial
Newbury J, Marley J. Functional assessment of the elderly (letter). BMJ. 1999:Oct 5. | Does not focus on reducing the risk or rate of falls or fallers
Newcomer R, Maravilla V, Faculjak P, Graves MT. Outcomes of preventive case management among high-risk elderly in three medical groups: a randomized clinical trial. Eval Health Prof. 2004;27:323–348. | Does not focus on reducing the risk or rate of falls or fallers
Nichols JF, Hitzelberger LM, Sherman JG, Patterson P. Effects of resistance training on muscular strength and funcational abilities of community-dwelling older adults. J Aging Phys Activ. 1995;238–250. | Does not focus on reducing the risk or rate of falls or fallers
Nikolaus T, Bach M. Preventing falls in community-dwelling frail older people using a home intervention team (HIT): results from the randomized Falls-HIT trial. J Am Geriatr Soc. 2003;51:300–305. | Population is not comparable to primary care
Nitz JC, Choy NL. The efficacy of a specific balance-strategy training programme for preventing falls among older people: a pilot randomised controlled trial. Age Ageing. 2004;33:52–58. | Not a randomized controlled trial
Nnodim JO, Strasburg D, Nabozny M, et al. Dynamic balance and stepping versus Tai Chi training to improve balance and stepping in at-risk older adults. J Am Geriatr Soc. 2006;54:1825–1831. | Does not focus on reducing the risk or rate of falls or fallers
Nowalk MP, Prendergast JM, Bayles CM, D’Amico FJ, Colvin GC. A randomized trial of exercise programs among older individuals living in two long-term care facilities: the FallsFREE program. J Am Geriatr Soc. 2001;49:859–865. | Not conducted in primary care or other setting with primary care-comparable population
O’Donnell S, Moher D, Thomas K, Hanley DA, Cranney A. Systematic review of the benefits and harms of calcitriol and alfacalcidol for fractures and falls. J Bone Mineral Metab. 2008;26:531–542. | Used only as source document
Pahor M, Blair SN, Espeland M, et al. Effects of a physical activity intervention on measures of physical performance: results of the Lifestyle Interventions and Independence for Elders Pilot (LIFE-P) study. J Gerontol A Biol Sci Med Sci. 2006;61:1157–1165. | Does not focus on reducing the risk or rate of falls or fallers
Pardessus V, Puisieux F, Di Pompeo C, Gaudefroy C, Thevenon A, Dewailly P. Benefits of home visits for falls and autonomy in the elderly: a randomized trial study. Am J Phys Med Rehabil. 2002;81:247–252. | Population is not comparable to primary care
Peel N, Cartwright C, Steinberg M. Monitoring slips, trips and falls in the older community: preliminary results. Health Promot J Aust. 1998;148–150. | Does not focus on reducing the risk or rate of falls or fallers
Peel N, Steinberg M, Williams G. Home safety assessment in the prevention of falls among older people. Aust N Z J Pub Health. 2000;24:536–539. | Not a randomized controlled trial
Peeters GM, de Vries OJ, Elders PJ, Pluijm SM, Bouter LM, Lips P. Prevention of fall incidents in patients with a high risk of falling: design of a randomised controlled trial with an economic evaluation of the effect of multidisciplinary transmural care. BMC Geriatr. 2007;7:15. | Provides no data not otherwise covered in other articles for this study
Pereira MA, Kriska AM, Day RD, Cauley JA, LaPorte RE, Kuller LH. A randomized walking trial in postmenopausal women: effects on physical activity and health 10 years later. Arch Intern Med. 1998;158:1695–1701. | Does not focus on reducing risk or rate of falls or fallers
Pereira MA. Ten year follow-up of a randomized exercise trial in post-menopausal women [PhD thesis]. Pittsburgh: University of Pittsburgh; 1996. | Does not focus on reducing the risk or rate of falls or fallers
Perry SD, Radtke A, McIlroy WE, Fernie GR, Maki BE. Efficacy and effectiveness of a balance-enhancing insole. J Gerontol A Biol Sci Med Sci. 2008;63:595–602. | Population-based or community, non-referral population
Peterson JF, Kuperman GJ, Shek C, Patel M, Avorn J, Bates DW. Guided prescription of psychotropic medications for geriatric inpatients. Arch Intern Med. 2005;165:802–807. | Not conducted in primary care or other setting with primary care-comparable population
Peterson JF, Rosenbaum BP, Waitman LR, et al. Physicians’ response to guided geriatric dosing: initial results from a randomized trial. Medinfo. 2007;12:2–40. | No relevant outcomes
Pfeifer M, Dobnig H, Begerow B, Suppan K. Effects of vitamin D and calcium supplementation on falls and parameters of muscle function: a prospective randomized, double-blind muliti-centre study. J Bone Mineral Res. 2004;19:S58. | Not a randomized controlled trial
Piirtola M, Era P. Force platform measurements as predictors of falls among older people: a review. Gerontology. 2006;52:1–16. | Not a randomized controlled trial
Pit SW, Byles JE, Henry DA, Holt L, Hansen V, Bowman DA. A Quality Use of Medicines program for general practitioners and older people: a cluster randomised controlled trial. Med J Aust. 2007;187:23–30. | Does not focus on reducing the risk or rate of falls or fallers
Protas EJ, Mitchell K, Williams A, Qureshy H, Caroline K, Lai EC. Gait and step training to reduce falls in Parkinson’s disease. NeuroRehabilitation. 2005;20:183–190. | Not feasible in primary care
Province MA, Hadley EC, Hornbrook MC, et al. The effects of exercise on falls in elderly patients: a preplanned meta-analysis of the FICSIT Trials. JAMA. 1995;273:1341–1347. | Provides no data not otherwise covered in other articles for this study
Ray WA, Taylor JA, Meador KG, et al. A randomized trial of a consultation service to reduce falls in nursing homes. JAMA. 1997;278:557–562. | Not conducted in primary care or other setting with primary care-comparable population
Reinsch S, MacRae P, Lachenbruch PA, Tobis JS. Attempts to prevent falls and injury: a prospective community study. Gerontologist. 1992;32:450–456. | Poor reporting
Resnick B. Testing the effect of the WALC intervention on exercise adherence in older adults. J Gerontol Nurs. 2002;28:40–49. | Not conducted in primary care or other setting with primary care-comparable population
Reuben DB, Frank JC, Hirsch SH, McGuigan KA, Maly RC. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc. 1999;47:269–276. | Does not focus on reducing the risk or rate of falls or fallers
Richardson DA, Steen N, Bond J, Bexton R, Kenny RA. Cardiac pacing reduces falls in cartoid sinus hypersensitivity. Age Ageing. 2000;29(Suppl 1):46. | Provides no data not otherwise covered in other articles for this study
Ringe JD, Farahmand P, Schacht E, Rozehnal A. Superiority of a combined treatment of alendronate and alfacalcidol compared to the combination of alendronate and plain vitamin D or alfacalcidol alone in established postmenopausal or male osteoporosis (AAC-Trial). Rheumatol Int. 2007;27:425–434. | Not a randomized controlled trial
Rizzo JA, Baker DI, McAvay G, Tinetti ME. The cost-effectiveness of a multifactorial targeted prevention program for falls among community elderly persons. Med Care. 1996;34:954–969. | Provides no data not otherwise covered in other articles for this study
Ro OC, Hjort PF. Interventional research in primary health care for the elderly. Scand J Prim Health Care. 1985;3:133–136. | Not a randomized controlled trial
Robertson MC, Campbell AJ, Gardner MM, Devlin N. Preventing injuries in older people by preventing falls: a meta-analysis of individual-level data. J Am Geriatr Soc. 2002;50:905–911. | Provides no data not otherwise covered in other articles for this study
Robertson MC, Devlin N, Scuffham P, Gardner MM, Buchner DM, Campbell AJ. Economic evaluation of a community based exercise programme to prevent falls. J Epidemiol Community Health. 2001;55:600–606. | Provides no data not otherwise covered in other articles for this study
Robertson MC, Gardner MM, Devlin N, McGee R, Campbell AJ. Effectiveness and economic evaluation of a nurse delivered home exercise programme to prevent falls, 2: controlled trial in multiple centres. BMJ. 2001;322:701–704. | Not a randomized controlled trial
Robertson MC. Development of a Falls Prevention Programme for Elderly People: Evaluation of Efficacy, Effectiveness, and Efficiency. Dunedin, New Zealand: University of Otago; 2001. | Provides no data not otherwise covered in other articles for this study
Robson E, Edwards J, Gallagher E, Baker D. Steady As You Go (SAYGO): a falls-prevention program for seniors living in the community. Can J Aging. 2003;22:207–216. | Poor reporting
Rockwood K, Stadnyk K, Carver D, et al. A clinimetric evaluation of specialized geriatric care for rural dwelling, frail older people. J Am Geriatr Soc. 2000;48:1080–1085. | Does not focus on reducing the risk or rate of falls or fallers
Rooks DS, Ransil BJ, Hayes WC. Self-paced exercise and neuromotor performance in community-dwelling older adults. J Aging Phys Activ. 1997;135–149. | Does not focus on reducing the risk or rate of falls or fallers
Rubenstein LZ, Alessi CA, Josephson KR, Trinidad HM, Harker JO, Pietruszka FM. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. 2007;55:166–174. | Not a randomized controlled trial
Ryan JW, Spellbring AM. Implementing strategies to decrease risk of falls in older women. J Gerontol Nurs. 1996;22:25–31. | Poor reporting
Sakamoto K, Nakamura T, Hagino H, et al. Effects of unipedal standing balance exercise on the prevention of falls and hip fracture among clinically defined high-risk elderly individuals: a randomized controlled trial. J Orthopaed Sci. 2006;11:467–472. | Population is not comparable to primary care
Salkeld G, Cumming RG, O’Neill E, Thomas M, Szonyi G, Westbury C. The cost effectiveness of a home hazard reduction program to reduce falls among older persons. Aust N Z J Pub Health. 2000;24:265–271. | Population is not comparable to primary care
Santana-Sosa E, Barriopedro MI, Lopez-Mojares LM, Perez M, Lucia A. Exercise training is beneficial for Alzheimer’s patients. Int J Sports Med. 2008;29:845–850. | Not conducted in primary care or other setting with primary care-comparable population
Sato T, Ebihara S, Kudo H, Fujii M, Sasaki H, Butler JP. Toe clearance rehabilitative slipper for gait disorder in the elderly. Geriatr Gerontol Int. 2007;7:310–311. | Does not focus on reducing the risk or rate of falls or fallers
Sato Y, Iwamoto J, Kanoko T, Satoh K. Low-dose vitamin D prevents muscular atrophy and reduces falls and hip fractures in women after stroke: a randomized controlled trial. Cerebrovasc Dis. 2005;20:187–192. | Not conducted in primary care or other setting with primary care-comparable population
Sato Y, Manabe S, Kuno H, Oizumi K. Amelioration of osteopenia and hypovitaminosis D by 1alpha-hydroxyvitamin D3 in elderly patients with Parkinson’s disease. J Neurol Neurosurg Psychiatry. 1999;66:64–68. | Does not focus on reducing the risk or rate of falls or fallers
Schnelle JF, Alessi CA, Simmons SF, Al-Samarrai NR, Beck JC, Ouslander JG. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. J Am Geriatr Soc. 2002;50:1476–1483. | Not conducted in primary care or other setting with primary care-comparable population
Schnelle JF, Kapur K, Alessi C, et al. Does an exercise and incontinence intervention save healthcare costs in a nursing home population? J Am Geriatr Soc. 2003;51:161–168. | Not conducted in primary care or other setting with primary care-comparable population
Schoenfelder DP. A fall prevention program for elderly individuals: exercise in long-term care settings. J Gerontol Nurs. 2000;26:43–51. | Population is not comparable to primary care
Schwarting AE, Listerman LR, Harrison AL. The effectiveness of an intervention plan in decreasing fear of falling. J Geriatri Phys Ther. 2002;25:39. | Does not focus on reducing the risk or rate of falls or fallers
Scott IU. Falls and health status in elderly women following first eye cataract surgery: a randomized controlled trial. Evid Based Ophthalmol. 2005;6:119–120. | No relevant outcomes
Shapiro A, Taylor M. Effects of a community-based early intervention program on the subjective well-being, institutionalization, and mortality of low-income elders. Gerontologist. 2002;42:334–341. | Does not focus on reducing the risk or rate of falls or fallers
Shaw FE, Bond J, Richardson DA, et al. Multifactorial intervention after a fall in older people with cognitive impairment and dementia presenting to the accident and emergency department: randomised controlled trial. BMJ. 2003;326:73. | Population is not comparable to primary care
Shaw FE. Can multidisciplinary intervention prevent falls in patients with cognitive impairment and dementia attending a casualty department? Age Ageing. 2000;29(Suppl 1):47. | Population is not comparable to primary care
Shaw FE. Physiotherapy intervention for cognitively impaired elderly fallers attending casualty. Oxford: National Research Register; 2003. | Population is not comparable to primary care
Shekelle PG, Maglione M, Chang JT, et al. Falls Prevention Interventions in the Medicare Population. Baltimore, MD: Centers for Medicare and Medicaid Services; 2004. | Used only as source document
Sherrington C, Lord SR, Finch CF. Physical activity interventions to prevent falls among older people: update of the evidence. J Sci Med Sport. 2004;7:43–51. | Used only as source document
Shigematsu R, Chang M, Yabushita N, et al. Dance-based aerobic exercise may improve indices of falling risk in older women. Age Ageing. 2002;31:261–266. | Not a randomized controlled trial
Shigematsu R, Okura T, Nakagaichi M, et al. Square-stepping exercise and fall risk factors in older adults: a single-blind, randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2008;63:76–82. | Not a randomized controlled trial
Shigematsu R, Okura T, Sakai T, Rantanen T. Square-stepping exercise versus strength and balance training for fall risk factors. Aging Clin Exp Res. 2008;20:19–24. | Not a randomized controlled trial
Silverman M, Musa D, Martin DC, Lave JR, Adams J, Ricci EM. Evaluation of outpatient geriatric assessment: a randomized multi-site trial. J Am Geriatr Soc. 1995;43:733–740. | Does not focus on reducing the risk or rate of falls or fallers
Sjösten N, Vaapio S, Kivelä SL. The effects of fall prevention trials on depressive symptoms and fear of falling among the aged: a systematic review. Aging Ment Health. 2008;12:30–46. | Used only as source document
Sjösten NM, Salonoja M, Piirtola M, et al. A multifactorial fall prevention programme in home-dwelling elderly people: a randomized-controlled trial. Public Health. 2007;121:308–318. | No relevant outcomes
Sjösten NM, Salonoja M, Piirtola M, et al. A multifactorial fall prevention programme in the community-dwelling aged: predictors of adherence. Eur J Public Health. 2007;17:464–470. | No relevant outcomes
Skelton D, Dinan S, Campbell M, Rutherford O. Tailored group exercise (Falls Management Exercise—FaME) reduces falls in community-dwelling older frequent fallers (an RCT). Age Ageing. 2005;34:636–639. | Not a randomized controlled trial
Skelton D, Dinan S, Campbell M, Rutherford O. FaME (Falls Management Exercise): an RCT on the effects of a 9-month group exercise programme in frequently falling community dwelling women aged 65 and over. J Aging Phys Activ. 2004;12:457–458. | Provides no data not otherwise covered in other articles for this study
Skelton D, Dinan S. Exercise for falls management: rationale for an exercise programme to reduce postural instability. Physio Theory Pract. 1999;15:105–120. | Provides no data not otherwise covered in other articles for this study
Skelton D, Stranzinger K, Dinan S, Rutherford O. BMD improvements following FaME (Falls Management Exercise) in frequently falling women age 65 and over: an RCT. J Aging Phys Activ. 2008;16:S89–S90. | No relevant outcomes
Smith H, Anderson F, Raphael H, Maslin P, Crozier S, Cooper C. Effect of annual intramuscular vitamin D on fracture risk in elderly men and women—a population-based, randomized, double-blind, placebo-controlled trial. Rheumatology. 2007;46:1852–1857. | Does not focus on reducing the risk or rate of falls or fallers
Smith L. Falls prevention using ‘best practice outcomes’. Can Nurs Home. 2004;15:13–19. | Not conducted in primary care or other setting with primary care-comparable population
Sorensen KH, Sivertsen J. Follow-up three years after intervention to relieve unmet medical and social needs of old people. Compr Gerontol [B]. 1988;2:85–91. | Does not focus on reducing the risk or rate of falls or fallers
Spink MJ, Menz HB, Lord SR. Efficacy of a multifaceted podiatry intervention to improve balance and prevent falls in older people: study protocol for a randomised trial. BMC Geriatrics. 2008;8:30. | No relevant outcomes
Steinberg M, Cartwright C, Peel N, Williams G. A sustainable programme to prevent falls and near falls in community dwelling older people: results of a randomised trial. J Epidemiol Community Health. 2000;54:227–232. | Not a randomized controlled trial
Steultjens E, Clemson L. A preventative home safety programme for community-dwelling older people with low vision reduced falls and was more cost-effective than an exercise programme: commentary. Aust Occup Ther J. 2006;53:243–244. | Provides no data not otherwise covered in other articles for this study
Steultjens EM, Dekker J, Bouter LM, Jellema S, Bakker EB, van den Ende CH. Occupational therapy for community dwelling elderly people: a systematic review. Age Ageing. 2004;33:453–460. | Used only as source document
Stevens M, Holman CD, Bennett N. Preventing falls in older people: impact of an intervention to reduce environmental hazards in the home. J Am Geriatr Soc. 2001;49:1442–1447. | Provides no data not otherwise covered in other articles for this study
Stevens VJ, Hornbrook MC, Wingfield DJ, Hollis JF, Greenlick MR, Ory MG. Design and implementation of a falls prevention intervention for community-dwelling older persons. Behav Health Ageing. 1991;2:57–73. | No relevant outcomes
Strever T. Trauma library in review. [Commentary on] A meta-analysis of fall prevention programs for the elderly. J Trauma Nurs. 2002;9:84. | Provides no data not otherwise covered in other articles for this study
Stuck AE, Aronow HU, Steiner A, et al. A trial of annual in-home comprehensive geriatric assessments for elderly people living in the community. N Engl J Med. 1995;333:1184–1189. | Does not focus on reducing the risk or rate of falls or fallers
Stuck AE, Minder CE, Peter-Wuest I, et al. A randomized trial of in-home visits for disability prevention in community-dwelling older people at low and high risk for nursing home admission. Arch Intern Med. 2000;160:977–986. | Does not focus on reducing the risk or rate of falls or fallers
Suzuki T, Kim H, Yoshida H, Ishizaki T. Randomized controlled trial of exercise intervention for the prevention of falls in community-dwelling elderly Japanese women. J Bone Mineral Metabol. 2004;22:602–611. | High or differential attrition
Swanenburg J, de Bruin ED, Stauffacher M, Mulder T, Uebelhart D. Effects of exercise and nutrition on postural balance and risk of falling in elderly people with decreased bone mineral density: randomized controlled trial pilot study. Clin Rehabil. 2007;21:523–534. | Comparative effectiveness study design
Tennstedt S, Howland J, Lachman M, Peterson E, Kasten L, Jette A. A randomized, controlled trial of a group intervention to reduce fear of falling and associated activity restriction in older adults. J Gerontol B Psychol Sci Soc Sci. 1998;53:384–392. | Does not focus on reducing the risk or rate of falls or fallers
Tinetti ME, McAvay G, Claus E. Does multiple risk factor reduction explain the reduction in fall rate in the Yale FICSIT Trial? Am J Epidemiol. 1996;144:389–399. | Does not focus on reducing the risk or rate of falls or fallers
Tinetti ME, Mendes de Leon CF, Doucette JT, Baker DI. Fear of falling and fall-related efficacy in relationship to functioning among community-living elders. J Gerontol. 1994;49:M140–M147. | Not a randomized controlled trial
Tinetti ME. Prevention of falls and fall injuries in elderly persons: a research agenda. Prev Med. 1994;23:756–762. | Not a randomized controlled trial
Tobis J, Reinsch S, MacRae P, Lachenbruch T. Experimental intervention at senior centres for the prevention of falls. J Am Geriatr Soc. 1990;38:A28. | Provides no data not otherwise covered in other articles for this study
Tulloch AJ, Moore V. A randomized controlled trial of geriatric screening and surveillance in general practice. J R Coll Gen Pract. 1979;29:733–740. | Does not focus on reducing the risk or rate of falls or fallers
Vaillant J, Vuillerme N, Martigne P, et al. Balance, aging, and osteoporosis: effects of cognitive exercises combined with physiotherapy. Joint Bone Spine. 2006;73:414–418. | Does not focus on reducing the risk or rate of falls or fallers
van der Velde N, Meerding WJ, Looman CW, Pols HA, van der Cammen TJ. Cost effectiveness of withdrawal of fall-risk-increasing drugs in geriatric outpatients. Drugs Aging. 2008;25:521–529. | Editorial, letter, non-systematic reviews, opinions, clinical controlled trial, case-control, or cohort
van Haastregt JC, van Rossum E, Diederiks JP, de Witte LP, Voorhoeve PM, Crebolder HF. Process-evaluation of a home visit programme to prevent falls and mobility impairments among elderly people at risk. Patient Educ Couns. 2002;47:301–309. | Not a randomized controlled trial
Vass M, Avlund K, Kvist K, Hendriksen C, Andersen CK, Keiding N. Structured home visits to older people: are they only of benefit for women? A randomised controlled trial. Scand J Prim Health Care. 2004;22:106–111. | Does not focus on reducing the risk or rate of falls or fallers
Vassallo M, Vignaraja R, Sharma JC, Briggs RS, Allen SC. Can intervention prevent falls and injury in geriatric wards? Hospital Injury Prevention (HIP) study. Age Ageing. 2001;30(Suppl 2):15. | Not conducted in primary care or other setting with primary care-comparable population
Verfaillie DF, Nichols JF, Turkel E, Hovell MF. Effects of resistance, balance, and gait training on reduction of risk factors leading to falls in elders. J Aging Phys Activ. 1997;213–228. | Does not focus on reducing the risk or rate of falls or fallers
Vetter NJ, Jones DA, Victor CR. Effect of health visitors working with elderly patients in general practice: a randomised controlled trial. Br Med J (Clin Res Ed). 1984;288:369–372. | Does not focus on reducing the risk or rate of falls or fallers
Wallace JI, Buchner DM, Grothaus L, et al. Implementation and effectiveness of a community-based health promotion program for older adults. J Gerontol A Biol Sci Med Sci. 1998;53:M301–M306. | Does not focus on reducing the risk or rate of falls or fallers
Ward CD, Turpin G, Dewey ME, et al. Education for people with progressive neurological conditions can have negative effects: evidence from a randomized controlled trial. Clin Rehabil. 2004;18:717–725. | Population is not comparable to primary care
Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23:399–404. | Other quality issue
Weerdesteyn V, Rijken H, Geurts AC, Smits-Engelsman BC, Mulder T, Duysens J. A five-week exercise program can reduce falls and improve obstacle avoidance in the elderly. Gerontology. 2006;52:131–141. | Problems with baseline comparability between groups
White D. Vitamin D prevents falls in the elderly. Evid Based Pract. 2005;8:1–2. | Article covered by an included systematic review
Widen HL, von Koch L, Kostulas V, et al. A randomized controlled trial of rehabilitation at home after stroke in southwest Stockholm. Stroke. 1998;29:591–597. | Population is not comparable to primary care
Wilkins S, Jung B, Wishart L, Edwards M, Norton SG. The effectiveness of community-based occupational therapy education and functional training programs for older adults: a critical literature review. Can J Occup Ther. 2003;70(4):214–225. | Used only as source document
Williams ME, Williams TF, Zimmer JG, Hall WJ, Podgorski CA. How does the team approach to outpatient geriatric evaluation compare with traditional care: a report of a randomized controlled trial. J Am Geriatr Soc. 1987;35:1071–1078. | Does not focus on reducing the risk or rate of falls or fallers
Wilson P, Rodgers B. Research on falls prevention and physical activity in older adults and a notice of a new Web-based quality system by the Agency for Healthcare Research and Quality. Home Healthcare Nurs. 2006;24:632–633. | Not a randomized controlled trial
Wolf B, Feys H, De Weerdt W, et al. Effect of a physical therapeutic intervention for balance problems in the elderly: a single-blind, randomized, controlled multicentre trial. Clin Rehabil. 2001;15:624–636. | Does not focus on reducing the risk or rate of falls or fallers
Wolf SL, Barnhart HX, Ellison GL, Coogler CE. The effect of Tai Chi Quan and computerized balance training on postural stability in older subjects. Phys Ther. 1997;77:371–381. | No relevant outcomes
Wolf SL, Barnhart HX, Kutner NG, et al. Reducing frailty and falls in older persons: an investigation of Tai Chi and computerized balance training. J Am Geriatr Soc. 2003;51:1794–1803. | Provides no data not otherwise covered in other articles for this study
Wolf SL, Kutner NG, Green RC, McNeely E. The Atlanta FICSIT study: two exercise interventions to reduce frailty in elders. J Am Geriatr Soc. 1993;41:329–332. | Provides no data not otherwise covered in other articles for this study
Wolf SL, Sattin RW, Kutner M, O’Grady M, Greenspan AI, Gregor RJ. Intense Tai Chi exercise training and fall occurrences in older, transitionally frail adults: a randomized, controlled trial. J Am Geriatr Soc. 2003;51:1693–1701. | Not conducted in primary care or other setting with primary care-comparable population
Wolf SL, Sattin RW, O’Grady M, et al. A study design to investigate the effect of intense Tai Chi in reducing falls among older adults transitioning to frailty. Control Clin Trials. 2001;22:689–704. | Not conducted in primary care or other setting with primary care-comparable population
Wolfson L, Whipple R, Derby C, et al. Balance and strength training in older adults: intervention gains and Tai Chi maintenance. J Am Geriatr Soc. 1996;44:498–506. | Does not focus on reducing the risk or rate of falls or fallers
Woo J, Hong A, Lau E, Lynn H. A randomised controlled trial of Tai Chi and resistance exercise on bone health, muscle strength and balance in community-living elderly people. Age Ageing. 2007;36:262–268. | Does not focus on reducing the risk or rate of falls or fallers
Wyman JF, Croghan CF, Nachreiner NM, et al. Effectiveness of education and individualized counseling in reducing environmental hazards in the homes of community-dwelling older women. J Am Geriatr Soc. 2007;55:1548–1556. | Does not focus on reducing the risk or rate of falls or fallers
Yardley L, Nyman SR. Internet provision of tailored advice on falls prevention activities for older people: a randomized controlled evaluation. Health Promot Int. 2007;22:122–128. | No relevant outcomes
Yates SM, Dunnagan TA. Evaluating the effectiveness of a home-based fall risk reduction program for rural community-dwelling older adults. J Gerontol A Biol Sci Med Sci. 2001;56:M226–M230. | Does not focus on reducing the risk or rate of falls or fallers
Young CM, Weeks BK, Beck BR. Simple, novel physical activity maintains proximal femur bone mineral density, and improves muscle strength and balance in sedentary, postmenopausal Caucasian women. Osteoporos Int. 2007;18:1379–1387. | No relevant outcomes
Zhang JG, Ishikawa-Takata K, Yamazaki H, Morita T, Ohta T. The effects of Tai Chi Chuan on physiological function and fear of falling in the less robust elderly: an intervention study for preventing falls. Arch Gerontol Geriatr. 2006;42:107–116. | Does not focus on reducing the risk or rate of falls or fallers
Zimmer JG, Groth-Juncker A, McCusker J. A randomized controlled study of a home health care team. Am J Public Health. 1985;75:134–141. | Does not focus on reducing the risk or rate of falls or fallers