# Search

Appendix B Figure 1 Search Results and Article Flow

Appendix B Figure 1 is a flow chart that summarizes the search and selection of articles. There were 2,944 citations identified by searching databases and Web sites. Of these, 2,346 citations were excluded after abstract review. The remaining 598 full-text articles were assessed for eligibility by key question. Of the 257 articles reviewed for key question 1, 39 articles representing 36 different studies were deemed eligible for inclusion. Of these 36 studies, 13 were included in the qualitative synthesis for multifactorial assessment and management, 12 were included in the qualitative synthesis for single clinical treatment, 1 was included in the qualitative synthesis for clinical education/behavioral counseling, 1 was included in the qualitative synthesis for home hazard modification, and 10 were included in the qualitative synthesis for exercise/physical therapy (some studies were included in more than one area). Of the 350 articles reviewed for key questions 2 and 4, 51 articles representing 47 different studies were deemed eligible for inclusion. Of these 47 studies, 14 were included in the qualitative synthesis for multifactorial assessment and management, 16 were included in the qualitative synthesis for single clinical treatment, 1 was included in the qualitative synthesis for clinical education/behavioral counseling, 3 were included in the qualitative synthesis for home hazard modification, and 17 were included in the qualitative synthesis for exercise/physical therapy (some studies were included in more than one area). Of the 84 articles reviewed for key question 3, 49 articles representing 48 different studies and 1 meta-analysis were deemed eligible for inclusion.

Appendix B Table 1 Search Strategies

Systematic Reviews
Databases: CDSR, DARE, HTA, NICE, PubMed 1991 to October 2007; 1. “Accidental Falls”[MeSH]; 2. “Accidental Falls”[MeSH] Limits: Aged: 65+ years, 80 and over: 80+ years; 3. geriatrics[mesh] OR geriatric[tw] OR older*[tiab] OR elder*[tiab] OR geriatric*[tiab] OR senior*[tiab]; 4. #1 AND #3; 5. fall[ti] OR falls[ti] OR falling[ti]; 6. older*[tiab] OR elder*[tiab] OR geriatric*[tiab] OR senior*[tiab] OR aged[tiab]; 7. #5 AND #6; 8. #7 AND (in process[sb] OR publisher[sb]); 9. #2 OR #4 OR #8; 10. #9 AND systematic[sb]; 11. #9 AND systematic[sb] Limits: English; 12. #11 AND jsubsetaim; 13. #11 AND Limits: added to PubMed in the last 1 year
Databases: MEDLINE, AHRQ 1992 to September 2008; 1. “Cataract Extraction/adverse effects”[Majr:NoExp] AND systematic[sb] Limits: Publication Date from 1994 to 2008, English; 2. “Estrogen Replacement Therapy/adverse effects”[Majr:NoExp] OR “Estrogen Replacement Therapy/mortality”[Majr:NoExp] OR “Hormone Replacement Therapy/adverse effects”[Majr:NoExp] OR “Hormone Replacement Therapy/mortality”[Majr:NoExp]) AND systematic[sb] Limits: Publication Date from 2002 to 2008, English; 3. “Vitamin D”[Mesh:noexp] AND systematic[sb] AND (“adverse effects “[Subheading:NoExp] OR adverse*[tiab] OR harm*[tiab]) Limits: Publication Date from 2002 to 2008, English; 4. “vitamin d”[ti] OR “hormone replacement”[ti] OR “cataract surgery”[ti]) AND (in process[sb] OR publisher[sb] OR pubmednotmedline[sb]) AND systematic[sb] Limits: English; 5. #1 OR #2 OR #3 OR #4
Interventions to Prevent Falls (KQ 2), Fall-Related Injuries, Mortality, Disability, and Improve Quality of Life (KQ 1) and Identification of High-Risk Older Adults (KQ 4)
Databases: MEDLINE, CCRCT, CINAHL 2002 to February 2009; 1. Accidental Falls/; 2. (falls or faller or fallers).ti,ab.; 3. (fall or falling).ti.; 4. 1 or 2 or 3; 5. limit 4 to (“all aged (65 and over)” or “aged (80 and over)”); 6. aged/ or “aged, 80 and over”/ or frail elderly/; 7. Geriatric Assessment/; 8. Geriatrics/; 9. Health Services for the Aged/; 10. geriatric$.ti,ab.; 11. older.ti,ab.; 12. senior$.ti,ab.; 13. elder$.ti,ab.; 14. aged.ti,ab.; 15. 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14; 16. 4 and 15; 17. 5 or 16; 18. limit 17 to (controlled clinical trial or meta analysis or randomized controlled trial or clinical trial); 19. controlled clinical trial/ or randomized controlled trial/ or clinical trial/; 20. meta-analysis/; 21. (control$ adj3 trial$).ti,ab.; 22. random$.ti,ab.; 23. clinical trial$.ti,ab.; 24. 19 or 20 or 21 or 22 or 23; 25. 24 and 17; 26. 18 or 25; 27. limit 26 to english language; 28. limit 27 to yr=“2002 – 2009”; 29. from 28 keep 1–500
Harms of Clinical Assessment, Home Hazard Modification, Clinical Education/Behavioral Counseling, and Exercise/Physical Therapy Interventions to Prevent Falls (KQ 3)
Databases: MEDLINE, CINAHL 1992 to February 2009; 1. Accidental Falls/; 2. (falls or faller or fallers).ti,ab.; 3. (fall or falling).ti.; 4. 1 or 2 or 3; 5. Geriatric Assessment/; 6. (multifactorial or multifaceted or multidimensional).ti,ab. and (assessment$ or intervention$).ti,ab,hw.; 7. geriatric assessment$.ti,ab.; 8. Patient Education as Topic/; 9. Patient education.ti,ab.; 10. Health Education/; 11. Health Education.ti,ab.; 12. education$ intervention$.ti,ab.; 13. Counseling/; 14. Directive Counseling/; 15. counsel$.ti,ab.; 16. Cognitive Therapy/; 17. House Calls/; 18. home visit$.ti,ab.; 19. ((home hazard$ or home safety) and (modification$ or program$)).ti,ab.; 20. hazard reduction.ti,ab. and home.ti,ab,hw.; 21. Exercise/; 22. Exercise Therapy/; 23. exercise therapy.ti,ab.; 24. Physical Therapy.ti,ab.; 25. Physical Therapy Modalities/; 26. Exercise Movement Techniques/; 27. exercise training.ti,ab.; 28. tai chi.ti,ab.; 29. Tai Ji/; 30. gait training.ti,ab.; 31. balance training.ti,ab.; 32. mobility training.ti,ab.; 33. muscle strengthening.ti,ab.; 34. recurrent faller$.ti,ab.; 35. recurrent falls.ti,ab.; 36. Accidental Falls/pc; 37. or/5–36; 38. adverse effects.fs.; 39. adverse$.ti,ab.; 40. harm$.ti,ab.; 41. psychology.fs.; 42. “fear of falling”.ti,ab.; 43. falls efficacy.ti,ab.; 44. or/38–43; 45. 4 and 37 and 44; 46. or/21–33; 47. injuries.fs.; 48. injur$.ti,ab.; 49. 47 or 48; 50. 4 and 46 and 49; 51. 45 or 50; 52. limit 51 to “all child (0 to 18 years)”; 53. limit 52 to “all aged (65 and over)”; 54. 52 not 53; 55. 51 not 54; 56. limit 55 to english language; 57. limit 56 to yr=“1992 – 2009”; 58. remove duplicates from 57; 59. from 58 keep 1–500
Harms of Clinical Management (Vision Correction, Hip Protectors, and Liquid Supplement) Interventions to Prevent Falls (KQ 3)
Databases: MEDLINE, CINAHL 1992 to February 2009; 1. Eyeglasses/; 2. spectacles.ti,ab.; 3. eyeglasses.ti,ab.; 4. glasses.ti,ab. and (vision or visual or eye$).ti,ab,hw.; 5. 1 or 2 or 3 or 4; 6. Dietary Supplements/; 7. Dietary Proteins/; 8. 6 and 7; 9. (protein adj2 supplement$).ti,ab.; 10. (ensure plus or ensure).rn.; 11. 8 or 9 or 10; 12. Protective Clothing/; 13. Protective Devices/; 14. Orthotic Devices/; 15. 12 or 13 or 14; 16. hip fractures/ or femoral neck fractures/; 17. (fracture$ adj2 (hip or femur$ or femor$)).ti,ab.; 18. 16 or 17; 19. 15 and 18; 20. (hip adj (protector$ or pad$)).ti,ab.; 21. 19 or 20; 22. 5 or 11 or 21; 23. adverse effects.fs.; 24. adverse$.ti,ab.; 25. harm$.ti,ab.; 26. 23 or 24 or 25; 27. 22 and 26; 28. aged/ or “aged, 80 and over”/ or frail elderly/ or middle aged/; 29. geriatric$.ti,ab.; 30. older.ti,ab.; 31. senior$.ti,ab.; 32. elder$.ti,ab.; 33. aged.ti,ab.; 34. 28 or 29 or 30 or 31 or 32 or 33; 35. 27 and 34; 36. limit 35 to english language; 37. limit 36 to yr=“1992 – 2009”; 38. remove duplicates from 37

Appendix B Table 2 Exclusion Criteria for Key Questions

Exclusion Criteria Applied to All Key Questions
Population:; - Conducted in population that is not comparable with primary care (e.g., persons in hospitals, nursing or care homes, rehabilitation centers, or other long-term care facilities); - Conducted in population that does not have an average age of ≥65 years; Setting:; - Intervention not conducted in primary care or other setting with primary care-comparable population (e.g., hospital, nursing or care home, rehabilitation center, other long-term care facility); - Intervention not conducted in countries culturally comparable with the United States as evidenced by a United Nations Human Development Index value of <0.900; Design:; - Editorials, letters, nonsystematic reviews, opinions, comparative effectiveness; Quality:; - Does not meet quality criteria; Other:; - Fall prevention not primary or secondary focus; - Precedes search period; - Article already covered by an included systematic review; - Provides no data not otherwise covered in other articles; - Systematic review used as source document only; - Language other than English
Additional Exclusion Criteria Specific to Each Key Question
Key Question 1. Is there direct evidence that primary care interventions reduce fall-related injury, improve quality of life, reduce disability, or reduce mortality when used alone or in combination to reduce falls in community-dwelling older adults?; 1a Do these interventions reduce injury, improve quality of life, reduce disability, or reduce mortality in older adults specifically identified as high risk for falls?; Intervention:; - Community interventions not generally accessible (e.g., senior residence program); - Social marketing (e.g., media campaign); - Policy (e.g., local and State public or health policy); - Institutional methods (e.g., use of restraints); Design:; - Clinical controlled trial, case-control, cohort; No relevant outcomes:; - Fall-related injuries other than fractures; - Quality of life measures other than SF-12, SF-36, and EuroQOL; - Disability measures other than activities of daily life and instrumental activities of daily life
Key Question 2. Do primary care interventions used alone or in combination in community-dwelling older adults reduce risk for or rate of falls/fallers?; 2a Do these interventions reduce incidence of falls in older adults specifically identified as high risk for falls?; 2b Are there positive outcomes other than reduced falls, and related morbidity and mortality, that result from primary care falls interventions?; Intervention:; - Community interventions not generally accessible (e.g., senior residence program); - Social marketing (e.g., media campaign); - Policy (e.g., local and State public or health policy); - Institutional methods (e.g., use of restraints); Design:; - Clinical controlled trial, case-control, cohort; No relevant outcomes:; - Positive outcome measures other than falls: Falls Efficacy Scale, Performance-Oriented Mobility Assessment, Timed Get Up & Go Test, 6-meter timed walk, Functional Reach Test, and Berg Balance Scale
Key Question 3. What are the adverse effects associated with interventions to reduce risk for or rate of falls/fallers? No relevant outcomes:; - Harms of interventions that do not have sufficient evidence of being effective or ineffective

Appendix B Table 3 Quality Rating Criteria

Design | USPSTF Quality Rating Criteria | NICE Methodology Checklists | QUADAS Tool
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - Study addresses an appropriate and clearly focused question; - Description of the methodology used is included; - Literature search is sufficiently rigorous to identify all relevant studies; - Study quality is assessed and taken into account; - Enough similarities between selected studies to make combining reasonable | Not applicable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - Study addresses an appropriate and clearly focused question; - Cases and controls are taken from comparable populations; - Same exclusion criteria are used for both cases and controls; - Percentage of each group (cases and controls) participating in study is noted; - Comparison made between participants and nonparticipants to establish similarities or differences; - Cases are clearly defined and differentiated from controls; - It is clearly established that controls are noncases; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid, and reliable way; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided | Not applicable
Randomized controlled trials | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Assignment of subjects to treatment groups is randomized; - Adequate concealment method is used; - Subjects and investigators are kept blind about treatment allocation; - Treatment and control groups are similar at start of the trial; - Only difference between groups is treatment under investigation; - All relevant outcomes are measured in a standard, valid, and reliable way; - Percentage of the individuals or clusters recruited into each treatment arm that dropped out before completion is reported; - All subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - When the study is carried out at more than one site, results are comparable for all sites | Not applicable
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - Study indicates how many people were asked to take part and did so, in each of the groups being studied; - Likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - Percentage of individuals or clusters recruited into each arm that dropped out before the completion is reported; - Comparison is made between full participants and those lost to follow-up, by exposure status; - Outcomes are clearly defined; - Assessment of outcome is blind to exposure status; - Where blinding is not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - Measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided? | Not applicable
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - Nature of test being studied is clearly specified; - Test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - Test and gold standard are measured independently (blind) of each other; - Test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - Pre-diagnosis is made and reported | - Spectrum of patients are representative of patients who will receive the test in practice; - Selection criteria are clearly described; - Reference standard is likely to correctly classify target condition; - Time period between reference standard and index test is short enough to be reasonably sure that target condition did not change between the two tests; - Whole sample or a random selection receives verification using a reference standard of diagnosis; - Patients receive the same reference standard regardless of index test result; - Reference standard is independent of index test; - Execution of index test and reference standard are described in sufficient detail to permit replication; - Index test results are interpreted without knowledge of reference standard results; - Reference standard results are interpreted without knowledge of index test results; - Same clinical data is available when test results are interpreted as would be available when test is used in practice; - Uninterpretable/intermediate test results are reported; - Study withdrawals are explained