# Terminology and Abbreviations

Balance: Stability produced by even distribution of weight on each side of the vertical axis.
Behavioral counseling: Activities delivered by primary care clinicians and related health care staff to assist patients in adopting, changing, or maintaining behaviors proven to affect health outcomes and health status.
Multifactorial assessment and management: Detailed medical examination and multifactor assessment of fall-related or generic problems or professional assessment by means of a scoring method with or without enforced protocol for acting upon the results. These include multifactorial risk assessment for falls, comprehensive geriatric assessment, or two or more of the following screenings specifically for falls risk: vision, gait, mobility, strength, medication review, cognitive impairment, or orthostatic hypotension. These interventions were stratified as:
  1. Comprehensive interventions: trials that provide multifactorial treatments based on the assessment results;
  2. Noncomprehensive interventions: trials that provided only referral, based on assessment results, limited intervention (e.g., exercise), or knowledge.
Clinical education: Activities delivered by primary care clinicians and related health care staff (e.g., health educator, social worker, nursing staff) to assist patients in adopting, changing, or maintaining behaviors related to fall risk, including exercise, fall risk reduction, and home hazard checklists. Education/counseling is delivered to individuals or small groups and does not primarily involve group-level interventions outside the primary care setting or more than 8 group sessions.
Single clinical treatment: Treatment of a single fall-related risk factor, including vision correction, medication optimization/adjustment, assistive device prescription, pharmacological/nutritional interventions, treatment for orthostatic hypotension, urinary incontinence, and hip protectors.
Fall: An unexpected event in which the participant comes to rest on the ground, floor, or lower level.
Falls efficacy: A measure of fear of falling based on the operational definition of fear as “low perceived self-efficacy or confidence at avoiding falls.”
Gait: A manner of walking or moving on foot.
Home hazard modification: Includes home visits to identify and remove potential fall hazards, adding grab bars and handrails, and modifying the environment to improve mobility and safety.
Intervention: The act, fact, or method of interfering with the outcome or course, especially of a condition or process (as to prevent harm or improve functioning).
Intensity: A categorization of interventions by number of contact hours. High intensity is >75 hours, moderate intensity is 26–75 hours, low intensity is 10–26 hours, and very low intensity is 0–9 hours.
Multifactorial: Having, involving, or produced by a variety of elements or causes.
Exercise: Organized program for individuals or small groups that is part of a health care setting or widely available for referral in most communities; includes general physical activity, mobility/gait training, muscle strengthening, balance training, or training for recurrent fallers.
Primary care feasible: Conducted in a primary care research setting or judged to be feasible in “usual” primary care. Delivery usually involves primary care physicians, other physicians, nurses, nurse practitioners, physician assistants, or related clinical staff (e.g., health educators, other counselors) or is seen as connected to the health care system by the participant.
Primary care referable: Conducted as part of a health care setting or widely available for referral in most communities. Delivery is usually through community groups that are nationally available or through other health professionals/clinical staff (e.g., occupational therapists conducting home hazard modifications or physical therapists conducting mobility/gait training).