# Appendixes

Appendix A Terminology and Abbreviations

Appendix B Search

Appendix C Evidence Tables (KQs 1, 2, 4)

Appendix D Evidence Tables (KQ3)

Appendix E Role of Falls History in Identifying High-Risk Adults

Appendix F Meta-Analysis

Appendix G Trials

Appendix H Risk Categories and Other Outcome Measures