# References

1 Landis SH, Murray T, Bolden S, Wingo PA. Cancer statistics, 1999. CA Cancer J Clin. 1999;49:8-31. [pmid: 10200775]. [pmcid: 238334].
2 Fletcher SW, Black W, Harris R, Rimer BK, Shapiro S Report of the International Workshop on Screening for Breast Cancer J Natl Cancer Inst1993 85 1644 1656 8105098
3 Early Breast Cancer Trialists' Collaborative Group. Systemic treatment of early breast cancer by hormonal, cytotoxic, or immune therapy. 133 randomised trials involving 31,000 recurrences and 24,000 deaths among 75,000 women. Lancet. 1992;339:1-15. [pmid: 1345950].
4 Fisher D, Redmond C New perspective on cancer of the contralateral breast: a marker for assessing tamoxifen as a preventive agent J Natl Cancer Inst 1991 83 1278 1280
5 Fisher B, Costantino JP, Wickerham DL, et al Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study J Natl Cancer Inst1998 90 1371 1388 9747868
6 Powles T, Eeles R, Ashley S, et al. Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998;352:98-101. [pmid: 9672274].
7 Veronesi U, Maisonneuve P, Costa A, et al. Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Italian Tamoxifen Prevention Study. Lancet. 1998;352:93-97. [pmid: 9672273].
8 Ries LAG, Eisner MP, Kosary CL, et al. SEER Cancer Statistics Review, 1973-1997. Bethesda, MD: National Cancer Institute; 2000.
9 Blackman DK, Bennett EM, Miller DS. Trends in Self-Reported Use of Mammograms (1989-1997) and Papanicolaou Tests (1991-1997) -- Behavioral Risk Factor Surveillance SystemWeb Page. Available at: http://www.cdc.gov/epo/mmwr/preview/mmwrhtml/ss4806a1.htm. Accessed October 8, 1999.
10 Kinsinger L, Harris R, Karnitschnig J. Worry about breast cancer in younger women: a major problem. J Gen Intern Med. 1998;13:507-514. [pmid: 9734786].
11 Kelsey JL, Bernstein L. Epidemiology and prevention of breast cancer. Annu Rev Public Health. 1996;17:47-67. [pmid: 8724215].
12 Kelsey JL, Gammon MD, John EM. Reproductive factors and breast cancer. Epidemiol Rev. 1993;15:36-47. [pmid: 8405211]. [pmcid: 354414].
13 Helzlsouer KJ. Early detection and prevention of breast cancer. In: Greenwald P, Kramer BS, Weed D, eds. Cancer Prevention and Control. New York, NY: Marcel Dekker, Inc. 1995:509-536.
14 Powles TJ, Hardy JR, Ashley SE, et al. Chemoprevention of breast cancer. Breast Cancer Res Treat. 1989;14:23-31. [pmid: 2690969]. [pmcid: 324689].
15 Hankinson SE, Willett WC, Manson JE, et al Plasma sex steroid hormone levels and risk of breast cancer in postmenopausal women J Natl Cancer Inst1998 90 1292 1299 9731736
16 Cauley JA, Lucas FL, Kuller LH, Stone K, Browner W, Cummings SR. Elevated serum estradiol and testosterone concentrations are associated with a high risk for breast cancer. Study of Osteoporotic Fractures Research Group. Ann Intern Med. 1999;130:270-277. [pmid: 10068384].
17 Toniolo PG, Levitz M, Zeleniuch-Jacquotte A, et al A prospective study of endogenous estrogens and breast cancer in postmenopausal women J Natl Cancer Inst1995 87 190 197 7707406
18 Zmuda JM, Cauley JA, Ljung BM, Bauer DC, Cummings SR, Kuller LH Bone mass and breast cancer risk in older women: differences by stage at diagnosis J Natl Cancer Inst2001 93 930 936 11416114 276537
19 Zhang Y, Kiel DP, Kreger BE, et al. Bone mass and the risk of breast cancer among postmenopausal women. N Engl J Med. 1997;336:611-617. [pmid: 9032046].
20 Schairer C, Lubin J, Troisi R, Sturgeon S, Brinton L, Hoover R. Menopausal estrogen and estrogen-progestin replacement therapy and breast cancer risk. JAMA. 2000;283:485-491. [pmid: 10659874].
21 Persson I, Weiderpass E, Bergkvist L, Bergstrom R, Schairer C. Risks of breast and endometrial cancer after estrogen and estrogen-progestin replacement. Cancer Causes Control. 1999;10:253-260. [pmid: 10482483]. [pmcid: 202315].
22 Colditx G, Rosner B Use of estrogen plus progestin is associated with greater increase in breast cancer risk than estrogen alone Am J Epidemiol. 1998 147(suppl):216007
23 Lippman SM, Brown PH Tamoxifen prevention of breast cancer: an instance of the fingerpost J Natl Cancer Inst1999 91 1809 1819 10547388
24 Zeleniuch-Jacquotte A, Toniolo P, Levitz M, et al. Endogenous estrogens and risk of breast cancer by estrogen receptor status: a prospective study in postmenopausal women. Cancer Epidemiol Biomarkers Prev. 1995;4:857-860. [pmid: 8634657]. [pmcid: 375949].
25 Smith-Warner SA, Spiegelman D, Yaun SS, et al. Alcohol and breast cancer in women: a pooled analysis of cohort studies. JAMA. 1998;279:535-540. [pmid: 9480365].
26 Tseng M, Weinberg CR, Umbach DM, Longnecker MP. Calculation of population attributable risk for alcohol and breast cancer (United States). Cancer Causes Control. 1999;10:119-123. [pmid: 10231160]. [pmcid: 25158].
27 Friedenreich CM, Thune K, Brinton LA, Albanes D. Epidemiologic issues related to the association between physical activity and breast cancer. Cancer. 1998;83:600-610. [pmid: 9690523].
28 Rockhill B, Willett WC, Hunter DJ, et al Physical activity and breast cancer risk in a cohort of young women J Natl Cancer Inst1998 90 1155 1160 9701365 329979
29 Rockhill B, Willett WC, Hunter DJ, Manson JE, Hankinson SE, Colditz GA. A prospective study of recreational physical activity and breast cancer risk. Arch Intern Med. 1999;159:2290-2296. [pmid: 10547168].
30 Verloop J, Rookus MA, van der Kooy K, van Leeuwen FE Physical activity and breast cancer risk in women aged 20-54 years J Natl Cancer Inst2000 92 128 135 10639514
31 Madigan MP, Ziegler RG, Benichou J, Byrne C, Hoover RN Proportion of breast cancer cases in the United States explained by well-established risk factors J Natl Cancer Inst1995 87 1681 1685 7473816 295266
32 Kerlikowski K, Grady D, Rubin S, Sandrock C, Ernster VL. Efficacy of screening mammography: a meta-analysis. JAMA. 1995;273:149-154. [pmid: 7799496].
33 Harris R, Leininger L. Clinical strategies for breast cancer screening: weighing and using the evidence. Ann Intern Med. 1995;122:539-547. [pmid: 7872591].
34 Lerman C, Trock B, Rimer BK, Boyce A, Jepson C, Engstrom PF. Psychological and behavioral implications of abnormal mammograms. Ann Intern Med. 1991;114:657-661. [pmid: 2003712].
35 Elmore JG, Barton MB, Moceri VM, Polk S, Arena PJ, Fletcher SW. Ten-year risk of false positive screening mammograms and clinical breast examinations. N Engl J Med. 1998;338:1089-1096. [pmid: 9545356].
36 US. Preventive Services Task Force. United States. Guide to Clinical Preventive Services. 2^nd^ ed. Alexandria, VA: International Medical Publishing. 1996. [pmcid: 190016].
37 Huang Z, Hankinson SE, Colditz GA, et al. Dual effects of weight and weight gain on breast cancer risk. JAMA. 1997;278:1407-1411. [pmid: 9355998].
38 Holmes MD, Hunter DJ, Colditz GA, et al. Association of dietary intake of fat and fatty acids with risk of breast cancer. JAMA. 1999;281:914-920. [pmid: 10078488].
39 Smith-Warner SA, Spiegelman D, Yaun SS, et al. Intake of fruits and vegetables and risk of breast cancer: a pooled analysis of cohort studies. JAMA. 2001;285:769-776. [pmid: 11176915].
40 Early Breast Cancer Trialists' Collaborative Group. Tamoxifen for early breast cancer: an overview of the randomised trials. Lancet. 1998;351:1451-1467. [pmid: 9605801].
41 Fisher B, Dignam J, Wolmark N, et al. Tamoxifen in treatment of intraductal breast cancer: National Surgical Adjuvant Breast and Bowel Project B-24 randomised controlled trial. Lancet. 1999;353:1993-2000. [pmid: 10376613].
42 Cummings SR, Eckert S, Krueger KA, et al. The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. Multiple Outcomes of Raloxifene Evaluation. JAMA. 1999;281:2189-2197. [pmid: 10376571].
43 Veronesi U, De Palo G, Marubini E, et al Randomized trial of fenretinide to prevent second breast malignancy in women with early breast cancer J Natl Cancer Inst1999 91 1847 1856 10547391
44 Anonymous. ACOG says use of tamoxifen in preventing breast cancer must be individualized. Web Page. Available at: http://www.acog.org/from_home/publications/press_releases/nr9-30-99.htm. Accessed December 1999.
45 Chlebowski RT, Collyar DE, Somerfield MR, Pfister DG. American Society of Clinical Oncology technolgy assessment on breast cancer risk reduction strategies: tamoxifen and raloxifene. J Clin Oncol. 1999;17:1939-1955. [pmid: 10561236].
46 Levine M, Moutquin JM, Walton R, Feightner J. Chemoprevention of breast cancer. A joint guideline from the Canadian Task Force on Preventive Health Care and the Canadian Breast Cancer Initiative's Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ. 2001;164:1681-1690. [pmid: 11450210]. [pmcid: 81154].
47 Gail MH, Costantino JH, Bryant J, et al Weighing the risks and benefits of tamoxifen treatment for preventing breast cancer J Natl Cancer Inst1999 91 1829 1846 10547390 43257
48 Harris JR, Morrow M, Osborne CK, et al. Treatment of early-stage breast cancer. In: Harris JR, Lippman ME, Morrow M, Hellman S, eds. Diseases of the Breast. Philadelphia, PA: Lippincott-Raven Publishers. 1996. [pmcid: 190016].
49 Harris RP, Helfand M, Woolf SH, et al Current methods of the U.S. Preventive Services Task Force. A review of the process Am J Prev Med. 2001 20(Suppl 3):21 35 11306229 181625
50 Rademacher MD, Simon R Estimation of tamoxifen's efficacy for preventing the formation and growth of breast tumors J Natl Cancer Inst2000 92 48 53
51 Pritchard KI. Commentary: Is tamoxifen effective in prevention of breast cancer?. Lancet. 1998;352:80-81. [pmid: 9672266].
52 Bilimoria MM, Jordan VC, Morrow M. Additional benefits of tamoxifen for postmenopausal patients. In: Jordan V, ed. Tamoxifen: A Guide for Clinicians and Patients. Huntington, NY: PRR. 1996:75-87.
53 Delmas PD, Bjarnason NH, Mitlak BH, et al. Effects of raloxifene on bone mineral density, serum cholesterol concentrations, and uterine endometrium in postmenopausal women. N Engl J Med. 1997;337:1641-1647. [pmid: 9385122].
54 Walsh BW, Kuller LH, Wild RA, et al. Effects of raloxifene on serum lipids and coagulation factors in healthy postmenopausal women. JAMA. 1998;279:1445-1451. [pmid: 9600478].
55 Rutqvist LE, Mattsson A Cardiac and thromboembolic morbidity among postmenopausal women with early-stage breast cancer in a randomized trial of adjuvant tamoxifen. The Stockholm Breast Cancer Study Group J Natl Cancer Inst1993 85 1398 1406 8350363 279778
56 McDonald CC, Stewart HJ. Fatal myocardial infarction in the Scottish adjuvant tamoxifen trial. The Scottish Breast Cancer Committee. BMJ. 1991;303:435-437. [pmid: 1912833].
57 McDonald CC, Alexander FE, Whyte BW, Forrest AP, Stewart HJ. Cardiac and vascular morbidity in women receiving adjuvant tamoxifen for breast cancer in a randomised trial. The Scottish Cancer Trials Breast Group. BMJ. 1995;311:977-980. [pmid: 7580638].
58 Costantino JP, Kuller LH, Ives DG, Fisher B, Dignam J Coronary heart disease mortality and adjuvant tamoxifen therapy J Natl Cancer Inst1997 89 776 782 9182975 277536
59 Barrett-Connor E, Wenger NK, Grady D, et al. Coronary heart disease in women, randomized clinical trials, HERS and RUTH. Maturitas. 1998;31:1-7. [pmid: 10091198]. [pmcid: 165567].
60 Love RR, Mazess RB, Barden HS, et al. Effects of tamoxifen on bone mineral density in postmenopausal women with breast cancer. N Engl J Med. 1992;326:852-856. [pmid: 1542321]. [pmcid: 153471].
61 Love RR, Barden HS, Mazess RB, Epstein S, Chappell RJ. Effect of tamoxifen on lumbar spine bone mineral density in postmenopausal women after 5 years. Arch Intern Med. 1994;154:2585-2588. [pmid: 7979855].
62 Khovidhunkit W, Shoback DM. Clinical effects of raloxifene hydrochloride in women. Ann Intern Med. 1999;130:431-439. [pmid: 10068418].
63 Ettinger B, Black DM, Mitlak BH, et al. Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. Multiple Outcomes of Raloxifene Evaluation (MORE) Investigators. JAMA. 1999;282:637-645. [pmid: 10517716].
64 Jordan VC. Tamoxifen for breast cancer prevention. Proceedings of the Society for Experimental Biology and Medicine. 1995;208:144-149. [pmid: 7831346].
65 Fisher B, Costantino JP, Redmond CK, Fisher ER, Wickerham DL, Cronin WM Endometrial cancer in tamoxifen-treated breast cancer patients: findings from the National Surgical Adjuvant Breast and Bowel Project (NSABP) B-14 J Natl Cancer Inst1994 86 527 537 8133536 278467
66 Suh-Burgmann EJ, Goodman A. Surveillance for endometrial cancer in women receiving tamoxifen. Ann Int Med. 1999;131:127-135. [pmid: 10419429].
67 Osborne CK. Tamoxifen in the treatment of breast cancer. N Engl J Med. 1998;339:1609-1618. [pmid: 9828250].
68 Love CDB, Muir BB, Scrimgeour JB, Leonard RCF, Dillon P, Dixon JM. Investigation of endometrial abnormalities in asymptomatic women treated with tamoxifen and an evaluation of the role of endometrial screening. J Clin Oncol. 1999;17:2050-2054. [pmid: 10561257].
69 Barakat RR. Screening for endometrial cancer in the patient receiving tamoxifen for breast cancer. J Clin Oncol. 1999;17:1967-1968. [pmid: 10561245].
70 Boss SM, Huster WJ, Neild JA, Glant MD, Eisenhut CC, Draper MW. Effects of raloxifene hydrochloride on the endometrium of postmenopausal women. Am J Obstet Gynecol. 1997;177:1458-1464. [pmid: 9423751].
71 Day R, Ganz PA, Constantino JP, Cronin WM, Wickerham DL, Fisher B. Health-related quality of life and tamoxifen in breast cancer prevention: a report from the National Adjuvant Surgical Breast and Bowel Project P-1 Study. J Clin Oncol. 1999;17:2659-2669. [pmid: 10561339].
72 Noe LL, Becker RV, Gradishar WJ, Gore M, Trotter JP The cost effectiveness of tamoxifen in the prevention of breast cancer Am J Managed Care. 1999(Suppl 5):S389 S406
73 Smith TJ, Hillner BE. Tamoxifen should be cost-effective in reducing breast cancer risk in high-risk women. J Clin Oncol. 2000;18:284-286. [pmid: 10637241]. [pmcid: 377963].
74 Stanford JL, Szklo M, Brinton LA. Estrogen receptors and breast cancer. Epidemiol Rev. 1986;8:42-59. [pmid: 3533584].
75 Veronesi U, Maisonneuve P, Costa A, Rotmensz N, Boyle P. Drop-outs in tamoxifen prevention trials [letter]. Lancet. 1999;353. [pmid: 9923912].
76 Veronesi A, Pizzichetta MA, Ferlante MA, et al. Tamoxifen as adjuvant after surgery for breast cancer and tamoxifen or placebo as chemoprevention in healthy women: different compliance with treatment. Tumori. 199;84:372-35. [pmid: 9678620].
77 National Cancer Institute Clinical trials. Available at: http://cancertrials.nci.nih.gov.
78 Cooper C The crippling consequences of fractures and their impact on quality of life Am J Med 1997 103(2A):12S 19S 9302893
79 Taylor AL, Adams-Campbell LL, Wright JT Jr Risk/benefit assessment of tamoxifen to prevent breast cancer-still a work in progress? J Natl Cancer Inst1999 91 1792 1793 10547378 288160
80 O'Connor AM, Rostom A, Fiset V, et al. Decision aids for patients facing health treatment or screening decisions: systematic review. BMJ. 1999;319:731-734. [pmid: 10487995]. [pmcid: 28223].
81 Kinsinger LS, Harris R. Breast cancer screening discussions for women in their forties. Breast Disease. 2001;13:21-31. [pmid: 15687619].