# Discussion

## Major Findings

Four randomized, masked, placebo-controlled trials of chemoprevention for breast cancer have been reported. Three were trials of tamoxifen in which breast cancer prevention was the primary outcome, and one was a trial of raloxifene in which breast cancer prevention was the secondary outcome. The largest of the three tamoxifen trials, the BCPT, found a strongly favorable effect (49 percent relative risk reduction) of tamoxifen on decreasing the incidence of breast cancer in women at high risk for developing the disease. These results are in keeping with a large body of evidence from previous studies of tamoxifen as adjuvant hormonal therapy for breast cancer, in which the risk of developing contralateral breast cancer was significantly reduced in women taking tamoxifen. The two smaller European chemoprevention trials did not find such benefits of tamoxifen. The raloxifene study, like the BCPT, found a large impact of raloxifene on decreasing the risk of breast cancer in older women with osteoporosis. This chapter will discuss the results of these four studies and examine several possible explanations for these discrepant findings.

Although the three tamoxifen studies are broadly similar in purpose and design, important differences among them stand out. These differences include age and underlying level of breast cancer risk in the study participants, overall size of the studies and numbers of cancers identified, compliance and continuation rates of participants, and co-interventions, specifically the use of HRT by women in the trials.

The age ranges of women in the tamoxifen trials varied somewhat: 61 percent of women in the Royal Marsden Hospital study were younger than age 50 years, whereas 38 percent of women in the Italian study and 39 percent of women in the BCPT were under the age of 50 years. Breast cancer in premenopausal women is more commonly associated with lower levels of estrogen receptors (i.e., ER-).^ 74 ^ The BCPT found a beneficial effect of tamoxifen only on ER+ tumors; thus, the likelihood of finding a positive effect in the Royal Marsden study is perhaps lower than in the other studies. The Royal Marsden investigators did not report the ER status of the breast cancers that occurred in their study.

All participants in the Royal Marsden study had strong family histories of breast cancer, having at least one first-degree relative under the age of 50 years with breast cancer, one first-degree relative with bilateral breast cancer, or two or more close relatives with breast cancer. In the BCPT, 76 percent of women had one or more family members with breast cancer (although age at onset was not given); only 21 percent of the women in the Italian study had family histories of breast cancer. Breast cancer genetic status (i.e., the presence of BRCA1 or BRCA2 genetic mutations) was not reported in any of the three studies. Previous studies have shown that 70 percent to 80 percent of breast cancers that develop in carriers of the BRCA1 mutation are ER-.^ 23 ^ If a greater proportion of women in the Royal Marsden study were carriers of the BRCA1 mutation, they would likely have a greater percentage of ER- tumors, and, as above, demonstrate less response to the breast cancer prevention effects of tamoxifen. Given that the population attributable risk from these genetic mutations is low, however, this would not seem to account for a major part of the difference among the trials.

In other ways, women in the Italian study were at lower risk for breast cancer than with women in the other two trials. Nearly half (48.3 percent) of the Italian women had had bilateral oophorectomies, thus reducing their overall risk for the disease. The number of breast cancers was only 2.3 per 1,000 woman-years of follow up in the placebo group of the Italian study; this compares with a rate of 5.0 cancers per 1,000 woman-years in the Royal Marsden study and 6.6 cancers per 1,000 woman-years in the BCPT.^ 51 ^

Of the three studies, the BCPT was by far the largest (13,175 women included in the analysis). Compared to the 368 breast cancers found among the BCPT participants, the Royal Marsden study diagnosed only 70 breast cancers and the Italian trial reported 41 cancers. The Royal Marsden investigators calculated they had sufficient power (90 percent) to detect a 50 percent reduction in breast cancer in their study, whereas Veronesi et al.^ 7 ^ estimated only 34 percent power to detect a 33 percent reduction in disease.

Concerns have been raised about compliance and dropout rates in all three trials.^23,51^ Total discontinuation rates (including dropouts, withdrawals, and loss to follow up) ranged from 26.3 percent in the Italian study to 46.8 percent in the Royal Marsden trial. Veronesi et al.^ 75 ^ noted that the dropout rate among women in the Italian study was higher in the first year of the trial and that most women left for reasons other than side effects of the drugs. The other two studies did not report information about the timing of discontinuation among their participants.

Veronesi and colleagues also compared discontinuation rates for women in adjuvant tamoxifen studies and women in the tamoxifen chemoprevention study. They found that women in the chemoprevention study stopped the study medication at a higher rate (26.7 percent) than did women in the adjuvant trials (15.1 percent).^ 76 ^ Healthy women, even those at higher-than-average risk for breast cancer, appear to be less willing to accept mild side effects of tamoxifen, such as hot flashes and vaginal discharge, than women who are taking the drug after having been diagnosed with breast cancer.

Another variation among the three tamoxifen trials is the use of HRT. Both the Royal Marsden and Italian studies allowed women to take such medication; the BCPT did not. Of the women in the Royal Marsden study, 41.2 percent were either taking HRT at the onset of the trial or began taking it during the trial. Paradoxically, the investigators found that participants who were already taking HRT at entry into the study had an increased risk of breast cancer than did nonusers (RR, 1.9; 95% CI, 1.1-3.3), whereas those women who started HRT during the course of the study had a decreased risk (RR, 0.4; 95% CI, 0.2-0.7). Tamoxifen appeared to have no effect on this interaction. The Italian study had so few breast cancer cases among women taking HRT throughout the trial (nine total) that conclusions about the impact of tamoxifen for HRT users cannot be drawn. The extent to which HRT use by women in these studies accounted for some of the discrepancy in the results is difficult to determine.

Given the younger population with strong family histories of breast cancer in the Royal Marsden study and relatively few breast cancer events among the smaller number of participants, perhaps the lack of effect of tamoxifen on reducing the incidence of breast cancer is not surprising. Likewise, considering the low incidence of breast cancer in the women in the Italian study, the negative findings from that study are also not unexpected. The Italian investigators reported, for women who continued their assigned study medication for at least one year, a trend toward fewer breast cancer events among women in the tamoxifen group (11 cases vs 19 in the placebo group, P = 0.16). They estimated a probability of 0.87 of finding a significant difference between the two groups after five more years of follow up, if the trend continued and the reduction in breast cancer incidence by tamoxifen was 33 percent. Therefore, had this study been continued over a longer period of time, it might have yielded results consistent with the BCPT results.

To answer the question of the effectiveness of tamoxifen in reducing the incidence of breast cancer, the BCPT results are the most compelling. This well-designed trial included a large number of women over wide ranges of age and risk status, and it accumulated enough events to make the statistical analysis robust. The consistency of these results with those of previous tamoxifen studies adds to its strength. The findings of the MORE study of raloxifene, showing a significant decrease in breast cancer risk, add further support to the role of these SERMs in chemoprevention of breast cancer.

The National Cancer Institute has launched a study that will directly compare these two agents, the Study of Tamoxifen and Raloxifene (STAR) trial (NSABP P-2).^ 77 ^ The trial plans to enroll 22,000 postmenopausal women at high risk of breast cancer; they will be randomly assigned to either tamoxifen or raloxifene for five years. No HRT use or placebo control will be included.

## Benefits and Harms

The decision about using a drug for chemoprevention for breast cancer depends on both the strength of the benefits and the significance of the possible harms. In contrast to therapeutic uses of medications, in which users are taking the medications to improve their current health status, chemoprevention requires that healthy persons take medications to prevent the possibility of an adverse health condition. More persons taking a drug for therapeutic reasons would be expected to benefit than would persons taking the drug for chemoprevention.

All persons exposed to the medication, whether for therapeutic reasons or for prevention, however, are at risk of side effects of the medication. Thus, the balance between benefits and harms may be different for chemoprevention than for treatment. Where the balance falls depends greatly on the importance of the potential benefits and the harms.

Preventing breast cancer is a benefit that many women in the United States likely would value highly. The cumulative incidence of invasive breast cancer in the BCPT in the women assigned to placebo was 4.3 per 100 women over 69 months, whereas among the women assigned to tamoxifen, the cumulative incidence was 2.2 per 100 women, for an absolute risk reduction of 2.1 per 100 women. The number of women who would need to be treated (NNT) with daily tamoxifen for more than five years to prevent one case of breast cancer is 48. Women in the placebo group in the MORE study had a cumulative incidence of breast cancer of 1.2 per 100 in four years compared to 0.4 per 100 in the raloxifene group, yielding an absolute risk reduction of 0.8 per 100 women. The NNT for raloxifene over four years is 125 women.

Other potential benefits of tamoxifen and raloxifene include a reduction in CHD incidence and osteoporotic fracture rate. The evidence supporting a clinically significant improvement in CHD risk by either agent is quite modest. Neither the BCPT nor the meta-analysis of a large number of breast cancer treatment trials suggests an effect of tamoxifen on cardiac endpoints. Both tamoxifen and raloxifene have been shown to improve lipid levels but that does not necessarily correlate with improved heart disease outcomes.

In one RCT, raloxifene decreased the risk of vertebral fractures in postmenopausal women with osteoporosis by 30 percent to 50 percent. Among women with low BMD but no fractures, 46 to 59 would need to take raloxifene (60 or 120 mg per day) for three years to prevent one new vertebral fracture. Among women with low BMD and one or more prevalent fractures, 10 to 16 would need to be similarly treated to prevent a new fracture. In this study, however, raloxifene had no impact on hip fractures, yet hip fractures are associated with more serious clinical outcomes than are vertebral fractures.^ 78 ^

## Harms

The harms of these SERMs fall into two categories: those that are annoying but less serious and those that are potentially more serious. In the former category, increased frequency of hot flashes (with both drugs) and vaginal discharge (especially with tamoxifen) are the most commonly reported adverse effects. Although these symptoms may have led more women in the active treatment groups to discontinue the medication, a health-related quality of life survey of women in the BCPT found no evidence the drugs substantially affected their overall physical or emotional well-being.

In the latter category are the potentially more serious harms, such as endometrial cancer and thromoembolic disease. Although the absolute incidence of these outcomes is low, the tolerance for such outcomes among healthy women taking these agents for chemoprevention must also be low. An absolute increased risk of 1.4 cases of endometrial cancer per 1,000 women per year was seen only among women taking tamoxifen in the BCPT, whereas no increased incidence was reported for women taking raloxifene. Said another way, for each 714 women taking tamoxifen for five years, one woman would be newly diagnosed with endometrial cancer.

The absolute increase in the risk of thromboembolic disease, specifically deep vein thrombosis and pulmonary embolus, in the BCPT was even smaller than the increase noted for endometrial cancer. For both conditions, the increased risk was 0.5 cases per 1,000 women per year; thus for each 2,000 women taking tamoxifen for five years, one woman would develop a deep vein thrombosis and one woman would suffer a pulmonary embolus. Raloxifene was also associated with an elevated risk for venous thromboembolic disease, but absolute risk increases and the number of women who would be harmed by developing these conditions cannot be calculated from the available data.

Age of the women in the BCPT was a significant factor in determining the impact of adverse effects of tamoxifen. Women of all ages had similar reductions in breast cancer incidence, so the benefits did not vary by age. Postmenopausal women, however, were more at risk for endometrial cancer, deep vein thrombosis, and pulmonary embolism than premenopausal women. The annual rates of endometrial cancer for women taking tamoxifen were 1.3 per 1,000 women 49 years of age and younger (with intact uteri) and 3.1 per 1,000 similar women 50 years of age and older. Rates in the placebo group did not differ significantly between the two age ranges (1.1 and 0.8 per 1,000 women, respectively). Average annual rates of pulmonary embolism for women taking tamoxifen were 0.2 per 1,000 among those 49 years of age and younger and 1.0 per 1,000 among those 50 and older (placebo group rates were 0.1 and 0.3 per 1,000, respectively). Deep vein thrombosis occurred at annual rates of 1.1 per 1,000 women under the age of 50 and 1.5 for women ages 50 and over. Placebo group rates were similar in the two age groups (0.8 and 0.9 per 1,000 women, respectively).

In summary, the decision to use or not use chemoprevention for breast cancer is a complicated one, requiring a balancing of both important benefits and potentially serious harms. Women's decisions will depend on their individual risk profiles and their preferences and values. Health care providers will need to be able to help women understand the various pros and cons of breast cancer prophylaxis.

## Balance Sheets

Appendix C presents six balance sheets illustrating two variables important to understanding this trade-off: (1) the number needed to treat (NNT), i.e., the number of women who would need to be treated with daily tamoxifen for five years to prevent one case of breast cancer; (2) the number needed to harm (NNH), i.e., the number of women who would suffer a harmful side effect from treatment with tamoxifen over five years. The balance sheets, based on a model developed by Gail and colleagues,^ 47 ^ are presented for three age groups (40-49 years, 50-59 years, and 70-79 years) and two risk levels (average and high).

Specifically, Gail and colleagues developed a summary of benefits and risks associated with tamoxifen use based on BCPT results (see Appendix B, Evidence Table).^ 47 ^ For women 40 to 49 years of age (Balance Sheets 1 and 2), they calculated the number of life-threatening events that would be expected during the next five years among 10,000 untreated 40-year-old white women (with uteri) at high risk of breast cancer (2 percent projected five-year risk of invasive breast cancer). They then compared those figures with the number of expected cases that would be prevented or caused by five years of tamoxifen use. As shown in Balance Sheet 2, they estimated that, in the cohort of 10,000 untreated women, 200 cases of invasive breast cancer would occur, but that in the 10,000 women treated with tamoxifen, 97 cases might be prevented. In contrast to that benefit, they computed the additional harms that might occur among treated women relative to untreated women: 16 more cases of endometrial cancer (26 in the treated group, 10 in the untreated group); 13 more strokes (35 vs 22 cases, respectively) and 15 additional cases of pulmonary embolism (22 vs 7 cases, respectively).

Gail et al. also calculated the number of severe events in the same two groups of 40-year-old women treated and not treated with tamoxifen for five years. The number of cases of in situ breast cancer was lower for treated women: 106 cases per 10,000 untreated women and 53 cases per 10,000 treated women (53 cases prevented). In addition, the number of women with deep vein thrombosis was higher among treated women, 24 cases in the untreated cohort and 39 in the treated cohort (15 cases caused).

Thus, for a younger woman at high risk of breast cancer, tamoxifen may offer greater benefits than harms. That judgment, however, depends on her personal risks and preferences.

Older women (over the age of 50) at high risk for breast cancer would likely experience greater benefits than those estimated for 40-year-old women, based on a higher incidence of breast cancer and an equal reduction in risk by tamoxifen. They would also suffer more adverse events, given their higher rates of endometrial cancer, stroke, and pulmonary embolism.

Appendix C presents estimates of benefits and harms for average and high-risk women ages 50 to 59 years (Balance Sheets 3 and 4) and ages 70 to 79 years (Balance Sheets 5 and 6). For an older woman at average risk of breast cancer, the balance between benefits and harms of tamoxifen appears to be closer to even than is the case for younger women. Again, each woman's own choices are critical in making a decision about whether to take the drug.

Finally, a younger woman at average risk of breast cancer would likely accrue fewer benefits but also would likely suffer few harms, as shown in Balance Sheet 1. Her decision may be especially influenced by her perception of her risk for breast cancer. Many women in this age group are particularly worried about breast cancer^ 10 ^ and perceive their risk to be higher than actual risk calculations would estimate. For these women, tamoxifen may offer some additional benefit, in terms of psychological "peace of mind."

## Future Research Needs

### Limitations of the Literature

Despite the high-quality RCTs described above, several unanswered questions remain about the use of these SERMs for chemoprevention of breast cancer. These may be categorized as (1) questions not studied at all; (2) questions not fully studied; and (3) methodologic questions about the studies that have been done. The most important question that has not been studied at all is the overarching question of whether chemoprevention leads to fewer breast cancer deaths.

Questions not fully studied include the population of women to whom these results apply. The studies reported to date included very few women of color (96.5 percent white in the BCPT, 95.7 percent white in the MORE study). Rates of breast cancer incidence and mortality vary by racial groups, as do rates of complications, including endometrial cancer, stroke, and thromboembolic events.^ 79 ^ Extrapolation of the findings of these studies to groups other than white women may not be appropriate.

Whether the agents work by preventing the formation of new tumors or by treating very early, undetectable cancers (or both) has not been clearly determined.^ 50 ^ Although these drugs do reduce the incidence of breast cancer (an important outcome in itself), an effect on breast cancer mortality has not yet been shown.

Given that one common side effect of both tamoxifen and raloxifene is hot flashes and that these drugs may not have the same degree of risk reduction of CHD as that thought to be true of estrogen, the relative advantages of these drugs over HRT in postmenopausal women, for whom the risk of dying of heart disease exceeds that of breast cancer, is uncertain. Also as yet undetermined is the impact of chemoprevention on women with very high risk of breast cancer due to the presence of genetic abnormalities (BRCA1 and BRCA2). The BCPT investigators plan to look for these markers among the women in their trial to answer this question. The issue of compliance with medications taken by healthy women to reduce a possible future risk is another question to be addressed.

Little is known yet about the length of time a woman should take tamoxifen or raloxifene for breast cancer prevention, should she decide to do so. None of the trials were designed to continue following women after the three-to-five year period of treatment to determine long-term effects of these drugs on breast cancer risk reduction. What happens to a woman's risk after taking a chemopreventive agent for a period of time is also unknown. The role of estrogen receptors is not yet clear from the published studies. The proportion of ER+ tumors in the Royal Marsden study has not been reported but would be helpful in interpreting the results.

### Future Research Needs

A large research agenda exists to clarify further the role of SERMs and other chemopreventive agents in breast cancer prevention. Women who have participated in the chemoprevention studies should be followed, without treatment, for another five years or so, to determine the natural history of five years of chemoprevention. Whether more treatable breast cancers are the ones being prevented and, if so, what impact that has on overall mortality from breast cancer need both to be determined. Given the conflicting results of the three tamoxifen trials and the inherent limitations of making recommendations from only one trial of raloxifene, further studies of these SERMs should be done to confirm or refute their results. Newer SERMs with fewer adverse effects will likely be developed in the coming years, and they will need to be studied rigorously.

If chemoprevention is shown conclusively to be effective, the issue of long-term compliance with medications will loom larger. Effective decision aids and communication strategies about benefits and harms of breast cancer prevention will become increasingly important for helping women make decisions regarding this complex issue.^ 80 ^ Shared decisionmaking between a woman and her clinician will likely prove useful in addressing this topic.^ 81 ^ Further research in regard to the benefits and harms of HRT will also bear substantially on the question of chemoprevention for breast cancer.