# Results

In this chapter, we present the results of our SER. The results are organized according to the key questions defined in our analytic framework (Figure 1). The key questions that constitute the major headings of this chapter correspond to the major linkages of the analytic framework. We first address the lack of evidence for the effectiveness of chemoprevention on mortality from breast cancer (Key Question 1) and then examine the evidence for the effectiveness of chemoprevention to prevent the occurrence of breast cancer (Key Question 2). Next, we discuss the potential benefits, adverse effects, and costs of chemoprevention for the prevention of breast cancer (Key Questions 3 through 5). As noted in Chapter 1, Key Questions 6 through 8 are not addressed in this review.

## Key Question No. 1: Effectiveness of Chemoprevention to Reduce Mortality from Breast Cancer

We found no study that was large or long enough to answer this important first key question. The trials described under Key Question 2 (below) had too few deaths and too short a follow-up period to determine the impact of breast cancer chemoprevention on mortality. Data from trials of tamoxifen as adjuvant therapy in the treatment of breast cancer have shown a survival benefit of tamoxifen, but results of those studies may not apply to the issue of tamoxifen as a chemopreventive agent.

## Key Question No. 2: Effectiveness of Chemoprevention to Reduce Incidence of Breast Cancer

We found four RCTs of the effectiveness of chemoprevention to reduce the incidence of breast cancer (see Appendix B, Evidence Table). Three trials used tamoxifen: the Royal Marsden Hospital Tamoxifen Chemoprevention Trial (hereafter referred to as the Royal Marsden study);^ 6 ^ the Italian Tamoxifen Prevention Study (the Italian study);^ 7 ^ and the National Surgical Adjuvant Breast and Bowel Project P-1 Study, known as the Breast Cancer Prevention Trial (BCPT).^ 5 ^ One trial used raloxifene: the Multiple Outcomes of Raloxifene Evaluation trial (MORE).^ 42 ^ No RCTs of primary breast cancer prevention with fenretinide or other vitamin A analogs have been published.

## Chemoprevention Trials of Tamoxifen

As documented in the Evidence Table (Appendix B), the three tamoxifen trials were conducted among women at varying risk for breast cancer, had differing design elements, and found discrepant results. These three trials are described in detail below.

### The Royal Marsden Hospital Tamoxifen Chemoprevention Trial

The Royal Marsden study began in 1986 as a pilot trial to assess the effectiveness and safety of tamoxifen in the chemoprevention of breast cancer in healthy women who were at an increased risk of breast cancer because of family history of the disease. Eligible women were between 30 and 70 years of age, had no evidence of breast cancer, and had a family history of at least one first-degree relative under age 50 years with breast cancer, one first-degree relative with bilateral breast cancer, or one affected first-degree relative of any age plus another first-degree or second-degree relative with the disease. Women were allowed to continue or start using hormone replacement therapy (HRT) if indicated. Mammograms were repeated annually.

Over a 10-year period, 2,494 women were recruited for the trial; 23 were excluded because of pre-existing in situ or invasive breast cancer, leaving 2,471 participants for analysis. Women were randomly assigned to receive either 20 mg per day of tamoxifen or placebo for eight years.

Of the 2,471 women, 877 prematurely stopped the medication because of either side effects (320 women taking tamoxifen, 176 women taking placebo, P < 0.0005) or other reasons not explained in the report (381 women, difference between tamoxifen and placebo groups not significant). An additional 240 women (141 in the tamoxifen group, 139 in the placebo group) were lost to follow up for longer than 18 months. Overall, 1,157 of the 2,471 women in the trial (46.8 percent) withdrew from the study. The median follow-up period was 70 months. The study was designed to detect a 50 percent effect with 90 percent power based on a two-sided alpha of 5 percent. It used an intention-to-treat analysis.

At enrollment, 187 women in the tamoxifen group and 202 women in the placebo group were using HRT. During the trial, 336 women on tamoxifen and 305 women on placebo were treated with HRT. In total, 41.2 percent of women in the study were treated with HRT.

The study found 34 cases of breast cancer (including four cases of DCIS) in the tamoxifen group and 36 cases (also including four cases of DCIS) in the placebo group (RR, 1.06; 95% CI, 0.7-1.7). No difference was found between women who were taking HRT and those who were not. Four women in the tamoxifen group died of breast cancer, as did one woman in the placebo group. Five women in each group died of other causes.

The authors concluded that, despite the positive findings of the BCPT (see below), the benefits of tamoxifen chemoprevention for breast cancer are uncertain; they advocated for longer-term clinical trials to determine the benefit, if any, from tamoxifen.

### The Italian Tamoxifen Prevention Study

The Italian study by Veronesi et al.^ 7 ^ enrolled women from 1992 to 1997. Because of concerns about an increased risk of endometrial cancer by tamoxifen, the trial included only women ages 35 to 70 years who had had a hysterectomy for noncancer reasons. Some study participants had also had bilateral oophorectomy prior to menopause, so overall the women were at low-to-normal risk for breast cancer. Twenty-one percent of the enrollees had one or more first-degree relatives or aunts with breast cancer. Women were allowed to use HRT if prescribed by their physicians for menopausal symptoms; 14 percent of the women took HRT.^ 42 ^ Mammograms were done annually.

The trial randomized 5,408 women to tamoxifen 20 mg per day or placebo for five years. Complete data were obtained for 5,378 of the women; the median duration of follow up was 46 months. In total, 1,422 women withdrew from the study (26.3 percent). Of the 1,027 who withdrew for voluntary reasons, 301 women discontinued study medications because of side-effects. The remaining 395 women withdrew from the study for a variety of reasons: 239 dropped out because of the occurrence of a major event (nature not specified in the report); 60 withdrew for major changes in protocol (subtotal hysterectomy, endometriosis); 44 became ineligible; 33 were lost to follow up; 5 died; and 14 withdrew for other reasons. At the time of the report, only 149 women had completed five years of treatment (77 in the tamoxifen group, 72 placebo).

The study hypothesis estimated a 33 percent reduction in breast cancer cases, but its power was only 0.34 with alpha of 0.05. The investigators used an intention-to-treat analysis.

Of the 41 cases of breast cancer found in the study population, 19 were among women in the tamoxifen arm and 22 among women in the placebo arm (difference not significant). Among the women who followed assigned treatment for at least one year, however, fewer cases of breast cancer were detected in the tamoxifen group (11) than in the placebo group (19, P = 0.16). Although this difference was still not significant, the authors estimated an 87 percent probability of finding a significant difference after a further five years' follow-up if that difference remained and the reduction in breast cancer risk was 33 percent. No significant differences were noted between the two groups by estrogen or progesterone receptor status, family history, or age.

The authors concluded that their study was likely too short to truly determine an impact of tamoxifen on reducing the incidence of breast cancer and that further study is needed.

### The Breast Cancer Prevention Trial

The BCPT is the largest chemoprevention trial using tamoxifen. Between 1992 and 1997, this study recruited women considered to be at high risk for breast cancer, as determined by being either 60 years of age or older or having a history of lobular carcinoma in situ (LCIS) or between the ages of 35 to 59 and having a five-year predicted risk for breast cancer of at least 1.66 percent, as determined by the Gail model.^ 47 ^ Factors in this model include age, number of first-degree relatives with breast cancer, nulliparity or age at first birth, number of breast biopsies, pathologic diagnosis of atypical hyperplasia, and age at menarche. Women were not allowed to take HRT while in the study. Participants had clinical breast examinations at three and six months and every six months thereafter; they also had annual mammograms.^ 50 ^

In total, 13,388 women were randomized to receive either 20 mg per day of tamoxifen (6,681 women) or placebo (6,707 women). Of these, 212 had no follow up and 1 woman was excluded because she had invasive breast cancer at the beginning of the study, leaving 13,175 women in the study for analysis. A greater percentage of women in the tamoxifen group (23.7 percent) than in the placebo group (19.7 percent) stopped their therapy. Including all reasons for discontinuation (dropouts, withdrawal, and lost to follow up), 4,005 of the 13,175 women (30.4 percent) discontinued the study. Median follow up time was 54.6 months.

Of the 13,175 women in the study, 39.3 percent were 35 to 49 years old at randomization, 30.7 percent were 50 to 59 years, and 30.0 percent were 60 years of age or older. About one-quarter of the women (24.9 percent) had a five-year predicted risk of breast cancer of < 2 percent. Almost three-fifths (57.6 percent) had a five-year risk between 2.01 and 5 percent, and not quite one-fifth had a predicted risk greater than 5 percent. Nearly all participants (96.5 percent) were white. Calculations regarding the power of the study for its primary outcomes were not stated in the report, but the size of the trial and the number of primary outcomes indicate that power was likely adequate.^ 51 ^

A total of 368 invasive and noninvasive breast cancers occurred among the participants, 244 in the placebo group and 124 in the tamoxifen group. Of the 264 invasive breast cancer cases, 175 occurred in the placebo group compared with 89 in the tamoxifen group, yielding a 49 percent risk reduction (P < 0.00001). The risk reduction for noninvasive breast cancer (LCIS and DCIS) was similar at 50 percent (69 placebo cases vs 35 tamoxifen cases, P < 0.002). No significant differences in breast cancer deaths were seen (6 in the placebo group, 3 in the tamoxifen group).

Tamoxifen was equally effective in subgroups of women defined by age, history of LCIS, history of atypical hyperplasia, and level of predicted risk for breast cancer. Effectiveness differed by tumor hormone receptor status; however, tamoxifen reduced the annual rate of ER+ tumors by 69 percent, but it had no effect on ER- cancers. Tamoxifen was more effective in reducing the occurrence of tumors 2 centimeters or smaller (compared with larger ones) and in reducing tumors without nodal involvement (compared with those with one or more positive nodes).

The study authors concluded that tamoxifen is very effective in reducing the incidence of invasive and noninvasive breast cancer, especially ER+ tumors. In the study, high-risk women under the age of 50 years received as much benefit as older women, but they had few significant adverse effects. Thus, similar women should be considered strong candidates for tamoxifen chemoprevention. Older women may also benefit from tamoxifen, but the decision to use this agent is more complex for this group, given the drug's detrimental effects.

## Chemoprevention Trial of Raloxifene

Only one study of raloxifene as breast cancer chemoprevention has been published. In the Multiple Outcomes of Raloxifene Evaluation (MORE) trial by Cummings et al.,^ 42 ^ the effect of raloxifene on breast cancer cases was a secondary outcome; effect on osteoporosis fracture risk was the primary outcome of the study. The study, sponsored by Eli Lilly, Inc., was conducted at 180 clinical centers, mainly in the United States, Canada, and Europe, and enrolled 7,705 women who were at least two years postmenopausal and no older than 80 years. All participants had either osteoporosis (as determined by bone mineral density [BMD] studies) or at least one moderate or two mild vertebral fractures on radiographs. Women were not allowed to take HRT while in the study. Mammograms were done at baseline; they were optional after the first year but were mandatory after the second and third years of treatment.

Participants were randomly assigned to one of three treatment groups: 60 mg per day of raloxifene (2,557 women), 120 mg per day of raloxifene (2,572 women), or placebo (2,576 women) for three years. The mean age was 66.5 years, nearly all (96 percent) were white, and 12.3 percent reported a family history of breast cancer.

A total of 652 women (25 percent) had withdrawn from the placebo group by the end of 36 months, as did 1,152 women (22 percent) in the combined raloxifene groups (overall discontinuation rate: 23.4 percent). Reasons for dropout were not given in the report.

With a median of 40 months of follow up, 54 cases of breast cancer were identified; 40 were invasive breast cancer and 12 were DCIS (two cases had insufficient information to classify the degree of invasion). Of the 40 cases of invasive breast cancer, 13 occurred in the 5,129 women taking raloxifene and 27 in the 2,576 women taking placebo (RR, 0.24; 95% CI, 0.13-0.44). Outcomes did not differ between the two raloxifene dosage groups. Estrogen receptor status was determined for 35 of the 40 women with invasive breast cancers; 24 were ER+ and 11 were ER-. Of the 24 ER+ tumors, 20 were in the placebo group and four in the raloxifene groups (RR, 0.10; 95% CI, 0.04-0.24). Raloxifene did not affect ER- cancers, nor did it have a significant impact on cases of DCIS (5 in the placebo group, 7 in the raloxifene groups).

## Key Question No. 3: Other Beneficial Effects of Breast Cancer Chemoprevention

### Coronary Heart Disease and Serum Lipid Levels

As the benefit of tamoxifen for the treatment of breast cancer became established, concern was raised that its anti-estrogen effects would adversely affect lipid levels and lead to an increased risk of heart disease. Over the past 10 years, several studies have shown that tamoxifen acts like an estrogen agonist on serum lipid profiles. A summary of 10 studies of the effects of tamoxifen on lipoproteins showed an average decrease in total cholesterol of 13 percent, a decrease in low-density lipoprotein (LDL) cholesterol of 19 percent, but no significant change in high-density lipoprotein (HDL) cholesterol.^ 52 ^ Raloxifene also has been found to lower total and LDL cholesterol values.^53,54^ Similar to tamoxifen, raloxifene also had no significant effect on HDL cholesterol or on trigylcerides.

Evidence that the favorable serum lipid changes seen with tamoxifen therapy lead to improved clinical cardiovascular outcomes, however, is modest. Three RCTs of tamoxifen as adjuvant therapy in early breast cancer have reported rates of coronary heart disease (CHD) events from retrospective analyses. The Swedish trial of 2,365 postmenopausal women treated with 40 mg of tamoxifen daily for two or five years versus placebo found a 32 percent decrease in first hospital admissions for cardiac disease (51 vs 72 first admissions in the tamoxifen and placebo groups, respectively; relative hazard [RH], 0.68; 95% CI, 0.48-0.97).^ 55 ^ Longer tamoxifen therapy (five years) was associated with a greater benefit than shorter use (two years) (5 vs 14 first admissions, respectively; RH, 0.37; 95% CI, 0.15-0.92). No difference in cardiac-related deaths was noted between the two groups (12 vs 14 deaths).

The Scottish study of 1,312 women taking adjuvant tamoxifen or placebo following mastectomy for breast cancer reported fewer fatal myocardial infarctions (MI) in the tamoxifen group than in the placebo group (respectively, 10 and 25 MIs; RH, 0.37; 95% CI, 0.18-0.77).^ 56 ^ In addition, fewer hospital admissions for both fatal and nonfatal MIs occurred among women taking tamoxifen (15) than among those on placebo (22).^ 57 ^

The National Surgical Adjuvant Breast and Bowel Project (NSABP) B-14 trial of adjuvant tamoxifen therapy in women with ER+ breast cancers examined CHD mortality among the 2,885 women in the trial. Death from definite or possible CHD occurred in 19 women in the tamoxifen arm and 22 in the placebo arm, a nonsignificant difference.^ 58 ^

The BCPT was the first trial to measure cardiovascular endpoints prospectively. The tamoxifen and placebo groups did not differ in rates of ischemic heart disease. Among women receiving tamoxifen, 31 MIs occurred, including 7 fatal MIs; among the placebo group, 28 MIs occurred, including 8 fatal MIs. Overall, 71 ischemic heart disease events occurred in the tamoxifen arm, 62 in the placebo arm (RR, 1.15; 95% CI, 0.81-1.64).

No clinical trial has yet reported on CHD mortality or other cardiovascular outcomes from raloxifene. The Raloxifene Use for the Heart (RUTH) trial is currently under way to study the effects of raloxifene in postmenopausal women with or at high risk for CHD.^ 59 ^ The primary endpoints for the RUTH trial, which plans to enroll 10,000 women from 26 countries, are nonfatal MI and coronary death.

### Bone Density and Fractures

Another area of concern with regard to the long-term use of the two SERMs under consideration in this SER, tamoxifen and raloxifene, has been their impact on bone density loss, osteoporosis, and fracture risk. Both agents act as estrogen agonists, leading to increased BMD. Several studies have measured the effect of tamoxifen on BMD and bone turnover markers,^ 52 ^ but few have examined fracture rates as defined outcomes. In an RCT of tamoxifen versus placebo, Love et al.^ 60 ^ found that, after two years of therapy, the mean lumbar spine BMD in the 70 women given tamoxifen increased by 0.61 percent per year, whereas in the 70 women given placebo, it decreased by 1.00 percent per year (P < 0.001). Follow-up at five years of a subgroup of these women who were still taking their originally assigned therapy showed no further change in BMD measurements.^ 61 ^

The BCPT is the only trial that prospectively evaluated fracture risk with tamoxifen; it followed participants for osteoporotic fractures of the hip, spine, and lower radius. Fewer osteoporotic fractures occurred in women in the tamoxifen arm (111) than in the placebo arm (137), although this difference was not significant (RR, 0.81; 95% CI, 0.63-1.05). Nearly 40 percent of the participants in the BCPT were under 50 years of age and at little risk for fractures; this factor contributed to the insignificant results. The effect of tamoxifen in women with osteoporosis has not been studied.

Raloxifene, in contrast to tamoxifen, has been shown to increase BMD and reduce osteoporotic fractures. The Food and Drug Administration has recently approved the drug for the prevention of osteoporosis. Delmas et al.^ 53 ^ conducted a placebo-controlled trial of raloxifene in 601 postmenopausal women who received either 30, 60, or 150 mg of raloxifene per day or placebo for two years. BMD increased significantly in the lumbar spine, total hip, femoral neck, and total body by 1.2 to 1.6 percent with all doses of raloxifene, whereas bone loss of 0.6 to 1.3 percent occurred at each site in women in the placebo group (P < 0.0001 for all comparisons).^53,62^

The MORE investigators have presented the results of their RCT of raloxifene (60 mg per day and 120 mg per day) on the risk of vertebral and nonvertebral fractures.^ 63 ^ At 36 months of follow up of 6,828 women with evaluable radiographs, 10.1 percent of women receiving placebo had at least one new vertebral fracture, compared with 6.6 percent of women receiving 60 mg per day of raloxifene (RR, 0.7; 95% CI, 0.5-0.8) and 5.4 percent of women receiving 120 mg per day of raloxifene (RR, 0.5; 95% CI, 0.4-0.7). Vertebral fracture risk was reduced in women who did and women who did not have vertebral fractures at baseline. BMD in the femoral neck and spine increased by 2.1 percent to 2.7 percent in the two groups of raloxifene dosages. Raloxifene did not reduce the frequency of nonvertebral fractures.

## Key Question No. 4: Adverse Effects of Breast Cancer Chemoprevention

### Endometrial Cancer

In addition to having potentially beneficial, estrogen-like effect on bones and serum lipids, tamoxifen also has pro-estrogenic activity in the endometrium and thus may lead to harmful outcomes, including endometrial cancer.^ 64 ^ In its meta-analysis of 55 breast cancer trials of tamoxifen, the Early Breast Cancer Trialists' Collaborative Group (EBCTCG) showed that women taking tamoxifen were 2.58 times more likely to develop endometrial cancer than women taking placebo (P < 0.00001).^ 40 ^ Among the 37,000 women in these trials followed for two to five years, however, only a total of 92 cases of endometrial cancer occurred in the tamoxifen group, 32 in the placebo group. The 10-year risk for the diagnosis of endometrial cancer increased from 2 per 1,000 women to 6 per 1,000. Tamoxifen use was associated with an excess of one death from endometrial cancer per 1,000 women over 10 years.

The NSABP B-14 study found a much higher relative risk of endometrial cancer (RR, 7.5; 95% CI, 1.7-32.7).^ 65 ^ However, the incidence of disease in the placebo group was unusually low, making the relative risk appear quite high. When compared with population-based data from the SEER program, the relative risk dropped to 2.2. Other tamoxifen trials have not found a significant increased risk from tamoxifen, but these studies have been criticized for lack of statistical power, inadequate follow-up, and short duration of tamoxifen use.^ 66 ^

Among the chemoprevention trials described above, the Royal Marsden study reported that four women taking tamoxifen and one woman taking placebo developed endometrial cancer. In the BCPT, participants who received tamoxifen, compared with those who took placebo, had a 2.53 times greater risk of developing endometrial cancer (36 vs 15 cases; 95% CI, 1.35-4.97). This increased risk occurred mostly in women 50 years of age or older. All but one of the cases of endometrial cancer were stage 1.

Overall, these data suggest an increased risk of about two- to threefold for the development of endometrial cancer in postmenopausal women taking tamoxifen. The cancers appear to be of early stage and have a low potential for leading to premature death.^ 67 ^

Possible surveillance procedures to reduce the risk of endometrial cancer for women on tamoxifen include annual gynecologic examination, Papanicolaou (Pap) smear, transvaginal ultrasonography, and endometrial biopsy. An observational study of 357 women taking adjuvant tamoxifen for breast cancer and 130 controls (women with breast cancer but not taking tamoxifen) found that women treated with tamoxifen had significantly thicker endometrium on transvaginal ultrasound examinations (7.3 mm vs 2.5 mm) than did women not exposed to tamoxifen.^ 68 ^ Further testing, however, did not find any endometrial cancers in the tamoxifen group. Thus, current recommendations are to educate women about the risk of endometrial cancer and the early warning signs of abnormal bleeding, to perform annual pelvic examinations and Pap smears, and to do more extensive evaluations only in women with symptoms suggestive of endometrial cancer.^66,69^

In contrast to tamoxifen, raloxifene behaves as an estrogen antagonist in the endometrium, having no effect on endometrial proliferation. Several studies of postmenopausal women have shown no increase in endometrial thickening in women taking raloxifene.^53,70^ In the MORE trial of raloxifene chemoprevention, six cases of endometrial cancer occurred in the treated group and four cases in the placebo group (RR, 0.8; 95% CI, 0.2-2.7) by 40 months of follow up.^ 42 ^

### Venous Thromboembolic Disease

Another concern about the SERMs is their effect on vascular events. Few studies have reported on rates of thromboembolic events with tamoxifen or raloxifene. The EBCTCG meta-analysis noted a nonsignificant increase of one death per 5,000 women-years of tamoxifen due to pulmonary embolus.^ 40 ^ The number of deep vein thrombosis and pulmonary embolism events in the four breast cancer chemoprevention trials are shown in Table 6.

Table 6. Venous Thromboembolic Disease in Breast Cancer Chemoprevention Trials

| Number of Cases and Relative Risk, by Trial
Type of thromboembolic event | Royal Marsden Hospital Tamoxifen Chemoprevention Trial^ 6 ^ | Italian Tamoxifen Prevention Study^ 7 ^ | Breast Cancer Prevention Trial^ 25 ^ | Multiple Outcomes of Raloxifene Trial^ 42 ^
Deep vein thrombosis | Placebo: 2 Tamoxifen: 4 RR: N/A | Placebo: 3 Tamoxifen: 6 RR: N/A | Placebo: 22 Tamoxifen: 35 RR: 1.6 (0.91-2.86)* | Placebo: 5 Raloxifene: 38 RR: N/A
Pulmonary embolism | Placebo: 2 Tamoxifen: 3 RR: N/A | Placebo: 1 Tamoxifen: 1 RR: N/A | Placebo: 6 Tamoxifen: 18 RR: 3.0 (1.2-9.3) | Placebo: 3 Raloxifene: 17 RR: N/A

N/A = not applicable.

* 95 percent confidence interval in parentheses.

When stratified by age, the increased risk of pulmonary embolism seen in the BCPT was significant only for women 50 years of age or older (16 vs 5 cases; RR, 3.19; 95% CI, 1.12-11.15).^ 5 ^ In this study, three women in the tamoxifen group but none in the placebo group died from pulmonary embolism (statistical significance not given). The combined relative risk for deep vein thrombosis and pulmonary embolism in the MORE trial was 3.1 times higher (95% CI, 1.5-6.2) for women taking raloxifene than for women taking placebo.^ 42 ^ One death due to pulmonary embolism occurred among the women in the raloxifene groups. Both SERMs appear, therefore, to lead to a small increase in risk of thromboembolic events, especially in postmenopausal women.

### Other Adverse Effects

Generally, the adjuvant and chemopreventive trials have noted few other adverse effects of tamoxifen and raloxifene. In the BCPT study, the group of women taking tamoxifen had a small increased risk of developing cataracts and undergoing subsequent surgery (RR, 1.57; 95% CI, 1.16-2.14).^ 5 ^ Of participants in the tamoxifen group, 67.5 percent reported moderately to extremely bothersome hot flashes, whereas 50.4 percent in the placebo group noted these symptoms. Similarly, 29.0 percent of women taking tamoxifen noted moderately to extremely bothersome vaginal discharge, compared with 13.0 percent taking placebo. On a health-related quality of life questionnaire, participants taking tamoxifen in the BCPT reported a small but consistent excess of symptoms in the domain of sexual functioning.^ 71 ^ These symptoms did not lead to a reduction in the proportion of women in the tamoxifen group who were sexually active. Women in the MORE study reported hot flashes, influenza-like symptoms, leg cramps, and peripheral edema somewhat more frequently while taking raloxifene compared with women taking placebo.^ 42 ^

## Key Question No. 5: Costs of Breast Cancer Chemoprevention

Two studies have addressed the issue of cost-effectiveness of tamoxifen in the prevention of breast cancer. Applying a decision-analysis model with age-stratified cohorts to BCPT data, Noe and colleagues^ 72 ^ estimated the incremental cost-effectiveness of using tamoxifen compared with no intervention as prophylaxis in women at high risk for breast cancer. The perspective of the analysis was that of a payer; thus, the model included only direct medical costs, not out-of-pocket patient costs, time lost from work, nonmedical costs, or costs of surveillance for adverse effects. Effectiveness was measured in terms of additional years of life expectancy.

The base-case analysis -- taking tamoxifen for five years -- found an incremental cost of $63,896 per life-year gained for all women in the study. Costs ranged from $41,372 per life-year gained for women 35 to 49 years of age to $74,981 for women 60 to 69 years of age. Costs were lower for women with previous hysterectomies: $39,934 per life-year gained for women ages 35 to 49 years; $49,149 for women ages 50 to 59 years; and $56,370 for women ages 60 to 69 years.

Smith and Hillner^ 73 ^ used clinical data from the BCPT and cost data from AHRQ. They estimated the cost to reduce the risk of invasive breast cancer for one woman to be $292,523. Assuming that a woman in her early forties would gain 34.5 years of life if death from breast cancer were to be 100 percent prevented, the cost per additional year of life gained would be $8,479 ($292,523/34.5).

Generally, interventions that fall under a threshold of $50,000 per life-year gained are considered acceptable from an economic standpoint; many interventions that cost as much as $100,000 per life-year gained have been accepted. These cost analyses suggest that the use of tamoxifen to prevent breast cancer is quite cost effective in younger women ages 35 to 49 years and is close to an acceptable range for older women as well.