# Methods

This chapter of the SER documents the procedures that the RTI-UNC EPC used to develop this report on chemoprevention to prevent breast cancer. We document the literature search (e.g., inclusion and exclusion criteria and relevant Medical Subject Headings [MeSH terms]) and briefly describe the procedures followed in abstracting data from included articles, developing evidence tables, analyzing the literature, and subjecting the draft to a robust peer review process.

In all these steps, EPC staff collaborated with two members of the USPSTF who acted as liaisons for this topic (see Acknowledgments, Appendix A). The collaboration took place chiefly by electronic mail and one conference call. Steps in the development of this SER were presented at USPSTF meetings in May and September 1999 and February 2000 where the EPC staff and Task Force liaisons also were able to discuss the analytic framework and key questions, literature search strategy, results, and implications of the findings.

## Literature Search Strategy

Our search strategy involved two phases. The first phase used broad search terms and review criteria for article abstracts; the aim was to maximize the probability that all articles that could be useful in any way came to our attention. The second phase used more stringent review criteria for articles themselves to focus our attention on those papers that most directly answered the key questions. Thus, our initial search terms and abstract review criteria were quite inclusive. Many abstracts satisfied our search terms in our MEDLINE searches, and many of these abstracts satisfied the abstract review criteria.

In the second phase, we reviewed this large set of articles one by one, applying a more stringent set of review criteria. The aim at this point was to identify studies directly relevant to our key questions. Finally, we reviewed the smaller set of directly applicable articles in detail, abstracting them for the evidence table that appears in Appendix B. Where appropriate in the other parts of the SER, we cite articles that are not in the evidence table; these studies or materials may not directly address the key questions, but they do assist in interpretation of the articles in the evidence table.

### Inclusion/Exclusion Criteria

To identify articles relevant to the key questions of chemoprevention to prevent breast cancer, the EPC staff searched the MEDLINE database from 1966 to present. As defined by the analytic framework in Chapter 1 (Figure 1) and the key questions, the searches focused on the following areas:

1. The incidence of breast cancer in women who receive chemoprevention (Key Question 2);
2. Other beneficial effects of using chemopreventive agents to prevent breast cancer (Key Question 3);
3. The adverse effects of using chemopreventive agents to prevent breast cancer (Key Question 4); and
4. The costs of using chemopreventive agents to prevent breast cancer (Key Question 5).

We prospectively established inclusion and exclusion criteria for our MEDLINE searches (Table 2). Table 3 presents search strategy results, including the search terms used. We searched for agents other than SERMs but found none. As explained above, we also prospectively established review criteria for both abstracts and full articles. Table 4 presents both sets of review criteria. Table 5 presents the summary results from the literature searches and reviews.

Table 2. Breast Cancer Chemoprevention: General Inclusion and Exclusion Criteria

Category | Inclusion | Exclusion
Databases | MEDLINE | Other databases
Languages | English only | Other languages
Populations | Humans only | Animal studies
Study Design | Cost-effectiveness, systematic reviews, meta-analyses to be reviewed and analyzed separately | Letters, editorials, and non-systematic reviews that have no original data

Table 3. Breast Cancer Chemoprevention: Search Strategy Results

Step | | Number of Articles
1 | Explode breast neoplasms | 90,662
2 | Limit 1 to (human and female) | 70,714
3 | Explode Tamoxifen | 6,743
4 | Explode estrogen antagonists or raloxifene | 10,229
5 | Explode estrogen antagonists or keoxifen | 10,206
6 | Selective estrogen receptor modulator | 32
7 | 3 or 4 or 5 or 6 | 10,230
8 | 2 and 7 | 3,756
9 | Limit 8 to controlled clinical trial | 45
10 | Limit 8 to randomized controlled trials | 447
11 | Explode randomized controlled trials | 12,678
12 | Explode random allocation | 38,532
13 | Explode single-blind method | 4,241
14 | Explode double-blind method | 55,099
15 | 11 or 12 or 13 or 14 | 98,408
16 | 8 and 15 | 349
17 | 9 or 10 or 16 | 635

Table 4. Breast Cancer Chemoprevention: Review Criteria for Abstracts and Articles

Review Criteria for Breast Cancer Chemoprevention
Review Criteria for Abstracts; 1. randomized controlled trial; 2. either primary prevention or treatment of patients with breast cancer; 3. difference between arms of trial is tamoxifen or raloxifene; 4. outcome is incidence, mortality, recurrence, or disease-free interval
Review Criteria for Articles; 1. randomized controlled trial; 2. primary prevention only; 3. tamoxifen/raloxifene versus placebo; 4. outcome is incidence of or mortality from breast cancer

Table 5. Summary Results from Literature Searches and Reviews

Search and Review Steps | Number of Articles
Number of Abstracts
From literature search | 682
From supplemental search | 65
Reviewed | 243
Excluded at abstract review phase | 504
Included for full article review | 70
Number of Articles
Excluded after full review | 66
Included in Evidence Table | 4

To identify relevant articles not found by our MEDLINE search, we used systematic reviews, other reviews, meta-analyses, and practice guidelines that addressed chemoprevention to prevent breast cancer. Finally, we reviewed our own personal files and those of our Task Force liaisons, plus the bibliographies of articles included in the searches, to find further relevant articles that had not been found at earlier stages.

### Literature Reviewed

Four EPC staff independently reviewed the titles and abstracts of the articles identified by the literature searches and excluded ones that they agreed clearly did not meet eligibility criteria. When the initial reviewers disagreed or were uncertain, the articles were carried forward to the next review stage in which EPC team members reviewed the full articles and made a final decision about inclusion or exclusion by consensus.

## Literature Synthesis and Preparation of Systematic Evidence Review

We entered study design and outcomes data from the articles on chemoprevention for breast cancer into an electronic database (Microsoft Access); we constructed the evidence table in Microsoft Word.

To characterize the quality of the included studies, we rated the internal and external validity for each article in the evidence table using criteria developed by the USPSTF Methods Work Group.^ 49 ^ We then rated the aggregate internal validity and external validity as well as the coherence (consistency or agreement of the results of the individual studies) for each of the key questions in the analytic framework.

## Peer Review Process

We conducted a broad-based, external review of the draft SER. Outside reviewers were representatives of key primary care professional associations that have formal liaison ties to the USPSTF, a representative of the Canadian Task Force on Preventive Health Care, representatives of other professional societies, clinical experts in the area of breast cancer chemoprevention, staff from the Agency for Healthcare Research and Quality (AHRQ), and representatives of other relevant federal agencies. Appendix A lists the names and affiliations of all peer reviewers. We took all comments into account in revising the draft SER to produce this final SER.