# Appendix C Balance Sheets

Balance Sheet 1. Women 40 to 49 Years of Age, at Average Risk

| No Tamoxifen | Tamoxifen | Difference | NNT/NNH
Invasive breast cancer | 50 | 25 | −25 | NNT=400
Noninvasive breast cancer | 30 | 15 | −15 | NNT=667
Hip fracture | 2 | 1 | −1 | NS
Endometrial cancer | 10 | 26 | +16 | NNH=625
Stroke | 22 | 35 | +13 | NNH=770
Pulmonary embolism | 7 | 22 | +15 | NNH=667
Deep vein thrombosis | 24 | 39 | +15 | NNH=667

Note:Number of events prevented (negative number) or caused (positive number) over five years among 10,000 Women 40 to 49 years of age with 0.5 percent predicted five-year risk.NNT indicates number needed to treat; NNH, number needed to harm; NS, not significant.

Balance Sheet 2. Women 40 to 49 Years of Age, at High Risk

| No Tamoxifen | Tamoxifen | Difference | NNT/NNH
Invasive breast cancer | 200 | 103 | −97 | NNT=103
Noninvasive breast cancer | 106 | 53 | −53 | NNT=189
Hip fracture | 2 | 1 | −1 | NS
Endometrial cancer | 10 | 26 | +16 | NNH=625
Stroke | 22 | 35 | +13 | NNH=770
Pulmonary embolism | 7 | 22 | +15 | NNH=667
Deep vein thrombosis | 24 | 39 | +15 | NNH=667

Note:Number of events prevented (negative number) or caused (positive number) over five years among 10,000 Women 40 to 49 years of age with 0.5 percent predicted five-year risk.NNT indicates number needed to treat; NNH, number needed to harm; NS, not significant.

Balance Sheet 3. Women 50 to 59 Years of Age, at Average Risk

| No Tamoxifen | Tamoxifen | Difference | NNT/NNH
Invasive breast cancer | 100 | 51 | −49 | NNT=204
Noninvasive breast cancer | 35 | 18 | −17 | NNT=588
Hip fracture | 50 | 28 | −32 | NNT=313
Endometrial cancer | 40 | 160 | +120 | NNH=83
Stroke | 54 | 86 | +32 | NNH=313
Pulmonary embolism | 25 | 74 | +49 | NNH=204
Deep vein thrombosis | 27 | 43 | +16 | NNH=625

Note:Number of events prevented (negative number) or caused (positive number) over five years among 10,000 Women 40 to 49 years of age with 0.5 percent predicted five-year risk.NNT indicates number needed to treat; NNH, number needed to harm.

Balance Sheet 4. Women 50 to 59 Years of Age, at High Risk

| No Tamoxifen | Tamoxifen | Difference | NNT/NNH
Invasive breast cancer | 210 | 107 | −103 | NNT=97
Noninvasive breast cancer | 64 | 32 | −32 | NNT=313
Hip fracture | 50 | 28 | −32 | NNT=313
Endometrial cancer | 40 | 160 | +120 | NNH=83
Stroke | 54 | 86 | +32 | NNH=313
Pulmonary embolism | 25 | 74 | +49 | NNH=204
Deep vein thrombosis | 27 | 43 | +16 | NNH=625

Note:Number of events prevented (negative number) or caused (positive number) over five years among 10,000 Women 40 to 49 years of age with 0.5 percent predicted five-year risk.NNT indicates number needed to treat; NNH, number needed to harm.

Balance Sheet 5. Women 70 to 79 Years of Age, at Average Risk

| No Tamoxifen | Tamoxifen | Difference | NNT/NNH
Invasive breast cancer | 140 | 71 | −69 | NNT=145
Noninvasive breast cancer | 42 | 21 | −21 | NNT=476
Hip fracture | 339 | 188 | −151 | NNT=67
Endometrial cancer | 75 | 298 | +223 | NNH=45
Stroke | 342 | 538 | +196 | NNH=51
Pulmonary embolism | 89 | 266 | +177 | NNH=57
Deep vein thrombosis | 74 | 128 | +44 | NNH=228

Note:Number of events prevented (negative number) or caused (positive number) over five years among 10,000 Women 40 to 49 years of age with 0.5 percent predicted five-year risk.NNT indicates number needed to treat; NNH, number needed to harm.

Balance Sheet 6. Women 70 to 79 Years of Age, at High Risk

| No Tamoxifen | Tamoxifen | Difference | NNT/NNH
Invasive breast cancer | 310 | 158 | −152 | NNT=66
Noninvasive breast cancer | 95 | 48 | −47 | NNT=213
Hip fracture | 339 | 188 | −151 | NNT=67
Endometrial cancer | 75 | 298 | +223 | NNH=45
Stroke | 342 | 538 | +196 | NNH=51
Pulmonary embolism | 89 | 266 | +177 | NNH=57
Deep vein thrombosis | 74 | 128 | +44 | NNH=228

Note:Number of events prevented (negative number) or caused (positive number) over five years among 10,000 Women 40 to 49 years of age with 0.5 percent predicted five-year risk.NNT indicates number needed to treat; NNH, number needed to harm.