# Appendix B Evidence Table 1

## Glossary of Evidence Table Abbreviations

ARI: absolute risk increase

ARR: absolute risk reduction

CI: confidence interval

DCIS: ductal carcinoma in situ

dl: deciliter

DVT: deep vein thrombosis

ER: estrogen receptor

f/u: follow up

HRT: hormone replacement therapy

mg: milligrams

mo(s): month(s)

NA: not applicable

NNH: number needed to harm

NNT: number needed to treat

NR: not reported

PE: pulmonary embolism

RR: relative risk

yr(s): year(s)

Evidence Table 1. Chemoprevention for Breast Cancer Prevention

Source: Author, Year, Study Population | Sample Size/Compliance/Attrition/Time Frame | Randomization/Intervention | Results: Benefits | Results: Harms | Conclusions/Comments/Quality Issues
BCPT P-1 Trial: Fisher et al., 1998^ 5 ^ Healthy women with increased breast cancer risk (equal to 60 yrs old woman or having lobular carcinoma in situ; RR, 1.66% by Gail model) Ages 39-49: 39% Ages 50-59: 31% Ages >60: 30% None on HRT | 13,388 randomized 13,175 analyzed 21.6% discontinued drug (19.7% placebo, 23.7% tamoxifen) 92% complete f/u 1992-1997 median f/u: 54.6 mos | Placebo: 6,707 Tamoxifen: 6,681 Dose: 20 mg/dl for 5 yrs | Invasive Breast Cancer Placebo: 175 cases Tamoxifen: 89 cases Incidence Density Placebo: 6.8/1000 women Tamoxifen: 3.4/1000 women RR, 0.51 (95% CI, 0.39-0.66) Cumulative Incidence (69 mos) Placebo: 4.3% Tamoxifen: 2.2% ARR: 2.1% NNT: 48 (in 69 mos) Noninvasive Breast Cancer Placebo: 69 cases Tamoxifen: 35 cases Incidence Density Placebo: 2.7/1000 women Tamoxifen: 1.4/1000 women RR, 0.50 (95% CI: 0.33-0.77) Cumulative Incidence (69 mos) Placebo: 1.6% Tamoxifen: 0.8% ARR: 0.8% NNT: 125 (in 69 mos) Effect only in ER + tumors Breast Cancer Mortality Placebo: 6 deaths Tamoxifen: 3 deaths | Endometrial Cancer Placebo: 15 cases Tamoxifen: 36 cases RR, 2.53 (95% CI, 1.35-4.97) ARI: 0.14% NNH: 714 (in 5 yrs) DVT Placebo: 22 cases Tamoxifen: 35 cases RR, 1.60 (95% CI, 0.91-2.26) ARI: 0.05% NNH: 2,000 (in 5 yrs) PE Placebo: 6 cases Tamoxifen: 18 cases RR, 3.01 (95% CI, 1.15-9.27) ARI: 0.05% NNH: 2,000 (in 5 yrs) Stroke Placebo: 24 cases Tamoxifen: 38 cases RR, 1.59 (95% CI, 0.93-2.77) ARI: 0.05% NNH: 2,000 (in 5 yrs) New Cataracts Placebo: 507 Tamoxifen: 574 RR, 1.14 (95% CI, 1.01-1.29) ARI: 0.31% NNH: 322 (in 5 yrs) All-Cause Mortality Placebo: 71 Tamoxifen: 57 RR, 0.81 (95% CI, 0.56-1.16) | Tamoxifen reduced incidence of invasive and noninvasive breast cancer by 50% in women at increased risk (all age groups, all risk levels). Nonsignificant increase in total ischemic heart disease rate: Placebo: 62 events Tamoxifen: 71 events RR, 1.15 (95% CI, 0.81-1.64) Nonsignificant decrease in fracture events: Placebo: 137 fractures Tamoxifen: 111 fractures RR, 0.81 (95% CI, 0.63-1.05) Power adequate for primary outcomes Intention-to-treat analysis Quality Grade Good
Royal Marsden Trial: Powles et al., 1998^ 6 ^ Healthy women ages 30-70 yrs with family history of breast cancer Median age: 47 yrs 25.6% on HRT during trial | 2,494 randomized 2,471 analyzed 877 discontinued drug (176 placebo, 320 tamoxifen for side effects, P<0.0005) 280 lost to f/u 1986-1996 median f/u: 70 mos | Placebo: 1,244 Tamoxifen: 1,250 Dose: 20 mg/dl for 8 yrs | All Breast Cancer Placebo: 36 cases (4 DCIS) Tamoxifen: 34 cases (4 DCIS) Incidence Density Placebo: 5.0/1000 Tamoxifen: 4.7/1000 RR, 1.06 (95%, CI 0.7-1.7) Cumulative Incidence [estimated from Figure 2] (11 yrs) Placebo: 5.6% Tamoxifen: 6.0% ARI: 0.4% NNT: NA Breast Cancer Mortality Placebo: 1 death Tamoxifen: 4 deaths | Endometrial Cancer Placebo: 1 case Tamoxifen: 4 cases DVT Placebo: 2 cases Tamoxifen: 4 cases PE Placebo: 2 cases Tamoxifen: 3 cases All-Cause Mortality Placebo: 6 deaths Tamoxifen: 9 deaths | No evidence of effect of tamoxifen in reducing incidence of breast cancer in women with positive family history of breast cancer 90% power to detect a 50% reduction in breast cancer at α=0.05 level Intention-to-treat analysis Quality Grade Good
MORE Trial: Cummings et al., 1999^ 42 ^ Postmenopausal women with osteoporosis, less than 80 yrs of age Median age: 66.5 yrs None on HRT | 7,705 randomized 92% took at least 80% of study drug during duration of f/u 1,804 dropped out by end of third yr (25% placebo, 22% raloxifene) 1994-1998 median f/u: 40 mos | 3 arms: Placebo: 2,576 Raloxifene A: 2,557 Raloxifene B: 2,572 Total Raloxifene: 5,129 Group A Dose: 60 mg/dl for 3 yrs Group B Dose: 120 mg/dl for 3 yrs A and B groups combined for analysis - no difference between them | All Breast Cancer Placebo: 32 cases Raloxifene: 22 cases Incidence Density Placebo: 4.3/1000 Raloxifene: 1.5/1000 RR, 0.35 (95% CI, 0.21-0.58) Cumulative Incidence [estimated from Figure] (4 yrs) Placebo: 1.2% Raloxifene: 0.4% ARR: 0.8% NNT: 125 (in 4 yrs) Invasive Breast Cancer Placebo: 27 cases Raloxifene: 13 cases RR, 0.24 (95% CI, 0.13-0.44) Estrogen Receptor + Breast Cancer Placebo: 20 cases Raloxifene: 4 cases RR, 0.10 (95% CI, 0.04-0.24) Breast Cancer Mortality NR | Endometrial Cancer Placebo: 4 cases Raloxifene: 6 cases RR, 0.8 (95% CI, 0.2-2.7) DVT Placebo: 5 cases Raloxifene: 18 cases PE Placebo: 3 cases Raloxifene: 10 cases RR (for both DVT and PE): 3.1 (95% CI, 1.5-6.2) New or Worsening Type 2 Diabetes Mellitus Placebo: 0.5% Raloxifene: 1.2% P=0.0009 No significant difference in changes in glycemic levels or diabetes medications All-Cause Mortality Placebo: 1.0% Raloxifene: 0.8% | Raloxifene reduced incidence of breast cancer by 65% over 40 mos in post-menopausal women with osteoporosis (76% reduction in invasive cancer; 90% reduction in estrogen receptor positive breast cancer). Power calculations NR Intention-to-treat analysis Quality Grade Good
Italian Trial: Veronesi et al., 1998^ 7 ^ Healthy women ages 35-70 yrs with hysterectomy (benign) Median age: 51 yrs 14% on HRT (from secondary source) | 5,408 randomized 5,378 with complete data 1,422 dropped out of study (301 because of side effects) 33 lost to f/u 1992-1997 median f/u: 46 mos | Placebo: 2,700 Tamoxifen: 2,708 Dose: 20 mg/dl for 5 yrs | All Breast Cancer Placebo: 22 cases Tamoxifen: 19 cases Women on treatment 1 yr or longer Placebo: 19 cases Tamoxifen: 11 cases P=0.16 Cumulative Incidence (40 mos) Placebo: 0.8% Tamoxifen: 0.7% ARR:0.1% NNT: 1000 (in 40 mos) Placebo+HRT: 8 cases Tamoxifen+HRT: 1 case ARR: 1.3% NNT: 77 (in 40 mos) No difference by ER status Breast Cancer Mortality None | Endometrial Cancer NA DVT Placebo: 3 cases Tamoxifen: 6 cases PE Placebo: 1 case Tamoxifen: 1 case Superficial Phlebitis Placebo: 9 cases Tamoxifen: 33 cases Cerebrovascular Ischemic Events Placebo: 5 (0 strokes) Tamoxifen: 9 (5 strokes) All-Cause Mortality Placebo: 9 deaths Tamoxifen: 6 deaths | No evidence of effect of tamoxifen in reducing incidence of breast cancer in women with hysterectomies Women in study at lower risk of breast cancer compared to other studies 34% power to detect a 33% reduction in breast cancer at α=0.05 level Intention-to-treat analysis Quality Grade Good