# Appendix A Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency for Healthcare Research and Quality(AHRQ) (Task No. 3 to support the U.S. Preventive Services Task Force [USPSTF]). We acknowledge the ongoing guidance and assistance of David Atkins, MD, MPH, Director of the Preventive Services Program at AHRQ, and the continuing support of Jacqueline Besteman, JD, MA, Director of the AHRQ Evidence-based Practice Program. We especially want to thank our USPSTF liaison, Steven Woolf, MD, MPH, Virginia Commonwealth University, Fairfax, VA.

The investigators deeply appreciate the considerable support and contributions of faculty and staff from the University of North Carolina at Chapel Hill -- Timothy S. Carey, MD, MPH; Michael Pignone, MD, MPH; Barbara E. Starrett, MHA; Alyssa Wood, MFA; and Catherine Mills Burchell, MA. We would also like to thank the following RTI staff: Kathleen N. Lohr, PhD; Anjolie Idicula Laubach, BA; Sonya Sutton, BSPH; Sheila White; and Loraine Monroe.

In addition, we would like to thank the following peer reviewers for their thoughtful and constructive comments: Erica Frank, MD, Emory University, Atlanta, GA; Michael L. LeFevre, MD, MSPH, University of Missouri School of Medicine, Columbia, MO; Mary Mitchell, American College of Obstetricians and Gynecologists, Washington, DC; Jean-Marie Moutquin, MD, MSc., FRSC(C), Canadian Task Force, Sherbrooke, Quebec; Debbie Saslow, MD, American Cancer Society, Atlanta, GA; Mark Somerfield, PhD, American Society of Clinical Oncology, Alexandria, VA; and Donald Wickerham, National Surgical Adjuvant Breast and Bowel Project Operations Center, Pittsburgh, PA.