# Discussion

## Summary of Findings

We conducted this systematic review to assist the USPSTF in updating their 2002 and 2003 physical activity and healthful diet counseling recommendations.24,26 Our review focused on the effectiveness and harms of primary care relevant counseling interventions across three distinct topics: physical activity, healthful diet, and the combination of these two. We included a total of 66 fair- or good-quality randomized controlled trials published after 1989 that evaluated these counseling interventions.

Building on the 2003 healthful diet review, we found evidence (39 trials; n=76,088) confirming the benefit of medium- or high-intensity dietary counseling interventions, with or without concomitant physical activity counseling. This benefit was apparent despite the fact that we excluded counseling targeted to people with established CVD risk factors and/or those being medically managed for risk factors (e.g., hypertension, dyslipidemia, diabetes). Similar to the prior review, we found that less-intensive dietary counseling interventions did not produce significant behavioral changes. By expanding the scope of this review to include important physiological outcomes, we found small but statistically significant improvements in adiposity, blood pressure, and lipids in high-intensity healthful diet counseling (with or without concomitant physical activity counseling) in 28 trials (n=62,285).

Building on the 2002 physical activity review, we found evidence that contrasts with the results of the prior review, largely based on 28 new trials (only two of the eight trials from the prior review were included). Based on 30 trials targeting physical activity counseling only (n=15,265) and an additional 14 trials (n=5,054) examining combined lifestyle counseling, we found that medium- and high-intensity physical activity counseling interventions (with or without concomitant dietary counseling) improved self-reported physical activity, but only clearly improved adiposity and blood pressure when combined with dietary counseling. However, many physical-activity only trials did not report adiposity, blood pressure, or lipid outcomes. Similar to the previous review, no consistent behavioral benefit was found for low-intensity behavioral counseling to increase physical activity. These data were inconsistent (four of 11 trials showed a benefit), however, suggesting that some low-intensity interventions might be effective.

Magnitude, duration, and clinical interpretation of effects on adiposity, blood pressure, and lipids. High-intensity counseling for healthful diet (with or without concomitant physical activity counseling) results in statistically significant, albeit small, reductions in adiposity, blood pressure, and total and LDL cholesterol. This is based on 16 healthful diet (n=58,557) and 14 combined lifestyle (n=3,855) counseling trials (Table 9, Appendix G, Figures 1, 3, 5,7,9). There is limited evidence suggesting that these reductions in physiologic measures persist beyond 12 months. We found that focused physical activity interventions alone were insufficient to affect adiposity, blood pressure, or lipids, despite increasing physical activity. However, these outcomes were less commonly reported (k=8; N=3,731) (Table 9).

Table 9 Summary of Evidence By Key Question

No. of studies (k) | Design | Major limitations | Consistency | Applicability | Overall quality | Summary of findings
KQ1. Do primary care-relevant behavioral counseling interventions for physical activity and/or healthful diet reduce cardiovascular disease (CVD) in adults?
k=3 n=50,769 | RCT | Only 3 HD trials. Two trials with observational followup after trials were completed. | Fair. Trials evaluated different interventions in different populations. | Fair. Largest trial in post-menopausal women. Two trials in pre-HTN. | Fair-Good | In the WHI, high-intensity general low-fat counseling did not statistically significantly decrease major CVD events at 8.1 years. Observational followup of TOHP I and II showed that high-intensity sodium reduction counseling in pre-HTN decreased CVD events and revascularization at 10–15 years.
KQ2. Do primary care-relevant behavioral counseling interventions for physical activity and/or healthful diet improve intermediate outcomes (e.g., adiposity, blood pressure, lipids) in adults?
Evidence for physical activity counseling alone
PA only: k=8, n=3731 | RCT | Intermediate outcomes not commonly reported. | Good. | Fair. Only one trial conducted in the US. Only one low- intensity trial. | Fair-Good | Sparsely reported. Pooled estimates showed that mostly medium-intensity counseling did not improve adiposity, blood pressure, or lipids. Two trials did show statistically signficant group differences in adiposity, blood pressure, or lipids; however, the remaining trials did not.
Evidence for healthful diet counseling with or without physical activity counseling
HD only: k=16 n=58,557 CL: k=14 n=3,855 Meta-analysis: k=28 n=60,799 | RCT | Very high I^2^ for adiposity meta- analyses. Limited evidence beyond 12 months. | Fair. HD and CL trials were not distributed consistently by intervention intensity and population risk. | Good. | Fair | High-intensity counseling for healthful diet results in statistically significant reductions in adiposity, blood pressure, and total and LDL cholesterol. BMI was reduced by approximately 0.3 to 0.7 kg/m^2^. Systolic and diastolic blood pressures were reduced by 1.5 and 0.7 mmHg. Total and LDL cholesterol were reduced by 0.17 and 0.13 mmol/L (6.56 and 5.02 mg/dL), respectively. No statistically significant changes were seen for HDL and triglycerides.
KQ3. Do primary care-relevant behavioral counseling interventions for physical activity and/or healthful diet change associated health behaviors in adults?
Evidence for change in physical activity
PA only: k=30 n=15,265 CL: k=15 n=4,975 Meta-analysis: k=39 n=18,517 | RCT | Wide variety in measurement of physical activity. Mostly self-reported measures. Egger test positive. Limited evidence beyond 12 months. | Fair. PA and CL trials were not distributed consistently by intervention intensity and population risk. | Good. Most trials conducted in persons selected for sedentary behavior or some increased risk for CVD. | Fair | Medium- to high-intensity interventions improved self- reported measures of physical activity, by approximately 38 minutes per week. Although baseline levels of physical activity varied across trials, this modest increase meant that most persons exercised for at least 1 hour per week. Results for the effectiveness of low-intensity counseling were mixed. Although the pooled estimate was not statistically significant, 4 trials (2 of which were not in the meta-analysis) showed statistically significant improvements in self-reported activity levels.
Evidence for change in dietary intake
HD only: k=25 n=71,267 CL: k=16 n=4,951 Meta-analysis: k=34 n=74,152 | RCT | High I^2^ for all dietary intake meta- analyses. Mostly self-reported measures. Egger test positive for total fat dietary intake. Limited evidence beyond 12 months. | Fair. HD and CL trials were not distributed consistently by intervention intensity and population risk. | Good. | Fair | High-intensity counseling showed an approximate 7–11% decrease in total energy consumption. Although there was high statistical heterogeneity amongst pooled trials, there appeared to be a dose effect with intervention intensity. High-intensity counseling resulted in moderate to large reductions in self-reported fat intake, 5.9–11% decrease in energy from total fat, and 2.8–3.7% decrease in energy from saturated fat. Low- to medium-intensity interventions resulted in smaller changes. For low- to high-intensity counseling, there were moderate to large increases in fruit and vegetable intake, about 0.4–2 servings/day.
KQ4. What are the adverse effects of primary care-relevant behavioral counseling interventions for physical activity and/or healthful diet in adults?
Evidence for harms of physical activity or counseling to improve physical activity
Trials: k=2, n=483 Observational studies: k=7, n=4,354 cases | RCT Case-crossover | Adverse events only reported in 2 of 30 trials. Case-crossover design; difficult to measure habitual PA. | Good. | Fair. Observational studies often limited to nonfatal cases, cases primarily in men (range 57–100% male). Only 1 trial reported absolute risk of cardiac event during vigorous physical activity. | Fair | In 2 trials, almost 25% of participants reported mild muscular fatigue, strain, or soreness. In observational studies, risk of serious cardiac event was increased during vigorous physical activity. This increased risk was much greater in people with low levels of habitual physical activity. However, the absolute risk of cardiac event was very small.
Evidence for harms of healthful diet or counseling to improve diet
HD only: k=25 n=71,267 CL: k=16 n=4,951 | RCT | Explicit adverse events not reported in trials. | Good. | Good. | Fair | No specific examination of adverse effects, but two trials showed an increased intake of carbohydrates, although no increase in overall energy intake. Overall, few trials reported dietary intake of mono- or polyunsaturated fats, carbohydrates, or sugars.

CL – counseling; CV – cardiovascular; CVD – cardiovascular disease; HD – healthful diet; HDL – high-density lipoprotein; HTN – hypertension; LDL – low-density lipoprotein; PA – physical activity; TOHP – Trial of Hypertension Prevention; US – United States; WHI – Women’s Health Initiative

Although the included dietary and combined lifestyle counseling trials did not address weight loss as a direct goal of the intervention, they did have a modest effect on weight. Medium- to high-intensity dietary interventions (with or without concomitant physical activity counseling) decreased BMI approximately 0.3 to 0.7 kg/m^2^ at 12 months. Five trials evaluating high-intensity counseling had followup beyond 12 months and this reduction in BMI persisted up to 72 months, although this result was slightly attenuated.104,119,123,124,127 These changes may be clinically meaningful since epidemiological data suggest that the risk for both CVD and diabetes increase with each kg/m^2^ unit change in BMI.142 It is unclear, however, if small sustained reductions in BMI after the intervention’s conclusion translate into better cardiovascular health outcomes.

Blood pressure was improved in several types of healthful diet and combined lifestyle counseling interventions, at least over the short term. High-intensity diet and lifestyle interventions decreased blood pressure by approximately 1.5 mmHg and 0.7 mmHg systolic and diastolic, respectively, at 12 months (Appendix G, Figures 3 and 5). These changes were persistent although slightly attenuated in the three intensive salt-restriction counseling interventions in persons with mildly elevated diastolic blood pressure.87,98,143 Four other trials reported followup beyond 12 months, and none of these trials showed a statistically significant reduction by the trial’s end.104,119,124,127 Observational followup of TOHP I and II suggest that these blood pressure reductions could reduce incidence of CVD event in the long term, over 10 to 15 years.109 However, in the WHI, there were no significant reductions in major CVD events at 8 years followup in post-menopausal women in the intervention group who had blood pressure reductions of less than 1 mmHg, compared with women in the control group.140 Although these reductions in blood pressure were smaller than those seen in hypertension drug trials and feeding trials (in which participants are fed study-provided diets specifically designed to reduce hypertension),144,145 epidemiologic data suggest that even small changes in blood pressure (e.g., 2 mmHg systolic blood pressure) can decrease the risk of coronary heart disease by 6 percent or stroke by 16 percent.146

High-intensity diet and combined lifestyle counseling decreased total cholesterol by 0.17 mmol/L (6.56 mg/dL) and LDL by 0.13 mmol/L (5.02 mg/dL) (Appendix G, Figure 7).77,96,110,123,124,127 Of the three trials that reported followup beyond 12 months, two trials conducted exclusively in women demonstrated a persistent decrease in total cholesterol or LDL at 18 or 54 months.124 There was no statistically significant increase in HDL. Based on randomized controlled trials in primary prevention, a reduction of 0.6 mmol/L (23.17 mg/dL) in total serum cholesterol can reduce coronary heart disease by approximately 25 percent.147 However, in the WHI, there were no significant reductions in major CVD events at 8 years in post-menopausal women in the intervention group who had small net LDL reductions of approximately 0.09 mmol/L (3.55 mg/dl) at 3 years.140

Magnitude, duration, and clinical interpretation of effects on self-reported healthful diet and physical activity behaviors. Based on all the included trials (k=66; N=90,194), medium- to high-intensity counseling interventions improved self-reported dietary intake of energy, fats, and fruits and vegetables, objectively measured urinary sodium, and self-reported physical activity (Table 9). Behavioral changes in these trials were generally consistent in terms of effects on physiologic measures of adiposity, blood pressure, and lipids.

Overall, high-intensity diet-only and combined lifestyle counseling interventions showed a small to moderate reduction in energy consumption, approximately a 7 to 11 percent decrease in kcal/day depending on the baseline caloric intake of trial participants. Three of these trials showed statistically significant reductions in caloric intake up to 72 months.104,124,127 These changes in caloric intake are consistent with the findings of small reductions in weight. Diet and combined lifestyle counseling interventions also decreased self-reported total fat and saturated fat intake, and increased self-reported fruit and vegetable consumption. Although there was high statistical heterogeneity amongst pooled trials, there appeared to be a dose effect with intervention intensity (Appendix G, Figures 11 and 13). High-intensity counseling resulted in moderate to large reductions in self-reported fat intake—5.9 to 11 percent decrease in energy from total fat and 2.8 to 3.7 percent decrease in energy from saturated fat. Four trials had longer-term followup, up to 72 months, in which reductions in total fat and saturated fat were still significant.104,123,124,127 Low- and medium-intensity interventions resulted in smaller reductions in fat intake. None of the low- or medium-intensity counseling trials had followup beyond 12 months. There likely is some publication or selective reporting bias with total dietary fat outcomes, as the Egger’s statistical test for small study effects is positive. For low-, medium-, and high-intensity interventions, there was a moderate to large increase in fruit and vegetable intake, approximately 0.4 to 2 servings per day. Only two trials had followup beyond 12 months, which showed a persistent increase in fruit and vegetable intake at 24 and 72 months.42,104 Although the specific health effects of dietary behavior change are not clear, limited epidemiological data suggest that moderate to large changes in dietary behavior are likely to be associated with lower CVD rates.26,148,149

The medium-intensity physical activity counseling interventions resulted in an approximate 38-minute increase in physical activity per week. While baseline activity levels in trials varied, it appeared that most participants in these trials would have received at least 1 hour per week of physical activity if they increased their activity level by 38 minutes per week. One study suggested that support in maintaining recent increases in physical activity improves adherence.62 While followup beyond 12 months was very rare, changes in activity level were maintained in one moderate-intensity physical activity trial76 and one high-intensity combined lifestyle counseling trial.124 Epidemiological evidence suggests that participating in only 60 minutes of physical activity per week can lower the risk of all-cause mortality and coronary heart disease, but benefits are most clearly documented among adults who regularly get at least 150 minutes per week.6 More physical activity appears to provide more benefit, and it is unclear if there is a ceiling beyond which benefits do not continue to accrue.6 Other studies of physical activity have shown that at least 1,200 kilocalories per week of physical activity (roughly equivalent to 2.5 hours per week of vigorous physical activity) reduce total cholesterol and triglycerides by 4 to 7 percent.150 Physical activity changes of these magnitude were not seen in the trials included in this review, and, not surprisingly, blood lipids were unaffected by these interventions.

Adverse effects. There were no increased serious injuries from physical activity or unintended adverse changes in dietary intake, based on available counseling trials. In two trials, there was a paradoxical increase in carbohydrates, but not overall caloric intake. The clinical significance of these dietary changes is unclear. In the WHI, the replacement of fat intake with complex carbohydrates, over 6 years, was not associated with clinical adverse effects on lipid profiles.151 Seven additional observational studies suggest, however, that there was an increased risk of serious cardiac events during vigorous physical activity, primarily in persons with low levels of habitual activity. However, the absolute risk of serious cardiac events related to physical activity appears to be extremely small. Minor musculoskeletal injuries were fairly common, however, when participants increased their physical activity from habitual levels. Type and total amount of activity, and relative change in activity were all important factors in determining the risk of injury. Non-contact, low-impact activities such as walking, bicycling, and swimming had lower injury rates. Increasing physical activity in a series of small increments, each followed by an adaptation period, resulted in lower rates of injury.141 Additional information regarding harms of physical activity are detailed in the DHHS 2008 report on physical activity.141

## Considerations for Applicability of Findings

Distribution of evidence across type of counseling, intervention intensity, and population risk. This review included a body of literature with considerable heterogeneity. The major sources of heterogeneity were type of counseling (physical activity, diet, or both), intervention intensity, and the risk status of the patient. There is substantial evidence supporting the effectiveness of dietary counseling (with or without physical activity counseling) for changing adiposity, blood pressure, and lipids. The physical activity only counseling literature, however, had a smaller proportion of trials that used physiologic outcomes measures. All types of counseling, either alone or in combination, appeared to improve self-reported dietary and physical activity behaviors. The literature, however, did not evenly study all intensities of behavioral counseling interventions (Table 9). For example, only one physical activity counseling trial evaluated a high-intensity intervention, while only one combined lifestyle intervention trial evaluated a low-intensity intervention. The lack of high-intensity physical activity trials is largely due to the fact that we excluded trials providing supervised scheduled physical activity sessions.

Counseling interventions ranged from low-intensity counseling (e.g., conducted in single sessions or by mail alone) to very high-intensity interventions (e.g., up to 20 sessions over a 2-year period). Trials were distributed across three categories of study population risk (unselected, selected for behavioral factors, selected for increased cardiovascular risk) (Table 9). We had difficulty disentangling the effects of intervention intensity from the populations’ risk status when attempting to examine whether counseling improved health or behavioral outcomes. Depending on the body of literature, intervention intensity could correlate with population risk or could not. Among the healthful diet counseling trials, low-intensity interventions were almost all conducted in general-risk persons, and medium- to high-intensity interventions were mostly conducted among persons selected for poor dietary intake or with elevated risk for CVD. In contrast, almost all the physical activity counseling trials were conducted in persons not meeting recommended levels of physical activity. These trials were also somewhat evenly distributed between low- and medium-intensity interventions, and there was only one high-intensity counseling intervention. The combined lifestyle counseling interventions showed a very different distribution in that medium-intensity trials tended to target patients selected for risk factors related to CVD while high-intensity trials primary involved unselected populations.

Intervention considerations. Almost all of the effective medium- to high-intensity interventions were delivered by specially trained health educators or nurses, counselors or psychologists, dietitians or nutritionists, or exercise instructors or physiologists. Very few of these interventions involved the primary care physician at all. Interventions with significant benefit beyond 12 months were all high-intensity counseling interventions (up to 20 sessions) with group, phone, or mail contact throughout the trial. Many of the high-intensity interventions trials required resources that are not currently available or paid for in the current health system. Similarly, many of the low-intensity interventions required health system considerations that may not be readily available, such as computer support to generate “tailored” mailed feedback, automated phone calls, or ongoing phone followup. Low-intensity dietary counseling interventions showed small, but statistically significant, improvement in self-reported fat and fruit and vegetable intake. Evidence for low-intensity physical counseling interventions on increasing self-reported physical activity was mixed.

Other population considerations. There were fewer men represented in these trials, with men representing approximately 17 percent of all the trials’ participants. This is largely due to the inclusion of the WHI (n=48,835), which enrolled only women. The proportion of males rose to 35 percent when the WHI was excluded. This proportion was adequate to allow application of the overall findings of this review to men. Among the 38 trials conducted in the United States, approximately 18 percent were nonwhite, ranging from 3 to 100 percent. Trials were primarily conducted in middle-aged adults, with a mean age of 59 years, and a range from 20 to 78 years. Based on meta-regressions of these variables, there is no reason to believe that intervention effectiveness would vary significantly by age, sex, or race/ethnicity, although these analyses were purely exploratory and the study-level effects of these variables may not mirror the effects seen within individual trials. Evidence directly applicable to older adults is primarily available for physical activity counseling. Nine of the trials42,44,50,58,64,69,71,80,92 were explicitly conducted in older adults, selected for age 60 years or older, seven42,44,50,58,64,69,71 of which involved only physical activity counseling. Each of these seven trials showed that medium- to high-intensity counseling increased physical activity. Fruit and vegetable intake in those targeting dietary change reported results similar to those apparent in other age groups.80,92

## Limitations

In addition to the heterogeneity of trials limiting confidence in the pooled estimates of effect sizes for some outcomes, there are other limitations to consider for this body of evidence.

This updated review represents only a subset of the diet and physical activity counseling literature. In order to focus the review to support the USPSTF’s decisionmaking, we excluded some related bodies of literature, including trials focusing on populations with known disease (including hypertension, dyslipidemia, diabetes, or coronary heart disease); dietary counseling trials to prevent cancer, unless the trial had an explicit objective to reduce both CVD and cancer; and counseling trials that focused on weight loss or weight management. We also excluded trials without a true control arm (e.g., usual care, minimal intervention, attention control, waitlist control). Therefore, we did not address literature that assessed the comparative effectiveness of different types of behavioral counseling and intervention elements. We only included counseling interventions that could be conducted in primary care or referred from primary care. Therefore, worksite, school-based, community-based, public health, economic and policy oriented, or media-based interventions are not addressed in this review. For these types of interventions focused on improving diet and physical activity, we refer to the CDC Community Task Force.152

The majority of trials were short term and provided only 6 or 12 months followup. Only 11 of the 66 trials had followup beyond 12 months.42,59,76,87,98,101,104,119,120,124,127 These trials with longer followup involved high-intensity interventions with ongoing maintenance sessions throughout the trial period. Thus, even with longer-term followup, relatively little is known from this body of evidence about the maintenance of beneficial behavior or physiologic change after an active intervention ceases. Also, given the limited duration of followup, it is not surprising that only three trials reported health outcomes.98,101,106 Our categorization of counseling interventions primarily addresses the intensity (minutes of in-person contact) rather than duration (period of time over which counseling was delivered) of the intervention. Although most of the high-intensity interventions last over a period of several months, this period ranged from 1 to 24 months.

In addition to the limited duration of followup, many of the trials relied on self-reported behavioral outcome measures. Only 36 percent of trials reported any objectively measured intermediate outcomes. Measurement of behavioral outcomes varied across trials, and both dietary and physical activity behaviors can be difficult to measure validly and reliably. Dietary intake was generally measured by food frequency questionnaires, food diaries, and 24-hour food recalls. Each of these methods can be prone to bias.153 For physical activity, the various forms of physical activity, the episodic nature of some types of activity, and the subjective nature of people’s assessment of intensity make it difficult to get precise information on physical activity levels. Only seven of the studies reporting physical activity outcomes used objective measures (pedometer, accelerometer, actigraph), and this measure was always used in addition to a self-reported measure.50,53,55,69,72,112,121,124 Results were generally consistent between self-reported and objective measures, although two studies reported no between-group differences in objective measures but found statistically significant differences in self-reported activity.72,121 It is reassuring that the behavioral outcome results in this review were consistent with results using intermediate outcomes.

There were also limitations posed by the quantitative pooling of results. Six of the 66 trials did not report outcome data necessary to include in any quantitative pooling of results. Of the data included in the meta-analyses, some degree of calculation was necessary to include the majority of trials (86 percent) in the meta-analyses, although only a small percentage (12 percent) required statistical judgment. In these instances, we erred on the side of avoiding a type I error or overestimation of effect size. Sensitivity analysis showed that our methods for calculating missing data for the meta-analyses likely had little effect on overall results, and this effect was attenuated by effect size. In some instances, trials were simply excluded from the meta-analysis if they reported insufficient outcome data or noncomparable outcomes.

Other considerations include risk of bias due to including only published data, potential selective reporting of outcomes, and including trials that used volunteer participants. Egger’s statistical test for small study effects was significant only for self-reported total dietary fat intake and self-reported physical activity level among the physical-activity counseling trials. Sensitivity analyses excluding the small studies with large effects, however, still demonstrated a positive effect of physical activity counseling.

## Future Research

Although this is a very large body of literature, good-quality trial evidence is still needed to fully evaluate the longer-term health impacts of diet, physical activity, and combined lifestyle counseling interventions across a range of patients using counseling interventions that are most applicable to primary care. More trials are needed to evaluate low-intensity counseling interventions that would be more readily implemented in primary care, or medium-intensity interventions that could be referred to from primary care. Many of the high-intensity interventions would require resources that are not currently available or paid for in the current health system (not to mention issues concerning real-world patient adherence). Many of the high-intensity interventions were conducted among participants selected for increased risk of CVD. It is important to examine if the effectiveness of these interventions is reproducible in more unselected populations, or if counseling should indeed be targeted only to those selected for pre-clinical disease (e.g., impaired fasting glucose, pre-hypertension). In addition, trials with longer-term followup are crucial to understanding the maintenance effects of behavioral and physiologic changes after an intervention has ended.

This review was unable to address the effectiveness of specific intervention elements, which would likely be helped by more complete and consistent reporting of counseling intervention elements, replication of intervention approaches across different types of patients, and interventions with different behavioral foci. This issue might be best addressed by trials focusing on the comparative effectiveness of different counseling interventions. Comparative effectiveness trials may also be helpful to determine optimal or minimum intensity and duration of effective counseling. In addition to self-reported behavioral outcomes, trials should also collect and report objectively measured physiologic outcomes. Greater use of objective measures to assess physical activity would likely provide more accurate estimates of changes in physical activity level, which is especially important when the changes are small in magnitude. To help interpret the magnitude of effect, epidemiological evidence on the relationship between small to moderate changes in dietary and physical activity and health outcomes is needed.

## Conclusions

Medium- to high-intensity dietary behavioral counseling, with or without physical activity counseling, resulted in small, but statistically significant, improvements in adiposity, blood pressure, and cholesterol, as well as moderate to large changes in self-reported dietary and physical activity behaviors. Evidence for changes in physiologic outcomes was strongest for high-intensity counseling interventions. Medium- to high-intensity physical activity counseling resulted in large changes in self-reported physical activity. There was some evidence to suggest that even low-intensity dietary counseling results in moderate increases in fruit and vegetable intake, and small decreases in dietary fat intake. However, there was very limited evidence for maintenance of any behavioral or physiologic effects beyond 12 months, particularly for low- and medium-intensity interventions. Most trials for high-intensity interventions that had followup beyond 12 months showed persistent beneficial changes in adiposity and lipids (but not blood pressure) as well as improvements in self-reported behavioral outcomes. It appears that intervention intensity was the most important factor for differences in effect size among different trials. This literature, however, did not represent a full range of combinations of intensity and population risk. Instead, intensity and population risk were highly correlated in the healthful diet and combined counseling trials, and very few physical activity trials were conducted in those selected for increased CVD, or utilizing a high-intensity approach, so the two factors could not be fully disentangled.