# Results

We identified 66 trials reporting the effects of counseling for physical activity, healthful diet, or both. Thirty trials tested the effect of counseling individuals to increase physical activity,32–76 and 26 of these could be included in the meta-analyses of physical activity counseling.32–34,36,38,40–42,47,50,52,53,55,56,58–62,64,66,68–70,72,74,75 Twenty-five trials tested the effect of counseling people to eat a healthful diet,34,35,42,43,47,48,53,77–109 24 of which could be included in meta-analyses.42,47,53,77–83,86,87,90–98,101,104,108 Seventeen trials examined the effects of counseling people for both physical activity and healthful diet,47–49,81,110–132 15 of which were eligible for inclusion in meta-analyses (Table 1).47,81,110,112,114,117,119–124,127,130,131 Trials with multiple intervention arms that were applicable to different intervention targets were included in multiple target areas. In addition, seven studies were included to examine the harms of physical activity (Table 1).133–139

Table 1 Number of Trials Included in the Review and Meta-Analysis By Key Question

| Physical Activity | Healthful Diet | Lifestyle | Meta-analysis
Key Question 1-Health Outcomes | 0 | 3 | 0 | N/A
Key Question 2-Intermediate Outcomes | 8 | 16 | 14 | 33 (n=64,319)
Key Question 3-Behavioral Outcomes | 30 | 25 | 17 | 58 (n=87,930)
Key Question 4-Harms^*^ | 7 | 0 | 0 | N/A

* Additional studies identified for harms (not including trials included for key questions 1–3).

There was a large variation in the types and intensities in counseling interventions, which ranged from brief single-session counseling to over 20 group sessions over 2 years (Table 2). Twenty-one of the interventions across all three target areas were categorized as low-intensity trials, generally involving a single or two very brief contacts with providers or were limited to mailed or Web-based treatment with little or no direct contact with an intervention provider. These interventions are generally most likely to be feasible for implementation in primary care, and primary care providers played a substantial role in six of these 21 trials. Almost all of the low-intensity trials targeted either physical activity or healthful diet. Only a single trial of combined lifestyle counseling had a low-intensity intervention.120 Thirty-two of the trials across all three target areas involved medium-intensity interventions. These interventions were quite heterogeneous, and may have involved phone or in-person counseling or both, and sometimes mailed materials as well. The number of phone calls ranged from three to 24 calls, and the number of in-person sessions ranged from one to eight. These interventions were too intensive to conduct in most primary care offices, but primary care providers at least played a role in seven of these trials. In most cases the provider’s role was to deliver a brief health promotion message during a primary care visit. Fifteen of the trials across all three target areas included high-intensity interventions. These interventions involved group counseling (range of four to 20 sessions over 1 to 24 months), with or without sporadic maintenance sessions for the trial duration. Only one of these trials involved physical activity counseling alone,71 the remaining included either healthful diet or combined lifestyle counseling. None of these trials involved the primary care provider.

Table 2 Counseling Trials By Intervention Intensity and Population Risk

Unselected | Selected for behavioral factors (physical activity or dietary intake) | Selected for increased cardiovascular risk
Low-intensity intervention (estimated 0–30 min)
4: Beresford 1997 (HD) 1: Carpenter 2004 (IG1) (HD) 1: Fries 2005 (HD) 1: John 2002 (HD) 1: Kristal 2000 (HD) 1: Lutz 1999 (HD) 1: Roderick 1997 (HD) 4: Sacerdote 2005 (HD) 0: de Vet 2009 (PA) 4: Katz 2008 (PA) 0: Stensel 1994 (PA) 0: Jeffery 1999 (HD+PA) | 1: Prochaska 2005 (HD) 4: Aittasalo 2006 (PA) 4: Goldstein 1999 (PA) 4: Grandes 2009 (PA) 1: Halbert 2000 (PA) 0: Marcus 2007 (IG2) (PA) 0: Marshall 2003 (PA) 0: Napolitano 2006 (PA) 0: Pekmezi 2009 (PA)
Moderate-intensity interventions (estimated 31–360 minutes)
4^*^:Baron 1990 (HD) 2: Green 2002 (PA) 0: Martinson 2008 (PA) 1: Morey 2009 (PA) 3–4: Norris 2000 (PA) 0: Franko 2008 (HD+PA) 0: Vandelanotte 2005(HD+PA) 0: Connell 2009 (PA) | 0: Greene 2008 (HD) (PA) 0: Bernstein 2002 (HD) 1: Delichatsios 2001 (HD) (PA) 0: King 2002 (HD) (PA) 3:Elley 2003 (PA) 1: Harland 1999 (PA) 0: King 2007 (PA) 1: Kinmonth 2008 (PA) 1: Kolt 2007 (PA) 4^*^: Lawton 2008 (PA) 0: Marcus 2007 (IG1) (PA) 2: Pinto 2005 (PA) | 0: Brekke 2005 (HD)(HD+PA) 1: Hellenius 1993 (ALL 3) 1: Stevens 2003 (HD) 0: Watanabe 2003 (HD) 3: Kallings 2009 (PA) 1: Yates 2009 (PA) 1: Babazono 2007 (HD+PA) 1: Eakin 2007 (HD+PA) 1: Hardcastle 2008 (HD+PA) 1: Keyserling 2008 (HD+PA) 1: Mosca 2008 (HD+PA) 1: Wister 2007 (HD+PA)
High-intensity interventions (>360 minutes)
0: Carpenter 2004 (IG2) (HD) 0: Aldana 2006 (HD+PA) 0: Hivert 2007 (HD+PA) 0: Simkin-Silverman 1995 (HD+PA) 0: Thompson 2008 (HD+PA) | 0: Coates 1999 (HD) 0: Tinker 2008 (HD) 1: Stewart 2001 (PA) | 0: HPT 1990 (HD) 0: TOHP I 1992 (HD) 0: TOHP II 1997 (HD) 0: Stefanick 1998 (HD) 0: Anderson 1992 (HD) 1: Edelman 2005 (HD+PA) 1: Oldroyd 2001 (HD+PA)

* Primary care nurse conducted intervention rather than physician; Bold=conducted in the United States

[underlined: Numeric Prefix:]

4=primary care provider conducted all or most of the intervention

3=primary care provider played substantial role in intervention (e.g., 1 of 2 visits was with primary care provider)

2=primary care provider played small role (e.g., brief advice followed by more extensive intervention conducted by other providers)

1=primary care provider played no direct role, but study participants were recruited from primary care or health plan rolls. Setting may have been primary care or mail, phone, or e-mail/Internet

0=primary care provider played no role, not conducted in primary care setting

In addition to the range in intensity of intervention, the distribution of these interventions varied by type of counseling intervention and whom was counseled (i.e., risk of population studied) (Table 2). None of the low-intensity trials were conducted in populations selected for increased risk of CVD. Instead, the healthful diet trials were generally in unselected populations, and the physical activity trials generally targeted people with inadequate levels of physical activity. The medium-intensity combined lifestyle trials were almost all conducted in samples selected for increased risk of CVD, whereas the physical activity trials were primarily conducted in people with inadequate levels of physical activity. The healthful diet trials were roughly evenly divided between being selected for poor diet and for increased CVD risk. The high-intensity healthful diet trials were primarily conducted in samples selected for CVD risk, while most of the combined lifestyle trials were in unselected samples.

## Key Question 1. Do primary care-relevant behavioral counseling interventions for healthful diet and/or physical activity improve CVD health outcomes in adults?

We found only three trials evaluating healthful diet counseling that specifically reported CVD-related health outcomes.106,109 Several trials reported mortality as part of their attrition, but not as a health outcome.44,71,87,92–94,101,104 In general, there were very few deaths in each trial and mortality was equivalent between the intervention and control groups.

In a very large good-quality trial, the Women’s Health Initiative (WHI) Randomized Controlled Dietary Modification Trial (n=48,835), post-menopausal women who were randomly assigned to intensive low-fat dietary counseling had no difference in major coronary heart disease events (hazard ratio [HR], 0.97 [95% CI, 0.90 to 1.06]) or stroke (HR, 1.02 [95% CI, 0.90 to 1.15]) or mortality (HR, 0.98 [95% CI, 0.91 to 1.07]) after approximately 8.1 years of followup, compared with those women who were randomly assigned to the usual-diet group.105,106 Although this was a good-quality trial, the authors state that the observed incidence rate for major coronary heart disease was 30 percent lower than projected and that the composite CVD outcome in persons without known CVD had a trend towards significance (HR, 0.94 [95% CI, 0.83 to 1.02]).106 Additionally, authors state that the dietary message focused on overall low-fat message for the primary purpose of breast cancer prevention, but did not include any specific messages about reducing saturated fats.140

Two hypertension prevention trials, Trials of Hypertension Prevention (TOHP) I and II, had long-term observation followup for 77 percent of the initial trial participants.109 In these two trials (n=3,126), pre-hypertensives with mildly elevated diastolic blood pressures who were randomly assigned to intensive sodium restriction counseling had less cardiovascular events and revascularization (n=2,415; HR, 0.70 [95% CI, 0.53 to 0.94]), but no difference in total mortality (n=3,126; HR, 0.80 [95% CI, 0.51 to 1.26]) after 10 to 15 years of followup. A more conservative CVD composite outcome (without revascularization) was not statistically significant, although the point estimate was similar (n=2,415; HR, 0.72 [95% CI, 0.50 to 1.03]). Cumulative incidence of CVD events between intervention and control groups in TOHP I and II appeared to diverge at approximately 8 to 9 years followup.

## Key Question 2. Do primary care-relevant behavioral counseling interventions for physical activity and/or healthful diet improve intermediate outcomes associated with CVD (e.g., adiposity, blood pressure, lipids, glucose tolerance) in adults?

### Physical Activity

Eight physical activity trials (n=3,731) did not show an impact on adiposity, blood pressure, lipids, or glucose tolerance (Table 3). Seven of eight trials were fair- or good-quality medium-intensity trials.36,47,50,56,59,62,72 The remaining trial was a low-intensity intervention that found no group differences in BMI at 6 months followup. In addition to the short followup, this trial has limited utility as it used a self-identified (volunteer), male-only sample, and did not examine any other intermediate outcomes.70 All of these trials were principally conducted in persons selected for sedentary behavior.

Table 3 Randomized Controlled Trials for Physical Activity Counseling Interventions: Intermediate Outcomes

Author, year Country Quality | Population details (total n, sex, age, race/ethnicity) | Intervention description | Intermediate outcomes (adiposity, blood pressure, lipids, glucose)
Low-intensity interventions (estimated 0–30 minutes)
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | | | Baseline | 12 months
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | | N | Mean | Mean change (SD)
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | BMI, kg/m^2^
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | IG | 42 | 25.4 | 0.0 (1.2)
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | CG | 23 | 24.8 | 0.2 (1.5)
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | NS
Medium-intensity interventions (estimated 31–360 minutes)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | | | Baseline | 12 months
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | BMI, kg/m^2^
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | IG | 451 | 30.0 | −0.1 (1.5)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | CG | 427 | 29.9 | −0.05 (1.3)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | SBP, mmHg
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | IG | 451 | 135.1 | −2.6 (15.7)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | CG | 427 | 135.4 | −1.2 (14.3)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | DBP, mmHg
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | IG | 451 | 82.4 | −2.6 (10.9)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | CG | 427 | 81.8 | −0.8 (10.2)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | Cholesterol, mmol/L
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | IG | 451 | 5.78 | −0.02 (0.70)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | CG | 427 | 5.64 | 0.01 (0.58)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner with PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | All NS
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | | | Baseline | 6 months
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | BMI, kg/m^2^
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | IG | 39 | 25.3 | −0.3(0.8)*
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | CG | 39 | 24.5 | 0.3(0.6)
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | SBP, mmHg
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | IG | 39 | 133 | −5.0(13.8)*
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | CG | 39 | 130 | −1.0(11.2)
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | DBP, mmHg
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | IG | 39 | 82 | −4.0(8.0)*
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | CG | 39 | 82 | −1.0(6.4)
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | Cholesterol, mmol/L
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | IG | 39 | 5.98 | −0.12(0.73)
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | CG | 39 | 5.97 | −0.13(0.64)
Hellenius 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | * p<0.05 for paired t-test of IG
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | | Baseline | | 6 months
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | BMI, kg/m^2^
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | IG | 47 | 29.7 | 41 | −0.6(1.0)*
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | CG | 54 | 30.4 | 50 | −0.2(0.7)
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | SBP, mmHg
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | IG | 47 | 137.6 | 41 | 0.2(14.7)
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | CG | 54 | 142.3 | 50 | −4.1(12.4)
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | DBP, mmHg
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | IG | 47 | 79.9 | 41 | −1.0(8.3)
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | CG | 54 | 81.6 | 50 | −1.7(9.6)
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | Cholesterol, mmol/L
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | IG | 47 | 5.6 | 41 | −0.30(0.98)*
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | CG | 54 | 5.5 | 50 | 0.10(0.36)
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | Fasting glucose, mmol/L
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | IG | 47 | 5.5 | 41 | −0.2 (0.33)
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | CG | 54 | 5.4 | 50 | −0.1 (0.36)
Kallings 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, one individual counseling session with specialty provider including PA prescription | * p<0.05
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | | | Baseline | 12 months
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | BMI, kg/m^2^
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | IG | 107 | 27.8 | 0.6(2.4)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | CG | 111 | 27.8 | 0.0(2.3)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | SBP, mmHg
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | IG | 107 | 124.2 | −3.2(12.2)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | CG | 111 | 122.6 | −3.4 (10.7)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | DBP, mmHg
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | IG | 107 | 79.1 | −1.7 (9.9)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | CG | 111 | 78.2 | −3.1 (7.8)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | Cholesterol, mmol/L
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | IG | 107 | 5.03 | 0.10 (0.91)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | CG | 111 | 5.29 | 0.02 (0.76)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | Plasma glucose, mmol/L
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | IG | 107 | 4.8 | 0.14 (--)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | CG | 111 | 4.9 | −0.01 (--)
Kinmonth 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15- minute counseling phone calls, postal contact for 7 months | All NS
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | | | Baseline | 12 months | 24 months
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change]
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | Weight, kg
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | IG | 544 | 73.2 | −0.6 (6.3) | −0.6
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | CG | 545 | 72.7 | 0.0 (6.3) | −0.2
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | SBP, mmHg
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | IG | 544 | 122.8 | −2.2 (14.6) | −3.7
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | CG | 545 | 123.4 | −1.5 (14.8) | −3.9
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | DBP, mmHg
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | IG | 544 | 73.8 | −2.3 (8.3) | −2.2
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | CG | 545 | 74.7 | −2.3 (7.8) | −3.0
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | Cholesterol, mmol/L
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | IG | 544 | 6.10 | −0.24 (0.96) | −0.45
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | CG | 545 | 6.03 | −0.20 (0.91) | −0.44
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | Glucose, mmol/L
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | IG | 544 | 5.02 | −0.05 (--)
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | CG | 545 | 4.96 | 0.0 (--)
Lawton 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | One brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls from community exercise specialist | All NS
Martinson 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | Four lectures, one group orientation, 23 phone calls, library or materials available for use, three motivational contests over 24 months, but not all completed at 6- month assessment | | | Baseline | 6 months
Martinson 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | Four lectures, one group orientation, 23 phone calls, library or materials available for use, three motivational contests over 24 months, but not all completed at 6- month assessment | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Martinson 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | Four lectures, one group orientation, 23 phone calls, library or materials available for use, three motivational contests over 24 months, but not all completed at 6- month assessment | BMI, kg/m^2^
Martinson 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | Four lectures, one group orientation, 23 phone calls, library or materials available for use, three motivational contests over 24 months, but not all completed at 6- month assessment | IG | 495 | 27.5 | −0.1 (2.4)
Martinson 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | Four lectures, one group orientation, 23 phone calls, library or materials available for use, three motivational contests over 24 months, but not all completed at 6- month assessment | CG | 491 | 27.7 | 0.0 (2.5)
Martinson 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | Four lectures, one group orientation, 23 phone calls, library or materials available for use, three motivational contests over 24 months, but not all completed at 6- month assessment | NS
High-intensity interventions (estimated >360 minutes)
Stewart, 2001^71^ US Fair | N=173 34% men Mean age 74 Race/ethnicity NR Selected for sedentary behavior and Medicare enrollment | 11 group sessions, one individual session, booklets, phone calls from counselor, monthly newsletters | Only self-reported BMI available
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | | | Baseline | 12 months
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | Weight, kg
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | IG | 58 | 80.6 | −0.03 (3.8)
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | CG | 29 | 81.1 | −0.7 (3.5)
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | SBP, mmHg
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | IG | 58 | 142.5 | −1.4 (14.9)
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | CG | 29 | 141 | −3.5 (14.0)
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | Cholesterol, mmol/L
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | IG | 58 | 4.75 | −0.03 (0.69)
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | CG | 29 | 4.8 | 0.11 (0.84)
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | 2-hour glucose, mmol/L
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | IG | 58 | 8.5 | −0.78 (2.01)
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | CG | 29 | 8.4 | −0.30 (2.54)
Yates 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions, and a subset received a pedometer | All NS

BMI – body mass index; calc – calculated; CG – control group; DBP – diastolic blood pressure; IG – intervention group; IGT – impaired glucose tolerance; L – liters; mmol –millimole; N – number randomized; NR – not reported; NS – not significant; PA – physical activity; RCT – randomized controlled trial; SBP – systolic blood pressure; SD – standard deviation; UK – United Kingdom; US – United States

Few of the medium-intensity trials found statistically significant between-group differences in intermediate outcomes. All seven medium-intensity trials reported either BMI or weight as a measure of adiposity. Only two of these studies found statistically significant group differences in adiposity,47,50 and the pooled standardized mean difference (SMD) showed no group differences (−0.09 [95% CI, −0.24 to 0.05]; I^2^=72.2%; n=3,490). Six36,47,50,56,59,72 of the seven medium-intensity trials also reported blood pressure outcomes, with statistically significant effects reported in one study for diastolic blood pressure only.36 Similarly, six36,47,50,56,59,72 of the seven medium-intensity studies reported lipid outcomes, but only one50 reported statistically significant group differences. The participants undergoing a single physician-led group session and one individual counseling session with a health educator reduced their total cholesterol by an average of 0.30 mmol/L after 6 months, compared with an average 0.10 increase among those in the control group (p=0.04). This study, however, did not find group differences in either HDL or LDL cholesterol levels. Also, only one of four trials reporting changes in plasma glucose found a statistically significant group difference, and this was in only one of the two treatment arms in a trial of persons with impaired glucose tolerance.72 Study participants receiving a pedometer and one 3-hour group session with two brief followup sessions reduced 2-hour fasting glucose by 1.75 mmol/L, compared with a 0.30 mmol/L decline in the control group (p=0.004). The robustness of this result is questionable, however, since the second intervention group, which was not given a pedometer (but otherwise received the same intervention), did not differ from the control group.72

Meta-analyses combining data from all eight trials confirmed no effect on intermediate outcomes, with no effect on adiposity (SMD, −0.09 [95% CI, −0.23 to 0.05]; I^2^=67.7%; k=8; N=3,555) (Figure 2), systolic blood pressure (weighted mean difference [WMD], −0.57 mmHg [95% CI, −1.89 to 0.74]; I^2^=14.0%; k=6; N=2,441) (Figure 3), diastolic blood pressure (WMD, −0.54 mmHg [95% CI, −1.90 to 0.81]; I^2^=58.5%; k=5; N=2,354) (Figure 4), lipids (total cholesterol WMD, −0.05mmol/L [95% CI, −0.13 to 0.04]; I^2^=23.9%; k=6; N=2,441) (Figure 5), HDLs (WMD, 0.0 [95% CI, −0.04 to 0.03]; I^2^=0.0%; k=4; N=1,476) (Figure 6), or LDLs (WMD, −0.02 [95% CI, −0.18 to 0.14]; I^2^=31.2%; k=3; N=387) (Figure 7). Thus, while available evidence suggests that counseling interventions of up to 6 hours duration are unlikely to affect intermediate health outcomes after 1 year, most studies did not report intermediate health outcomes. There was no evidence of statistically significant publication bias for any of the intermediate outcomes, based on Egger’s test.

Figure 2 Meta-Analysis of Physical Activity Trials (KQ2): Adiposity

Figure 2 displays a forest plot of physical activity trials reporting between-group differences in adiposity (reported as either body mass index or weight). Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (1 trial) the standardized mean difference was −0.15 (95% CI, −0.66 to 0.36). In the moderate-intensity (31 to 360 minutes) subgroup (7 trials) the combined standardized mean difference was −0.09 (95% CI, −0.24 to 0.06). The overall standardized mean difference for all 8 physical activity trials was −0.09 (95% CI, −0.23 to 0.05), indicating that there was no statistically significant effect on adiposity. There was substantial heterogeneity both within the moderate-intensity subgroup (chi-square=72.2%; p=0.001) and between the low- and moderate-intensity subgroups (chi-square=67.7%; p=0.003).

Figure 3 Meta-Analysis of Physical Activity Trials (KQ2): Systolic Blood Pressure

Figure 3 displays a forest plot of physical activity trials reporting between-group differences in systolic blood pressure. Data for the figure are presented alongside the forest plot. The overall unstandardized weighted mean difference for all 6 physical activity trials was −0.57 (95% CI, −1.89 to 0.74), indicating that there was no statistically significant effect on systolic blood pressure. There was no statistically significant heterogeneity across the trials (chi-square=14.0%; p=0.325).

Figure 4 Meta-Analysis of Physical Activity Trials (KQ2): Diastolic Blood Pressure

Figure 4 displays a forest plot of physical activity trials reporting between-group differences in diastolic blood pressure. Data for the figure are presented alongside the forest plot. The overall unstandardized weighted mean difference for all 5 physical activity trials was −0.54 (95% CI, −1.90 to 0.81), indicating that there was no statistically significant effect on diastolic blood pressure. There was moderate to substantial statistical heterogeneity across the trials (chi-square=58.5%; p=0.047).

Figure 5 Meta-Analysis of Physical Activity Trials (KQ2): Total Cholesterol

Figure 5 displays a forest plot of physical activity trials reporting between-group differences in total cholesterol. Data for the figure are presented alongside the forest plot. The overall unstandardized weighted mean difference for all 6 physical activity trials was −0.05 (95% CI, −0.13 to 0.04), indicating that there was no statistically significant effect on total cholesterol. There was no statistically significant heterogeneity across the trials (chi-square=23.9%; p=0.254).

Figure 6 Meta-Analysis of Physical Activity Trials (KQ2): High-Density Lipoproteins

Figure 6 displays a forest plot of physical activity trials reporting between-group differences in high-density lipoprotein (HDL) cholesterol. Data for the figure are presented alongside the forest plot. The overall unstandardized weighted mean difference for all 4 physical activity trials was 0 (95% CI, −0.04 to 0.03), indicating that there was no statistically significant effect on HDL cholesterol. There was no statistically significant heterogeneity across the trials (chi-square=0%; p=0.702).

Figure 7 Meta-Analysis of Physical Activity Trials (KQ2): Low-Density Lipoproteins

Figure 7 displays a forest plot of physical activity trials reporting between-group differences in low-density lipoprotein (LDL) cholesterol. Data for the figure are presented alongside the forest plot. The overall unstandardized weighted mean difference for all 3 physical activity trials was −0.02 (95% CI, −0.18 to 0.14), indicating that there was no statistically significant effect on LDL cholesterol. There was moderate statistical heterogeneity across the trials (chi-square=31.2%; p=0.234).

### Healthful Diet

Trials examining healthful diet counseling were more likely to report intermediate outcomes than trials focused only on physical activity. Of the 25 trials of healthful diet counseling interventions that met our inclusion criteria, 16 reported one or more intermediate health outcomes (e.g., objectively measured weight, blood pressure, cholesterol, and/or glucose tolerance) (Table 4). Three evaluated low-sodium dietary counseling,87,98,101 one trial evaluated fruits and vegetables only dietary counseling,90 and 12 trials evaluated general heart-healthy dietary counseling, including low-fat dietary changes.47,77,78,81,83,91,94–97,104,108

Table 4 Randomized Controlled Trials for Healthful Diet Counseling Interventions: Intermediate Outcomes

Reference Country Quality | Population details (total n, sex, age, race/ethnicity) | Intervention details | Intermediate outcomes (adiposity, blood pressure, lipids, glucose)
Salt only dietary counseling
High-intensity interventions (estimated >360 minutes)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | | Baseline | | 6 months | | 36 months
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SE)] | [underlined: N] | [underlined: Mean change (SD)]
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | SBP, mmHg
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | IG1+IG2 | 392 | 124.05 | 353 | −3.60 (--) | 352 | −3.46 (--)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | CG | 196 | 123.9 | 191 | −2.1 (0.6) | 177 | −2.9 (0.7)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | p IG2 v. IG1 | | | | 0.822 | | 0.161
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | p IG1 v. CG | | | | 0.126 | | 0.885
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | DBP, mmHg
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | IG1+IG2 | 196 | 82.6 | 353 | −3.55 (--) | 352 | −3.26 (--)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | CG | 196 | 83.0 | 191 | −3.0 (0.5) | 177 | −3.0 (0.5)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | p IG2 v. IG1 | | | | 0.597 | | 0.664
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months plus ongoing maintenance | p IG1 v. CG | | | | 0.398 | | 0.787
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | | Baseline | | 12 months | | 18 months
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | SBP, mmHg
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | IG | 327 | 124.8 | 301 | −5.83 (7.46) | 304 | −5.08 (7.94)
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | CG | 417 | 125.1 | 392 | −3.93 (7.43) | 395 | −3.02 (8.31)
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | Mean difference (95%CI) at end of study: −1.69 (−2.85, −0.54)
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | DBP, mmHg
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | IG | 327 | 83.7 | 301 | −4.44 (5.38) | 304 | −4.35 (5.65)
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | CG | 417 | 83.9 | 392 | −3.37 (5.74) | 395 | −3.18 (5.80)
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 individual or group sessions in 3 months plus ongoing maintenance | Mean difference (95%CI) at end of study: −0.85 (−1.68, −0.02)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | | Baseline | | 18 months | | 36 months
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | SBP, mmHg
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | IG | 594 | 127.7 | 513 | −3.8 (8.2) | 515 | −0.7 (9.0)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | CG | 596 | 127.3 | 525 | −1.8 (7.0) | 514 | 0.6 (8.5)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | Mean difference (SE): | | | | −2.0 (0.5)* | | −1.2 (0.5)#
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | DBP, mmHg
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | IG | 594 | 86.1 | 513 | −4.4 (6.5) | 515 | −3.0 (6.5)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | CG | 596 | 85.8 | 525 | −3.2 (5.8) | 514 | −2.4 (7.0)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | Mean difference (SE): | | | | −1.2 (0.4)† | | −0.7 (0.4)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months plus ongoing maintenance | * p<0.001 for comparison with CG † p=0.002 for comparison with CG # p=0.02 for comparison with CG
Fruits and vegetables only dietary counseling
Low-intensity interventions (estimated 0–30 minutes)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | | Baseline | | 6 months
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | Weight, kg
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | IG | 344 | 76.1 | 344 | 0.6 (2.6)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | CG | 346 | 75.6 | 346 | 0.6 (2.6)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | Adjusted difference in change (95%CI): 0.1 (−0.4, 0.6)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | SBP, mmHg
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | IG | 344 | 130.2 | 344 | −2.0 (13.5)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | CG | 346 | 129.3 | 346 | 1.4 (14.6)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | Adjusted difference in change (95%CI): 4.0 (2.0, 6.0)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | DBP, mmHg
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | IG | 344 | 79.2 | 344 | −1.6 (8.7)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | CG | 346 | 79.9 | 346 | −0.3 (8.7)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | Adjusted difference in change (95%CI): 1.5 (0.2, 2.7)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | Total cholesterol, mmol/L
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | IG | 344 | 5.037 | 344 | −0.018 (0.87)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | CG | 346 | 5.123 | 346 | −0.036 (0.56)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | Adjusted difference in change (95%CI): 0.010 (−0.097, 0.116)
Fats only dietary counseling
High-intensity interventions (estimated >360 minutes)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | | Women | | Men
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | | [underlined: N] | [underlined: Mean change (SD) at 12 mo] | [underlined: N] | [underlined: Mean change (SD) at 12 mo]
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | Body weight, kg
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 46 | −2.7 (3.5)*** | 49 | −2.8 (3.5)***
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 45 | 0.8 (4.2) | 46 | 0.5 (2.7)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | *** p<0.001 for comparison with the CG
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | SBP, mmHg
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 46 | −3.5 (9.2) | 49 | −1.7 (6.4)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 45 | −2.4 (7.6) | 46 | 0.3 (7.9)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | DBP, mmHg
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 46 | −1.9 (5.0) | 49 | −0.3 (5.2)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 45 | −0.6 (5.9) | 46 | 1.8 (6.1)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | HDL cholesterol, mmol/L
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 46 | 0.008 (0.489) | 49 | −0.021 (0.114)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 45 | 0.026 (0.158) | 46 | −0.005 (0.111)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | LDL cholesterol, mmol/L
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 46 | −0.189 (0.489) | 49 | −0.279 (0.486)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 45 | −0.026 (0.504) | 46 | −0.119 (0.546)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | Total cholesterol, mmol/L
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 46 | −0.204 (0.533) | 49 | −0.341 (0.499)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 45 | −0.026 (0.504) | 46 | −0.101 (0.559)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | Triglycerides, mmol/L
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 46 | −0.047 (0.735) | 49 | −0.071 (0.674)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 45 | 0.024 (0.479) | 46 | 0.079 (0.940)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | Glucose, mmol/L
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 46 | −0.428 (0.367) | 49 | −0.422 (0.478)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 45 | −0.144 (0.844) | 46 | −0.211 (0.583)
Multiple message or general cardiovascular dietary counseling
Low-intensity interventions (estimated 0–30 minutes)
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi- monthly newsletters over 12 months | Body weight, kg
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi- monthly newsletters over 12 months | | | 12 month
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi- monthly newsletters over 12 months | | [underlined: N] | [underlined: Mean change (SD)]
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi- monthly newsletters over 12 months | IG | 601 | 0.08 (--)
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi- monthly newsletters over 12 months | CG | 604 | 0.39 (--)
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi- monthly newsletters over 12 months | Adjusted intervention effect: −0.76, p=0.088 Adjusted for age, sex, race, and income
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | | Baseline | | 12 months
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | BMI, kg/m^2^
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | IG | 473 | 26.3 | 401 | 0.01 (1.97)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | CG | 483 | 25.9 | 352 | 0.14 (2.10)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | Mean difference within matched pairs (95%CI): −0.12 (−0.30, 0.05)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | SBP, mmHg
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | IG | 473 | 124.4 | 401 | −1.14 (16.10)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | CG | 483 | 125.2 | 352 | −0.39 (13.30)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | Mean difference within matched pairs (95%CI): −0.59 (−2.43, 1.24)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | DBP, mmHg
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | IG | 473 | 77.8 | 401 | −0.19 (10.55)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | CG | 483 | 77.1 | 352 | −0.09 (9.79)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | Mean difference within matched pairs (95%CI): 0.09 (−4.9, 5.0)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | Total cholesterol, mmol/L
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | IG | 473 | NR | 401 | −0.23 (--)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | CG | 483 | NR | 352 | −0.0007 (--)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum 1 session with nurse, followup session in 1 month if needed | Mean difference (95%CI): −0.20 (−0.38, −0.03)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | | Baseline | | 12 months
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | BMI, kg/m^2^
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | IG | 1592 | 24.8 | 1488 | −0.4 (1.8)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | CG | 1587 | 24.3 | 1489 | 0 (1.57)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | Adjusted effect of intervention: F=5.42, p=0.02
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | SBP, mmHg
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | IG | 1592 | 128.7 | 1488 | 0.1 (13.6)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | CG | 1587 | 128.8 | 1489 | −0.20 (13.3)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | Adjusted effect of intervention: F=0.01, p=0.93
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | DBP, mmHg
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | IG | 1592 | 78.5 | 1488 | 0.4 (7.6)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | CG | 1587 | 78.7 | 1489 | 0.6 (16.2)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 44 NR nonwhite Unselected | 15-minute session with PCP with brochure | Adjusted effect of intervention: F=0.03, p=0.85 Adjusted for sex, BMI, education, and time
Medium-intensity interventions (estimated 31–360 minutes)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | | Baseline | | 12 months
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | Total cholesterol, mmol/L
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | IG | 186 | 4.86 | 167 | −0.20 (0.76)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | CG | 181 | 4.84 | 178 | −0.42 (0.57)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | LDL, mmol/L
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | IG | 169 | 2.83 | 164 | −0.30 (0.69)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | CG | 167 | 2.81 | 164 | −0.30 (0.69)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | HDL, mmol/L
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | IG | 172 | 149 | 164 | −0.03 (0.26)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | CG | 174 | 1.52 | 158 | −0.02 (0.24)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | p= NS
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | | Baseline | | 12 months
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | BMI, kg/m^2^
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 25.0 | 24 | −0.15 (0.87)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 26.1 | 19 | 0.22 (1.36)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | Total cholesterol, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 4.84 | 24 | 0.10 (0.64)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 5.03 | 19 | 0.24 (0.58)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | HDL, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 1.26 | 24 | 0.08 (0.26)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 1.31 | 19 | −0.04 (0.16)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | LDL, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 3.06 | 24 | 0.01 (0.62)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 3.23 | 19 | 0.28 (0.49)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | Triglycerides, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 1.16 | 24 | 0.03 (0.42)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 1.10 | 19 | 0.01 (0.23)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | Fasting blood glucose, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 4.69 | 24 | −0.33 (0.81)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 5.04 | 19 | −0.21 (0.51)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | | Baseline | | 6 months
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | BMI, kg/m^2^
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | IG | 40 | 25.2 | 40 | −0.3 (1.02)*
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | CG | 39 | 24.5 | 39 | 0.3 (0.64)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | SBP, mmHg
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | IG | 40 | 130 | 40 | −7 (11.30)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | CG | 39 | 130 | 39 | −1 (11.20)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | DBP, mmHg
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | IG | 40 | 82 | 40 | −6 (6.40)*
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | CG | 39 | 82 | 39 | −1 (6.40)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | Total cholesterol, mmol/L
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | IG | 40 | 6.08 | 40 | −0.19 (0.19)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | CG | 39 | 5.97 | 39 | −0.13 (0.21)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | LDL, mmol/L
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | IG | 40 | 4.29 | 40 | −0.30 (0.77)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | CG | 39 | 4.14 | 39 | −0.15 (0.56)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | HDL, mmol/L
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | IG | 40 | 1.41 | 40 | 0.01 (0.77)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | CG | 39 | 1.36 | 39 | −0.02 (0.56)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | Triglycerides, mmol/L
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | | 40 | 1.27 | 40 | 0.03 (0.39)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | | 39 | 1.33 | 39 | 0.06 (0.45)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | 1 session with PCP and 1 session with dietitian over 2 weeks | * p<0.001
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated total cholesterol | 2 individual sessions over 1 month, plus 2 followup phone calls over 1 month | Total cholesterol, mmol/L
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated total cholesterol | 2 individual sessions over 1 month, plus 2 followup phone calls over 1 month | | Baseline | | 12 months
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated total cholesterol | 2 individual sessions over 1 month, plus 2 followup phone calls over 1 month | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated total cholesterol | 2 individual sessions over 1 month, plus 2 followup phone calls over 1 month | IG | 271 | 5.98 | 271 | −0.19 (0.58)
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated total cholesterol | 2 individual sessions over 1 month, plus 2 followup phone calls over 1 month | CG | 277 | 6.01 | 277 | −0.16 (0.60)
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated total cholesterol | 2 individual sessions over 1 month, plus 2 followup phone calls over 1 month | p=NS
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | 1 individual session, plus mailed tailored booklet at 1 month | Fasting plasma glucose, mmol/L
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | 1 individual session, plus mailed tailored booklet at 1 month | | Baseline | | 12 months
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | 1 individual session, plus mailed tailored booklet at 1 month | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean % change (SD)]
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | 1 individual session, plus mailed tailored booklet at 1 month | IG | 79 | 6.1 | 79 | −0.5 (0.9)
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | 1 individual session, plus mailed tailored booklet at 1 month | CG | 77 | 5.5 | 79 | 2.2 (0.9)
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | 1 individual session, plus mailed tailored booklet at 1 month | Adjusted mean difference (95%CI): −1.8 (−4.2, 0.6) Adjusted for baseline values
High-intensity interventions (estimated >360 minutes)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | | Baseline | | 12 months
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | Weight, kg
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 71.55 | 95 | −1.04 (3.05)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 71.44 | 51 | −0.44 (2.68)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | p=NS
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | | Baseline | | 6 months
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SE)]
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | Total cholesterol, mmol/L
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 6.09 | 95 | −0.69 (0.62)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 5.92 | 51 | −0.42 (0.57)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | p=0.009
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | LDL, mmol/L
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 4.16 | 95 | −0.66 (0.56)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 4.00 | 51 | −0.40 (0.43)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | p=0.005
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | HDL, mmol/L
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 1.29 | 95 | −0.02 (0.14)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 1.20 | 51 | 0.01 (0.14)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | p=NS
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | Log triglyceride
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 0.23 | 95 | −0.06 (0.69)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 0.36 | 51 | −0.06 (0.71)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | p=NS
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | | Baseline | | 6 months
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | BMI, kg/m^2^
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 28.7 | 1324 | −0.7 (2.06)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 29.1 | 883 | −0.1* (2.15)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | SBP, mmHg
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 127.1 | 1324 | −3.1 (17.08)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 127.3 | 883 | −1.4* (15.31)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | DBP, mmHg
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 76.3 | 1324 | −1.1 (8.68)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 76.9 | 883 | −0.6 (7.95)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | Fasting glucose, mmol/L
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 5.3 | 1324 | −0.2 (1.34)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 5.3 | 883 | −0.1 (1.34)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post-menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | *p<0.05 for differences between IG and CG
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | | Baseline | | 12 months | | 72 months
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | BMI, kg/m^2^
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | IG | 18,291 | 28.9 | 17,026 | −0.90 (2.59) | 14,409 | −0.10 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | CG | 27,386 | 28.9 | 24,977 | −0.20 (2.57) | 22,321 | 0.20 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | SBP, mmHg
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | IG | 18,375 | 127.1 | 17,126 | −2.70 (15.34) | 14,543 | −2.60 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | CG | 27,510 | 127.4 | 25,173 | −2.00 (14.18) | 22,532 | −2.80 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | DBP, mmHg
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | IG | 18,370 | 75.9 | 17,125 | −2.00 (8.18) | 14,540 | −4.20 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | CG | 27,505 | 76.0 | 25,169 | −1.30 (7.57) | 22,532 | −4.10 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | | Baseline | | 36 months
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | (5.8% subsample for lipid measures, N analyzed but not reported)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | Total cholesterol, mmol/L
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | IG | NR | 5.72 | NR | −0.25 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | CG | NR | 5.72 | NR | −0.19 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | Relative change (95%CI): 0.98 (0.97, 1.00)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | LDL, mmol/L
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | IG | NR | 3.33 | NR | −0.26 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | CG | NR | 3.35 | NR | −0.19 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | Relative change (95%CI): 0.97 (0.95, 1.00)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | HDL, mmol/L
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | IG | NR | 1.50 | NR | −0.01 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | CG | NR | 1.46 | NR | 0.00 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | Relative change (95%CI): 0.99 (0.98, 1.01)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | Triglycerides, mmol/L
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | IG | NR | 1.57 | NR | 0.04 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | CG | NR | 1.59 | NR | 0.04 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | Relative change (95%CI): 1.00 (0.97, 1.04)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | | Baseline | | 12 months | | 72 months
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | (5.8% subsample with analyzed serum samples)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | Fasting glucose, mmol/L
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | IG | 979 | 5.24 | 915 | −0.11 (--) | 760 | 0.12 (NR)
Tinker, 2008^104^ US Good | N=48835 0% men Mean age 62 18% nonwhite Selected for post- menopausal women and dietary fat intake >30% | 18 group sessions and 1 individual session over 12 months, plus ongoing maintenance for trial duration | CG | 1525 | 5.25 | 1366 | −0.02 (--) | 1165 | 0.09 (NR)

N - number; BP - blood pressure; HPT - Hypertension Prevention Trial; US - United States; IG - intervention group; CG - control group; SE - standard error; SBP -systolic blood pressure; DBP - diastolic blood pressure; mmHg - millimeters of mercury; TOHP - Trial of Hypertension Prevention; CI - confidence interval; SD -standard deviation; min - minutes; NR - not reported; UK - United Kingdom; mmol/L - millimoles per liter; kg - kilograms; NS - not significant; HDL - high density lipoprotein; LDL - low density lipoprotein; PCP - primary care physician; BMI - body mass index; kg/m^2^ - kilograms per meters squared

Low-sodium only dietary counseling. Three fair-to-good-quality trials of high-intensity low-sodium dietary counseling reduced blood pressure in persons with mildly elevated diastolic blood pressure (approximately 80–89 mmHg).87,98,101 All three trials were conducted in the United States among middle-aged adults. Approximately two thirds of participants were men and one fifth were nonwhite. Meta-analyses of blood pressure outcomes at 6 to 18 months showed a statistically significant reduction in systolic and diastolic blood pressure of −1.86 mmHg (95% CI, −2.49 to −1.23; I^2^=0.0%; k=3; N=2,275) (Figure 8) and −1.05 mmHg (95% CI, −1.55 to −0.54; I^2^=0.0%; k=3; N=2,275) (Figure 9), respectively. Reductions in blood pressure were still statistically significant, although slightly attenuated, at up to 36 months.87,98,101

Figure 8 Meta-Analysis of Healthful Diet Trials, Salt Reduction Counseling (KQ2): Systolic Blood Pressure

Figure 8 displays a forest plot of healthful diet trials reporting between-group differences in systolic blood pressure after low-sodium dietary counseling. Data for the figure are presented alongside the forest plot. The overall unstandardized weighted mean difference for all 3 healthful diet trials was −1.86 (95% CI, −2.49 to −1.23), indicating that there was a statistically significant reduction in systolic blood pressure. There was no statistical heterogeneity across the trials (chi-square=0%; p=0.835).

Figure 9 Meta-Analysis of Healthful Diet Trials, Salt Reduction Counseling (KQ2): Diastolic Blood Pressure

Figure 9 displays a forest plot of healthful diet trials reporting between-group differences in diastolic blood pressure after low-sodium dietary counseling. Data for the figure are presented alongside the forest plot. The overall unstandardized weighted mean difference for all 3 healthful diet trials was −1.05 (95% CI, −1.55 to −0.54), indicating that there was a statistically significant reduction in diastolic blood pressure. There was no statistical heterogeneity across the trials (chi-square=0%; p=0.705).

These three trials were generally good-quality trials. Although one trial (TOHP I) was considered overall fair-quality because of the lower followup of urinary sodium outcomes, followup for blood pressure outcomes, however, was greater than 90 percent.98 All three of these trials used a primarily self-identified (volunteer) sample recruited through media or other announcements and involved very intensive counseling, likely over 900 minutes of group counseling, plus ongoing maintenance sessions throughout the study duration.

Fruits and vegetables only dietary counseling. Only one of the three trials evaluating fruits and vegetables dietary counseling reported intermediate outcomes and showed mixed results.90 This fair-quality trial (n=29) conducted in the United Kingdom evaluated a 25-minute dietary intervention aimed at increasing fruit and vegetable intake for middle-aged adults without chronic diseases. At followup, the intervention group averaged slightly lower systolic (by 4 mmHg [95% CI, 2.0 to 6.0]) and diastolic (by 1.5 mmHg [95% CI, 0.2 to 2.7]) blood pressures than the waitlist control group. However, there were no statistically significant differences in weight or total cholesterol between groups. Although this trial showed a larger effect size than seen in the high-intensity sodium counseling trials, we are not confident that an effect this large could be replicated given that the trial had limitations in its conduct and followup was only 6 months.

Low-fat and general heart-healthy dietary counseling. Nine of the 12 trials evaluating low-fat and general heart-healthy dietary counseling reported weight or BMI as a measure of adiposity, generally demonstrating improvements in adiposity.47,77,81,83,91,94–96,104 There was a large variation in intervention intensity, which ranged from brief counseling conducted in a single session to high-intensity counseling with up to 20 sessions. Only three of these trials involved low-intensity interventions (i.e., single session or mail-only interventions).91,94,95 Meta-analyses showed a statistically significant reduction in adiposity, although the statistical heterogeneity was quite high (SMD, −0.30 [95% CI, −0.39 to −0.20]; I^2^=78.9%; k=8; N=48,394). Five of these eight trials showed a significant decrease in BMI.47,83,95,96,104 Stratified meta-analyses by intervention intensity showed statistically significant reductions in adiposity for the medium- and high-intensity counseling interventions. Only two trials were included in the medium-intensity group and a significant amount of heterogeneity remained in the high-intensity counseling trials (I^2^=85%) (Figure 10). While included trials were primarily conducted in middle-aged adults, two larger trials were conducted in slightly older, all-female populations with a mean age of about 60 years.83,104 Both trials showed a statistically significant decrease in BMI at 6 or 12 months.

Figure 10 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ2): Adiposity

Figure 10 displays a forest plot of healthful diet trials reporting between-group differences in adiposity (reported as either body mass index or weight) after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (2 trials) the combined standardized mean difference was −0.16 (95% CI, −0.33 to 0.00). In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined standardized mean difference was −0.57 (95% CI, −0.93 to −0.21). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined standardized mean difference was −0.37 (95% CI, −0.52 to −0.22). The overall standardized mean difference for all 8 healthful diet trials was −0.30 (95% CI, −0.39 to −0.20), indicating that there was a statistically significant reduction in adiposity. However, there was significant statistical heterogeneity, both within the low-intensity subgroup (chi-square=77.0%; p=0.037) and the high-intensity subgroup (chi-square=85.4%; p=0.000), and across all subgroups (chi-square=78.9%; p=0.000).

Six of the 12 trials evaluating low-fat and general heart-healthy dietary counseling reported blood pressure outcomes.47,83,94–96,104 Meta-analyses pooling blood-pressure outcomes at 6 to 12 months showed a statistically significant reduction in systolic (SMD, −0.88 mmHg [95% CI, −1.67 to −0.08]; I^2^=54.2%; k=6; N=48,501) (Figure 11) and diastolic (SMD, −0.72 mmHg [95% CI, −1.29 to −0.16]; I^2^=8.1%; k=6; N=48,496) (Figure 12) blood pressure. Statistical heterogeneity appeared to primarily stem from intervention intensity. In stratified meta-analyses, there were statistically significant reductions in systolic and diastolic blood pressures for medium- and high-intensity interventions, but not for the two low-intensity trials (Figures 11 and 12).94,95

Figure 11 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ2): Systolic Blood Pressure

Figure 11 displays a forest plot of healthful diet trials reporting between-group differences in systolic blood pressure after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (2 trials) the combined unstandardized weighted mean difference was 0.10 (95% CI, −0.82 to 1.02). In the moderate-intensity (31 to 360 minutes) subgroup (1 trial) the unstandardized weighted mean difference was −6.00 (95% CI, −10.96 to −1.04). In the high-intensity (more than 360 minutes) subgroup (3 trials) the combined unstandardized weighted mean difference was −0.96 (95% CI, −1.61 to −0.31).The overall unstandardized weighted mean difference for all 6 healthful diet trials was −0.88 (95% CI, −1.67 to −0.08), indicating that there was a statistically significant reduction in systolic blood pressure. However, there was some statistical heterogeneity across all subgroups (chi-square=54.2%; p=0.053).

Figure 12 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ2): Diastolic Blood Pressure

Figure 12 displays a forest plot of healthful diet trials reporting between-group differences in diastolic blood pressure after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (2 trials) the combined unstandardized weighted mean difference was −0.17 (95% CI, −0.94 to 0.60). In the moderate-intensity (31 to 360 minutes) subgroup (1 trial) the unstandardized weighted mean difference was −5.00 (95% CI, −7.82 to −2.18). In the high-intensity (more than 360 minutes) subgroup (3 trials) the combined unstandardized weighted mean difference was −0.70 (95% CI, −0.85 to −0.55).The overall unstandardized weighted mean difference for all 6 healthful diet trials was −0.72 (95% CI, −1.29 to −0.16), indicating that there was a statistically significant reduction in diastolic blood pressure. However, there was some statistical heterogeneity across all subgroups (chi-square=58.1%; p=0.036).

Eight of the 12 trials evaluating low-fat and general heart-healthy dietary counseling reported lipids outcomes at 6 to 12 months.47,77,78,81,94,96,97,104 Meta-analyses showed a statistically significant reduction in total cholesterol (WMD, −0.10 mmol/L [95% CI, −0.17 to −0.02]; I^2^=37.6%; k=6; N=1,335) (Figure 13) and LDL cholesterol (WMD, −0.14 mmol/L [95% CI, −0.25 to −0.04]; I^2^=33.8%; k=5; N=782) (Figure 14). Again, statistical heterogeneity appears to stem from intervention intensity. There were statistically significant reductions in total cholesterol and LDL for only the two highest-intensity interventions (k=2; N=332).77,96 There were no statistically significant changes in HDL or triglycerides (Figures 15 and 16).

Figure 13 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ2): Total Cholesterol

Figure 13 displays a forest plot of healthful diet trials reporting between-group differences in total cholesterol after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −0.05 (95% CI, −0.11 to 0.01). In the high-intensity (more than 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was −0.23 (95% CI, −0.35 to −0.11).The overall unstandardized weighted mean difference for all 6 healthful diet trials was −0.10 (95% CI, −0.17 to −0.02), indicating that there was a statistically significant reduction in total cholesterol. However, there was some statistical heterogeneity across the subgroups (chi-square=37.6%; p=0.156).

Figure 14 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ2): Low-Density Lipoproteins

Figure 14 displays a forest plot of healthful diet trials reporting between-group differences in low-density lipoprotein (LDL) cholesterol after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (3 trials) the combined unstandardized weighted mean difference was −0.08 (95% CI, −0.23 to 0.07). In the high-intensity (more than 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was −0.19 (95% CI, −0.31 to −0.08).The overall unstandardized weighted mean difference for all 5 healthful diet trials was −0.14 (95% CI, −0.25 to −0.04), indicating that there was a statistically significant reduction in LDL cholesterol. However, there was some statistical heterogeneity across the subgroups (chi-square=33.8%; p=0.196).

Figure 15 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ2): High-Density Lipoproteins

Figure 15 displays a forest plot of healthful diet trials reporting between-group differences in high-density lipoprotein (HDL) cholesterol after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (3 trials) the combined unstandardized weighted mean difference was 0.03 (95% CI, −0.06 to 0.13). In the high-intensity (more than 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was −0.03 (95% CI, −0.07 to 0.01).The overall unstandardized weighted mean difference for all 5 healthful diet trials was −0.01 (95% CI, −0.04 to 0.03), indicating that there was not a statistically significant effect on HDL cholesterol. However, there was some statistical heterogeneity across the subgroups (chi-square=33.8%; p=0.196). There was moderate statistical heterogeneity within the moderate-intensity subgroup (chi-square=42.2%; p=0.177); heterogeneity was not statistically significant across the subgroups (chi-square=17.2%; p=0.305).

Figure 16 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ2): Triglycerides

Figure 16 displays a forest plot of healthful diet trials reporting between-group differences in triglycerides after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was −0.01 (95% CI, −0.14 to 0.13). In the high-intensity (more than 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was −0.06 (95% CI, −0.22 to 0.09).The overall unstandardized weighted mean difference for all 4 healthful diet trials was −0.03 (95% CI, −0.13 to 0.07), indicating that there was not a statistically significant effect on triglycerides. There was no statistical heterogeneity across the subgroups (chi-square=0%; p=0.827).

Only five of the 12 trials evaluating general heart-healthy dietary counseling reported glucose tolerance outcomes.81,83,96,104,108 Meta-analyses showed a statistically significant reduction in fasting glucose, although statistical heterogeneity was extremely high (WMD, −0.63 mmol/L [95% CI, −1.20 to −0.05]; I^2^=98.8%; k=4; N=4,873) (Figure 17). When one outlier trial conducted in Japan was removed, statistical heterogeneity was somewhat reduced, although still substantial (66.7%), and the pooled effect was no longer statistically significant. This fair-quality trial was the only trial conducted in a nonwestern population and included only men with impaired fasting glucose.108

Figure 17 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ2): Glucose

Figure 17 displays a forest plot of healthful diet trials reporting between-group differences in glucose tolerance after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was −1.41 (95% CI, −3.94 to 1.11). In the high-intensity (more than 360 minutes) subgroup (3 trials) the combined unstandardized weighted mean difference was −0.10 (95% CI, −0.23 to 0.03).The overall unstandardized weighted mean difference for all 5 healthful diet trials was −0.63 (95% CI, −1.20 to −0.05), indicating that there was a statistically significant decrease in glucose tolerance. However, there was quite significant statistical heterogeneity, both within the moderate-intensity subgroup (chi-square=99.1%; p=0.000) and the high-intensity subgroup (chi-square=77.4%; p=0.012) and between the two subgroups (chi-square=98.8%; p=0.000).

The WHI was the largest and best quality study (n=48,835) studying the effects of general low-fat dietary counseling. For this trial, post-menopausal women received 19 counseling sessions aimed at decreasing overall fat consumption and increasing fiber and fruit and vegetable intake to prevent breast cancer and CVD.104 Although there was a statistically significant difference in change in blood pressure and fasting glucose at 12 months between the intervention and control groups, these differences were no longer statistically significant at 72 months. There were no statistically significant differences in total cholesterol, LDL, or HDL at 12 and 36 months. Change in BMI was the only statistically significant difference at both 12 and 72 months followup (Table 4).

The majority of dietary counseling trials reporting intermediate health outcomes were of fair-quality, and there was significant clinical and statistical heterogeneity. Much, but not all, of this heterogeneity could be attributed to different levels of counseling intensities. However, because intervention intensity generally corresponded with population risk for CVD or how the population was selected for the intervention (e.g., low-intensity interventions were primarily conducted in unselected persons), it is unclear if the heterogeneity was primarily a result of intervention intensity or population CVD risk. In addition, only nine77,83,87,91,96–98,101,104 of the 16 trials were conducted in the United States, five of which utilized primary care samples.83,97,98,101,104 Overall, there was no evidence for statistically significant publication bias based on the Egger’s test for any of the intermediate outcomes.

### Combined Lifestyle

Of the 17 trials of combined lifestyle counseling interventions that met our inclusion criteria, 14 reported intermediate health outcomes of objectively measured weight, blood pressure, cholesterol, and/or glucose tolerance (Table 5). Only two trials were rated as good quality.124,131 All but one evaluated medium- or high-intensity counseling interventions requiring more than 30 minutes of patient contact, ranging from two to 30 counseling sessions for up to 24 months. Of these 14 trials reporting intermediate outcomes, seven were conducted in the United States110,115,120–122,124,127 and five were conducted in unselected adults samples.110,119,120,124,127

Table 5 Randomized Controlled Trials for Combined Lifestyle Counseling Interventions: Intermediate Outcomes

Author, year Country Quality | Population details (total n, sex, age, race/ethnicity) | Intervention details | Intermediate outcomes (adiposity, blood pressure, lipids, glucose)
Low-intensity interventions (estimated 0–30 minutes)
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | IG1: 36 monthly newsletters plus additional activities offered every 6 months, over 36 months IG2: IG1 + incentives | | 12 months | | 36 months
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | IG1: 36 monthly newsletters plus additional activities offered every 6 months, over 36 months IG2: IG1 + incentives | | N | Mean Change (SD) | N | Mean Change (SD)
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | IG1: 36 monthly newsletters plus additional activities offered every 6 months, over 36 months IG2: IG1 + incentives | Weight, kg
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | IG1: 36 monthly newsletters plus additional activities offered every 6 months, over 36 months IG2: IG1 + incentives | IG | 395 | 0.45 (4.21) | 395 | 1.55 (7.02)
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | IG1: 36 monthly newsletters plus additional activities offered every 6 months, over 36 months IG2: IG1 + incentives | CG | 414 | 0.6 (4.07) | 414 | 1.8 (6.10)
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | IG1: 36 monthly newsletters plus additional activities offered every 6 months, over 36 months IG2: IG1 + incentives | p=NS for all measures Blood pressure: NR Lipids: NR Glucose tolerance: NR
Medium-intensity interventions (estimated 31–360 minutes)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | | Baseline | | 12 months
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | BMI, kg/m^2^
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 23.6 | 46 | −0.5 (1.4)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 24.0 | 41 | −0.1 (1.1)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | SBP, mmHg
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 127.6 | 46 | −5.2 (14.3)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 132.0 | 41 | −8.7 (14.0)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | DBP, mmHg
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 78.2 | 46 | −3.7 (8.7)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 79.3 | 41 | −3.8 (7.7)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | Total cholesterol, mmol/L
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 5.28 | 46 | −0.06 (0.74)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 5.35 | 41 | 0.07 (0.68)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | HDL, mmol/L
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 1.41 | 46 | 0.06 (0.28)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 1.44 | 41 | 0.02 (0.27)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | LDL, mmol/L
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 3.13 | 46 | −0.04 (0.66)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 3.20 | 41 | 0.00 (0.59)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | Trigylcerides, mmol/L
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 1.97 | 46 | −0.31 (0.94)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 1.87 | 41 | 0.02 (0.85)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | | [underlined: N] | Percent (SD) | [underlined: N] | Percent (SD)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | HbA1c
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 5.5 | 46 | 5.5 (0.4)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 5.4 | 41 | 5.4 (0.4)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | | [underlined: N] | [underlined: N (Percent)] | [underlined: N] | [underlined: N (Percent)]
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | Diabetic
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 50 | 10 (20.0) | 46 | 11 (23.9)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 49 | 7 (14.3) | 41 | 10 (24.4)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | Hypertensive
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 50 | 15 (30.0) | 46 | 10 (21.7)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 49 | 15 (30.6) | 41 | 6 (14.6)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130–159, DBP 85–99, or A1C 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | p=NS for all measures
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | | | Baseline | 12 months
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | BMI, kg/m^2^
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG2 | 25 | 26.1 | −0.72 (1.20)*
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 26.1 | 0.22 (1.36)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Total cholesterol, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG2 | 25 | 4.74 | 0.37 (0.73)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 5.03 | 0.24 (0.58)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | HDL, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG2 | 25 | 1.16 | 0.11 (0.17)*
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 1.31 | −0.04 (0.16)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | LDL, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG2 | 25 | 2.73 | 0.23 (0.55)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 3.23 | 0.28 (0.49)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Triglycerides, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG2 | 25 | 1.26 | 0.08 (0.48)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 1.10 | 0.01 (0.23)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Fasting blood glucose, mmol/L
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG2 | 25 | 5.13 | −0.43 (0.59)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 5.04 | −0.21 (0.51)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Blood pressure: NR
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | | | Baseline | 6 months
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | | [underlined: N] | [underlined: Mean] | [underlined: Mean Change (SD)]
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | BMI, kg/m^2^
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 33.67 | −0.21 (1.42)**
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 34.28 | 0.15 (1.14)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | SBP, mmHg
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 134.05 | −2.90 (10.83)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 133.29 | −0.60 (10.64)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | DBP, mmHg
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 83.52 | −1.98 (7.27)***
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 82.41 | 0.49 (7.21)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | Cholesterol, mmol/L
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 5.48 | −0.14 (0.71)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 5.42 | 0.00 (0.69)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | HDL, mmol/L
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 1.46 | −0.05 (0.14)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 1.53 | −0.07 (0.34)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | LDL, mmol/L
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 2.94 | 0.09 (1.00)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 3.03 | 0.25 (0.92)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | Triglycerides, mmol/L
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 1.96 | −0.17 (1.14)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 1.73 | −0.15 (0.92)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | Glucose tolerance: NR ** p<0.01 for t-value between IG and CG *** p<0.001 for t-value between IG and CG
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | | | Baseline | 6 months
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | BMI, kg/m^2^
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 26.1 | −0.6 (0.96)*
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 24.5 | 0.3 (0.64)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | SBP, mmHg
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 129 | −4 (9.6)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 130 | −1 (11.2)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | DBP, mmHg
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 81 | −2 (8.0)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 82 | −1 (6.4)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | Total cholesterol, mmol/L
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 6.53 | −0.45 (1.02)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 5.97 | −0.13 (0.64)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | LDL, mmol/L
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 4.66 | −0.35 (0.94)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 4.14 | −0.15 (0.56)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | HDL, mmol/L
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 1.33 | −0.03 (0.21)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 1.36 | −0.02 (0.21)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | Triglycerides, mmol/L
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 1.57 | −0.12 (0.62)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 1.33 | 0.06 (0.45)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | Glucose tolerance: NR *p<0.05
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | | Baseline | | 12 months
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | Weight, kg
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | IG | 108 | 82.3 | 106 | −0.06 (4.8)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | CG | 110 | 81.8 | 106 | −0.10 (4.2)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | SBP, mmHg
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | IG | 107 | 126 | 105 | 0.0 (15.4)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | CG | 110 | 129 | 105 | −4.0 (15.7)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | DBP, mmHg
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | IG | 107 | 77 | 105 | 2.0 (8.5)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | CG | 110 | 80 | 106 | −1.0 (9.5)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | Total cholesterol, mmol/L
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | IG | 106 | 5.30 | 106 | −0.15 (0.86)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | CG | 110 | 5.56 | 106 | −0.41 (0.74)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | HDL, mmol/L
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | IG | 106 | 1.47 | 106 | 0.0 (0.27)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | CG | 110 | 1.45 | 106 | 0.05 (0.25)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | LDL, mmol/L
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | IG | 102 | 3.12 | 103 | −0.17 (0.70)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | CG | 103 | 3.36 | 101 | −0.39 (0.66)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | Glucose tolerance: NR p=NS for all measures
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | | | Baseline | 12 months
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (95% CI)]
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | BMI, kg/m^2^
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 27.8 | −0.1 (2.7)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 28.4 | 0.0 (2.9)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | SBP, mmHg
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 126.7 | 3.0 (15.1)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 126.4 | 3.4 (13.9)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | DBP, mmHg
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 77.9 | 1.1 (10.3)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 77.0 | 1.9 (9.8)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | Total cholesterol, mmol/L
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 5.24 | −0.01 (0.89)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 5.32 | −0.07 (0.87)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | LDL, mmol/L
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 3.32 | −0.12 (0.83)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 3.38 | −0.17 (0.76)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | HDL, mmol/L
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 1.51 | 0.01 (0.40)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 1.55 | −0.06 (0.36)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | Triglycerides, mmol/L
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 1.30 | −0.02 (0.77)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 1.33 | 0.02 (0.70)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | Glucose, mmol/L
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 5.44 | 0.01 (0.75)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 5.52 | −0.04 (0.84)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | p=NS for all measures
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | | | Baseline | 12 months
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | | [underlined: N] | [underlined: Mean] | [underlined: Mean Change (SD)]
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | SBP, mmHg
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | IG | 157 | 139.0 | −7.49 (15.85)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | CG | 158 | 136.1 | −3.58 (16.03)*
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | Total cholesterol, mmol/L
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | IG | 157 | 5.8 | −0.41 (1.15)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | CG | 158 | 5.6 | −0.14 (1.15)*
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | HDL, mmol/L
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | IG | 157 | 1.3 | 0.04 (0.19)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | CG | 158 | 1.3 | 0.03 (0.19)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | Glucose, mmol/L
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | IG | 157 | 8.3 | −0.37 (3.07)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | CG | 158 | 8.1 | 0.01 (2.69)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | Framingham risk score
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | IG | 157 | 12.5 | −3.10 (5.36)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | CG | 158 | 11.0 | −1.30 (5.64)*
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | Adiposity: self-reported only * p<0.05
High-intensity interventions (estimated >360 minutes)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | | | Baseline | 6 months
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | BMI, kg/m^2^
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | IG | 174 | 33.3 | −1.6 (1.8)*
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | CG | 174 | 31.4 | −0.3 (1.3)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | SBP, mmHg
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | IG | 174 | 129 | −5 (12)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | CG | 174 | 128 | −4 (11)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | DBP, mmHg
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | IG | 174 | 78.3 | −5.5 (8.7)*
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | CG | 174 | 76.7 | −3.8 (7.7)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | Total cholesterol, mmol/L
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | IG | 174 | 4.99 | 0.16 (0.71)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | CG | 174 | 4.91 | 0.28 (0.78)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | HDL, mmol/L
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | IG | 174 | 1.16 | 0.04 (0.18)*
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | CG | 174 | 1.16 | 0.05 (0.11)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | LDL, mmol/L
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | IG | 174 | 3.15 | 0.13 (0.60)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | CG | 174 | 3.13 | 0.23 (0.74)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | Triglycerides, mmol/L
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | IG | 174 | 1.50 | −0.06 (0.81)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | CG | 174 | 1.29 | 0.02 (0.96)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | Fasting glucose, mmol/L
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | IG | 174 | 5.72 | −0.17 (0.79)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | 4 group sessions (120 minutes each) over 4 weeks | CG | 174 | 5.56 | −0.06 (2.53)
Edelman, 2005^115^ US Fair | N=294 20% men Mean age 53 23% nonwhite Selected for 1 or more CV risk factors (including BMI) | 2 individual sessions and 28 group sessions, plus 20 followup phone calls over 10 months | | Baseline | | 10 months
Edelman, 2005^115^ US Fair | N=294 20% men Mean age 53 23% nonwhite Selected for 1 or more CV risk factors (including BMI) | 2 individual sessions and 28 group sessions, plus 20 followup phone calls over 10 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean Change]
Edelman, 2005^115^ US Fair | N=294 20% men Mean age 53 23% nonwhite Selected for 1 or more CV risk factors (including BMI) | 2 individual sessions and 28 group sessions, plus 20 followup phone calls over 10 months | BMI, kg/m^2^
Edelman, 2005^115^ US Fair | N=294 20% men Mean age 53 23% nonwhite Selected for 1 or more CV risk factors (including BMI) | 2 individual sessions and 28 group sessions, plus 20 followup phone calls over 10 months | IG | 77 | 33.3 | 56 | −1.2
Edelman, 2005^115^ US Fair | N=294 20% men Mean age 53 23% nonwhite Selected for 1 or more CV risk factors (including BMI) | 2 individual sessions and 28 group sessions, plus 20 followup phone calls over 10 months | CG | 77 | 34.1 | 66 | −0.6
Edelman, 2005^115^ US Fair | N=294 20% men Mean age 53 23% nonwhite Selected for 1 or more CV risk factors (including BMI) | 2 individual sessions and 28 group sessions, plus 20 followup phone calls over 10 months | Blood pressure: data primarily reported in a figure. IG and CG overall decline in SBP of 8 mmHg. Lipids: data primarily reported in a figure. Overall decline in LDL-cholesterol for IG and CG of 7 mg/dL. Difference in change in LDL- cholesterol between baseline and 5 months was statistically significant between IG and CG (p=0.02), but not at 10 months (p=0.25). Glucose tolerance: NR *p<0.05
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | | | Baseline | 12 months | 24 months
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | | [underlined: N] | [underlined: Mean] | [underlined: Mean Change (SD)] | [underlined: Mean Change (SD)]
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | BMI, kg/m^2^
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 22.4 | −0.1 (0.8) | −0.3 (1.5)*
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 22.4 | 0.4 (1.5) | 0.2 (1.5)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | SBP, mmHg
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 111 | -- | 5 (15.2)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 110 | -- | 7 (15.1)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | DBP, mmHg
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 70 | -- | 2 (7.6)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 71 | -- | 0 (7.6)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | Total cholesterol, mmol/L
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 4.55 | -- | 0.02 (0.76)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 4.33 | -- | 0.26 (0.60)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | HDL, mmol/L
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 1.30 | -- | 0.20 (0.23)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 1.31 | -- | 0.27 (0.23)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | LDL, mmol/L
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 2.68 | -- | −0.14 (0.53)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 2.52 | -- | −0.06 (0.53)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | Triglycerides, mmol/L
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 1.24 | -- | −0.10 (0.61)*
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 1.11 | -- | 0.10 (0.45)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | Glucose tolerance: NR * ANOVA p<0.05 for group effect
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | | Baseline | | 12 months | | 24 months
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean Change (SD)] | [underlined: N] | [underlined: Mean Change (SD)]
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | Weight, kg
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 35 | 83.3 | 35 | −1.1 (3.4)* | 35 | −1.8 (5.9)*
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 32 | 85.5 | 32 | 1.5 (2.6) | 32 | 1.5 (2.6)
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | SBP, mmHg
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 35 | 137.2 | 35 | −7.9 (17.6) | -- | --
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 32 | 132.8 | 32 | −0.2 (13.0) | -- | --
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | DBP, mmHg
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 35 | 77.0 | 35 | −2.9 (10.4) | -- | --
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 32 | 75.5 | 32 | 1.9 (8.0) | -- | --
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | Total cholesterol, mmol/L
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 34 | 5.7 | 31 | −0.12 (0.62) | ? | 0.04 (0.79)
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 31 | 5.7 | 29 | −0.12 (0.63) | ? | −0.06 (0.59)
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | HDL, mmol/L
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 32 | 1.2 | -- | -- | -- | --
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 31 | 1.1 | -- | -- | -- | --
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | LDL, mmol/L
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 33 | 3.6 | 30 | −0.11 (0.58) | | −0.09 (0.71)
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 31 | 3.5 | 30 | −0.13 (0.69) | | −0.14 (0.56)
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | Triglycerides, mmol/L
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 34 | 1.9 | -- | -- | -- | --
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 31 | 2.2 | -- | -- | -- | --
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | Fasting plasma glucose, mmol/L
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 35 | 6.0 | 32 | 0.03 (0.60) | 30 | 0.25 (0.77)
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 32 | 6.2 | 30 | 0.08 (0.97) | 24 | 0.12 (1.0)
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | * p<0.05
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | | | Baseline | 18 months | 54 months
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | BMI, kg/m^2^
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | IG | 236 | 24.9 | −1.1 (1.4)* | -- | 0.05 (2.0)*
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | CG | 253 | 25.1 | 0.1 (1.5) | -- | 0.96 (1.8)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | SBP, mmHg
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | IG | 236 | 110.0 | −2.7 (11.5)* | -- | −0.12 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | CG | 253 | 110.1 | −0.5 (10.6) | -- | 0.20 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | DBP, mmHg
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | IG | 236 | 68.5 | 1.4 (7.0) | -- | 1.5 (--)*
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | CG | 253 | 67.9 | 1.9 (7.0) | -- | 2.2 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | Cholesterol, mmol/L
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | IG | 236 | 4.9 | −0.04 (0.62) | -- | --
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | CG | 253 | 4.9 | 0.20 (0.57) | -- | --
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | LDL, mmol/L
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | IG | 236 | 2.97 | −0.11 (0.53)* | -- | 0.09 (--)*
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | CG | 253 | 3.01 | 0.07 (0.52) | -- | 0.23 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | HDL, mmol/L
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | IG | 236 | 1.54 | 0.03 (0.25) | -- | 0.06 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | CG | 253 | 1.51 | 0.08 (0.23) | -- | 0.08 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | Triglycerides, mmol/L
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | IG | 236 | 0.93 | 0.03 (0.40)* | -- | 0.21 (--)*
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | CG | 253 | 0.88 | 0.09 (0.45) | -- | 0.34 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | Fasting glucose, mmol/L
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | IG | 236 | 5.45 | 0.07 (0.43)* | -- | 0.09 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | CG | 253 | 5.43 | 0.16 (0.42) | -- | 0.18 (--)
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail, or phone followup after initial 5 months | * p<0.05
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | | | Baseline | 12 months | 18 months
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change]
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | BMI, kg/m^2^
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 100 | 29.5 | −0.1 (2.7) | −0.1
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 100 | 29.2 | 0.3 (2.9) | 0.4
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | SBP, mmHg
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 100 | 115.8 | −1.4 (11.8) | −0.9
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 100 | 116.6 | 0.1 (10.9) | 0.4
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | DBP, mmHg
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 100 | 67.6 | 0.4 (9.5) | 0.3
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 100 | 68.7 | 0.4 (8.3) | 0.1
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | Total cholesterol, mmol/L
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 100 | 4.34 | −0.14 (0.72) | −0.16*
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 100 | 4.36 | −0.14 (0.56) | −0.09
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | LDL, mmol/L
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 100 | 2.42 | −0.16 (0.57) | −0.14*
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 100 | 2.38 | −0.15 (0.45) | −0.11
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | HDL, mmol/L
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 100 | 1.26 | 0.03 (0.25) | 0.0*
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 100 | 1.31 | 0.03 (0.22) | −0.01
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | Triglycerides, mmol/L
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 100 | 1.46 | −0.05 (0.56) | −0.06
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 100 | 1.46 | −0.06 (0.51) | 0.04
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | Fasting blood glucose, mmol/L
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 100 | 5.20 | −0.03 (0.43) | −0.08
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 100 | 5.16 | −0.01 (0.42) | 0.0
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | * RM ANOVA effect of visit p<0.05

BMI – body mass index; CV – cardiovascular; DBP – diastolic blood pressure; DM – diabetes mellitus; FPL – federal poverty level; HD – healthful diet; HDL – high density lipoprotein; IFG – impaired fasting glucose; LDL – low density lipoprotein; NR – not reported; NS – not significant; PA – physical activity; PCP – primary care physician; RM – repeated measures; SBP – systolic blood pressure; SD – standard deviation; US – United States; UK – United Kingdom

Thirteen of the 14 trials evaluating lifestyle counseling reported weight or BMI as a measure of adiposity.47,81,110,112,115,117,119–124,127 Meta-analyses showed a statistically significant reduction in adiposity (SMD, −0.40 [95% CI, −0.62 to −0.18]; k=12; N=3,247), with high statistical heterogeneity (I^2^=88%). Six of these 12 trials showed a statistically significant reduction in BMI.47,81,110,117,119,127 Stratified meta-analyses by intervention intensity (Figure 18) and population risk showed statistically significant reductions in adiposity for both medium- and high-intensity interventions, but statistical heterogeneity remained high within each subset (Figure 18). Longer-term followup from four trials illustrated that statistically significant reductions in BMI persist for up to 54 months.119,123,124,127

Figure 18 Meta-Analysis of Combined Lifestyle Trials (KQ2): Adiposity

Figure 18 displays a forest plot of combined lifestyle trials reporting between-group differences in adiposity (reported as either body mass index or weight). Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (1 trial) the standardized mean difference was −0.04 (95% CI, −0.17 to 0.10). In the moderate-intensity (31 to 360 minutes) subgroup (6 trials) the combined standardized mean difference was −0.34 (95% CI, −0.61 to −0.07). In the high-intensity (more than 360 minutes) subgroup (5 trials) the combined standardized mean difference was −0.54 (95% CI, −0.82 to −0.25). The overall standardized mean difference for all 12 combined lifestyle trials was −0.40 (95% CI, −0.62 to −0.18), indicating that there was a statistically significant reduction in adiposity. However, there was substantial statistical heterogeneity, both within the moderate-intensity subgroup (chi-square=78.1%; p=0.000) and the high-intensity subgroup (chi-square=80.9%; p=0.000) and across all subgroups (chi-square=88.2%; p=0.000).

Twelve of the 14 trials reported blood pressure outcomes.47,110,112,115,117,119,121–124,127,131 None of these were low-intensity interventions. Meta-analyses showed an average reduction of 1.40 mmHg for systolic blood pressure (95% CI, −2.77 to −0.03; I^2^=43.7%; k=10; N=2,592) (Figure 19), but no reduction in diastolic blood pressure (WMD, −0.76 mmHg [95% CI, −1.89 to 0.36]; I^2^=58.0%; k=9; N=2,278) (Figure 20). Stratified meta-analysis showed that reductions in systolic blood pressure were only apparent in the high-intensity trials (WMD, −1.87 mmHg [95% CI, −3.24 to −0.50]; I^2^=2.7%; k=4; N=1,104). In the three trials (n=850) that reported longer-term followup, changes in systolic blood pressure were no longer statistically significant at 24 and 54 months.119,124,127

Figure 19 Meta-Analysis of Combined Lifestyle Trials (KQ2): Systolic Blood Pressure

Figure 19 displays a forest plot of combined lifestyle trials reporting between-group differences in systolic blood pressure. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (6 trials) the combined unstandardized weighted mean difference was −0.76 (95% CI, −3.05 to 1.54). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −1.87 (95% CI, −3.24 to −0.50). The overall unstandardized weighted mean difference for all 10 combined lifestyle trials was −1.40 (95% CI, −2.77 to −0.03), indicating that there was a statistically significant reduction in systolic blood pressure. There was moderate statistical heterogeneity, both within the moderate-intensity subgroup (chi-square=59.4%; p=0.031) and between the moderate- and high-intensity subgroups (chi-square=43.7%; p=0.067).

Figure 20 Meta-Analysis of Combined Lifestyle Trials (KQ2): Diastolic Blood Pressure

Figure 20 displays a forest plot of combined lifestyle trials reporting between-group differences in diastolic blood pressure. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (5 trials) the combined unstandardized weighted mean difference was −0.27 (95% CI, −2.27 to 1.73). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −1.10 (95% CI, −2.38 to 0.19). The overall unstandardized weighted mean difference for all 9 combined lifestyle trials was −0.76 (95% CI, −1.89 to 0.36), indicating that there was not a statistically significant effect on diastolic blood pressure. There was significant statistical heterogeneity, both within the moderate-intensity subgroup (chi-square=71.9%; p=0.007) and between the moderate- and high-intensity subgroups (chi-square=58.0%; p=0.015).

Thirteen of the 14 trials reported on lipid measures.47,81,110,112,115,117,119,121–124,127,131 Again, there were no low-intensity interventions. Meta-analyses did not show a statistically significant improvement at 6 to 12 months in total cholesterol (k=11; N=2,637) (Figure 21), LDL (k=10; N=2,312) (Figure 22), HDL (k=11; N=2,634) (Figure 23), or triglycerides (k=9; N=2,110) (Figure 24). Pooled effect sizes for all of these outcomes, however, were very close to being statistically significant when limited to high-intensity trials. In the three trials with longer-term followup, reductions in total cholesterol, LDL, and/or triglycerides were statistically significant at 18 and 54 months.119,124,127

Figure 21 Meta-Analysis of Combined Lifestyle Trials (KQ2): Total Cholesterol

Figure 21 displays a forest plot of combined lifestyle trials reporting between-group differences in total cholesterol. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (7 trials) the combined unstandardized weighted mean difference was −0.05 (95% CI, −0.20 to 0.10). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −0.13 (95% CI, −0.25 to 0.00). The overall unstandardized weighted mean difference for all 11 combined lifestyle trials was −0.07 (95% CI, −0.18 to 0.03), indicating that there was not a statistically significant effect on total cholesterol. There was moderate statistical heterogeneity, both within the moderate-intensity subgroup (chi-square=64.5%; p=0.010) and the high-intensity subgroup (chi-square=50.0%; p=0.112) and between the two subgroups (chi-square=63.5%; p=0.002).

Figure 22 Meta-Analysis of Combined Lifestyle Trials (KQ2): Low-Density Lipoproteins

Figure 22 displays a forest plot of combined lifestyle trials reporting between-group differences in low-density lipoprotein (LDL) cholesterol. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (6 trials) the combined unstandardized weighted mean difference was 0.00 (95% CI, −0.13 to 0.12). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −0.10 (95% CI, −0.20 to 0.00). The overall unstandardized weighted mean difference for all 10 combined lifestyle trials was −0.04 (95% CI, −0.13 to 0.05), indicating that there was not a statistically significant effect on LDL cholesterol. There was moderate statistical heterogeneity, both within the moderate-intensity subgroup (chi-square=46.5%; p=0.096) and between the moderate- and high-intensity subgroups (chi-square=54.6%; p=0.019).

Figure 23 Meta-Analysis of Combined Lifestyle Trials (KQ2): High-Density Lipoproteins

Figure 23 displays a forest plot of combined lifestyle trials reporting between-group differences in high-density lipoprotein (HDL) cholesterol. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (7 trials) the combined unstandardized weighted mean difference was 0.03 (95% CI, −0.01 to 0.07). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −0.02 (95% CI, −0.05 to 0.00). The overall unstandardized weighted mean difference for all 11 combined lifestyle trials was 0.00 (95% CI, −0.03 to 0.03), indicating that there was not a statistically significant effect on HDL cholesterol. There was moderate statistical heterogeneity, both within the moderate-intensity subgroup (chi-square=55.0%; p=0.038) and between the moderate- and high-intensity subgroups (chi-square=57.2%; p=0.009).

Figure 24 Meta-Analysis of Combined Lifestyle Trials (KQ2): Triglycerides

Figure 24 displays a forest plot of combined lifestyle trials reporting between-group differences in triglycerides. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (5 trials) the combined unstandardized weighted mean difference was −0.06 (95% CI, −0.16 to 0.04). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −0.05 (95% CI, −0.11 to 0.01). The overall unstandardized weighted mean difference for all 9 combined lifestyle trials was −0.05 (95% CI, −0.10 to 0.00), indicating that there was not a statistically significant effect on triglycerides. There was no statistical heterogeneity across the subgroups (chi-square=0.0%; p=0.713).

Only eight of the 14 trials evaluating combined lifestyle counseling reported glucose tolerance outcome measures.81,110,112,122–124,127,131 Combined lifestyle counseling did not improve glucose tolerance outcomes (WMD, −0.06 mmol/L [95% CI, −0.11 to 0.00]; I^2^=0.0%; k=7; N=1,927) (Figure 25).

Figure 25 Meta-Analysis of Combined Lifestyle Trials (KQ2): Glucose

Figure 25 displays a forest plot of combined lifestyle trials reporting between-group differences in glucose tolerance. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (3 trials) the combined unstandardized weighted mean difference was −0.08 (95% CI, −0.32 to 0.15). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −0.07 (95% CI, −0.13 to −0.01). The overall unstandardized weighted mean difference for all 7 combined lifestyle trials was −0.06 (95% CI, −0.11 to 0.00), indicating that there was not a statistically significant effect on glucose tolerance. There was no statistical heterogeneity across the subgroups (chi-square=0.0%; p=0.501).

The majority of included trials were rated fair quality, and there was significant clinical and statistical heterogeneity amongst the trials. Some of this heterogeneity could be attributed to different levels of counseling intensity or population risk. In addition, only half110,115,120–122,124,127 of the trials were conducted in the United States, and five studies selected the study population from primary care.47,112,117,121,122 Overall, there was no evidence for statistically significant publication bias based on the Egger’s test for any intermediate outcome.

### Exploring Heterogeneity

We conducted meta-regressions examining study characteristics’ effects on intermediate health outcomes. These regressions focused on adiposity, blood pressure (systolic and diastolic), and lipids (total cholesterol and LDL) using all data available from the 66 included studies. We ran multivariate models including each of the four primary predictor variables (intervention target, risk status of the sample, intensity of the intervention, and recruitment strategy) on each of the five outcomes. Intervention intensity and participants’ risk group predicted effect size for adiposity and systolic blood pressure. High-intensity interventions were associated with larger than average reductions in adiposity and systolic blood pressure. Paradoxically, medium-intensity interventions had smaller effect sizes than low-intensity interventions on average, although this low-intensity estimate is based on only three trials for this outcome. As such, this result should not be considered robust.

In addition, risk status was a significant predictor of both adiposity and systolic blood pressure. Samples selected for cardiovascular risk or suboptimal behavior showed smaller reductions in adiposity compared with unselected samples. Samples selected for suboptimal behavior showed greater average reductions in systolic blood pressure than other samples. Given the small number of trials in some intensity levels and risk groups, however, these results should be interpreted cautiously.

Further exploratory analyses of additional potential sources of heterogeneity found that the effects on adiposity, systolic and diastolic blood pressure, and total cholesterol were slightly reduced in studies conducted in the United States after adjusting for the four a priori predictor variables, compared with those conducted in other countries. More recent publication was associated with reduced average effect sizes for systolic blood pressure, total cholesterol, and LDL. Additionally, percent male, percent nonwhite (among U.S.-based studies only), study quality, and degree of calculation/estimation needed for inclusion in the meta-analysis each predicted one or two intermediate health outcomes. However, due to the exploratory nature of these analyses, the small number of trials in important subgroups, and the number of models run, these effects should be interpreted with great caution. In addition, those exploratory analyses using study-level patient characteristics (i.e., sex, race, and baseline BMI), are vulnerable to ecologic fallacy. Forest plots of meta-analyses combining trials from all three intervention targets and stratified by intervention intensity of the population are provided in Appendix G.

## Key Question 3. Do primary care-relevant behavioral counseling interventions for physical activity and/or healthful diet change associated health behaviors in adults?

### Physical Activity

Overall, counseling increased participants’ physical activity levels, especially in trials that provided at least medium-intensity interventions. All 30 trials of physical-activity interventions meeting our inclusion criteria reported at least one behavioral outcome (Table 6). Eleven of these studies delivered low-intensity interventions,32,33,38,40,44,52,60,61,66,70,75 19 delivered medium-intensity interventions,34,36,41,42,46,47,50,53,55,56,58–60,62,64,68,69,72,74 and one trial delivered a high-intensity intervention.71 One of these trials included both low- and medium-intensity arms, and, as such, is discussed with each of these bodies of literature.60 Seven of the included trials were rated as good quality,36,40,50,58,59,62,64 all but one40 of which were medium-intensity trials. Nineteen studies recruited from primary care, and an additional three studies recruited from general-risk populations comparable to primary care populations. Sixteen trials were conducted in the United States, 34,38,41,42,52,53,55,60,62,64,66,68,69,71,74,75 nine of which involved primary care populations.34,38,41,52,62,64,68,69,71 A number of trials focused specifically on middle-aged and/or older adults; seven were limited to adults aged 60 or older.42,44,50,58,64,69,71 The remaining trials, which included a wide range of ages, reported average ages in the 40s or 50s. The populations for these trials were approximately one third men and one fifth nonwhite. Individual trial details are summarized in Table 6.

Table 6 Randomized Controlled Trials for Physical Activity Counseling Interventions: Behavioral Outcomes

Author, year Country Quality | Population details (total n, sex, age, race/ethnicity) | Intervention details | Behavioral outcomes (self-reported unless otherwise noted)
Low-intensity interventions (estimated 0–30 minutes)
Aittasalo, 2006^32^ Finland Fair | N=265 24% men Mean age 47 Race/ethnicity NR Selected for sedentary behavior and age 20–65 years | One counseling session with PCP with a subset receiving a pedometer | | | Baseline | 6 months
Aittasalo, 2006^32^ Finland Fair | N=265 24% men Mean age 47 Race/ethnicity NR Selected for sedentary behavior and age 20–65 years | One counseling session with PCP with a subset receiving a pedometer | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Aittasalo, 2006^32^ Finland Fair | N=265 24% men Mean age 47 Race/ethnicity NR Selected for sedentary behavior and age 20–65 years | One counseling session with PCP with a subset receiving a pedometer | Any physical activity, minutes/week
Aittasalo, 2006^32^ Finland Fair | N=265 24% men Mean age 47 Race/ethnicity NR Selected for sedentary behavior and age 20–65 years | One counseling session with PCP with a subset receiving a pedometer | IG | 192 | 368 | 167 (728)
Aittasalo, 2006^32^ Finland Fair | N=265 24% men Mean age 47 Race/ethnicity NR Selected for sedentary behavior and age 20–65 years | One counseling session with PCP with a subset receiving a pedometer | CG | 73 | 430 | 50 (736)
Aittasalo, 2006^32^ Finland Fair | N=265 24% men Mean age 47 Race/ethnicity NR Selected for sedentary behavior and age 20–65 years | One counseling session with PCP with a subset receiving a pedometer | p=NS
de Vet, 2009^33^ Netherlands Fair | N=709 33% men Mean age 46 Race/ethnicity NR Selected for age 18–65 years | Questionnaire with section encouraging implementation plan for walking or self-selected activity, with a subset receiving 2 followup questionnaires | | | Baseline | 6 months
de Vet, 2009^33^ Netherlands Fair | N=709 33% men Mean age 46 Race/ethnicity NR Selected for age 18–65 years | Questionnaire with section encouraging implementation plan for walking or self-selected activity, with a subset receiving 2 followup questionnaires | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
de Vet, 2009^33^ Netherlands Fair | N=709 33% men Mean age 46 Race/ethnicity NR Selected for age 18–65 years | Questionnaire with section encouraging implementation plan for walking or self-selected activity, with a subset receiving 2 followup questionnaires | Moderate-intensity physical activity, minutes/week
de Vet, 2009^33^ Netherlands Fair | N=709 33% men Mean age 46 Race/ethnicity NR Selected for age 18–65 years | Questionnaire with section encouraging implementation plan for walking or self-selected activity, with a subset receiving 2 followup questionnaires | IG | 397 | 458 | 56 (678)
de Vet, 2009^33^ Netherlands Fair | N=709 33% men Mean age 46 Race/ethnicity NR Selected for age 18–65 years | Questionnaire with section encouraging implementation plan for walking or self-selected activity, with a subset receiving 2 followup questionnaires | CG | 163 | 519 | 43 (800)
de Vet, 2009^33^ Netherlands Fair | N=709 33% men Mean age 46 Race/ethnicity NR Selected for age 18–65 years | Questionnaire with section encouraging implementation plan for walking or self-selected activity, with a subset receiving 2 followup questionnaires | p=NS
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | | | Baseline | 6 months
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | Moderate and vigorous activity, minutes/week
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | IG | 2248 | 34.4 | 82.6 (547.8)*
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | CG | 2069 | 33.2 | 65.1 (527.7)
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | Meeting physical activity recommendation, percent †
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | IG | 2248 | 0 | 18.8 (--)*
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | CG | 2069 | 0 | 15.0 (--)
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | VO _2_ max, mL/kg/minute
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | IG | 2248 | 24.4 | 1.2 (8.2)
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | CG | 2069 | 24.7 | 1.1 (8.0)
Grandes, 2009^40^ Spain Good | N=4317 34% men Mean age 50 Race/ethnicity NR Selected for sedentary behavior and age 20–80 years | One brief counseling visit with PCP using Web-based software, additional visit offered, printed pamphlet | * p<0.05 in multivariate model
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | | Baseline | | 8 months
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | PASE score
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | IG | 181 | 108.5 | 158 | 4.1 (96.3)
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | CG | 174 | 108.8 | 154 | 2.2 (82.8)
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | Meeting physical activity recommendation, percent †
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | IG | 181 | 15 | 159 | 13 (--)
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | CG | 174 | 17 | 157 | 7 (--)
Goldstein, 1999^38^ US Fair | N=355 35% men Mean age 66 3% nonwhite Selected for age 50 years or older | One brief counseling visit with PCP including PA prescription, followup session scheduled, monthly mailed materials, PCP training and materials | p=NS
Halbert, 2000^44^ Australia Fair | N=299 46% male Mean age 68 Race/ethnicity NR Selected for sedentary behavior and age 60 years or older | One visit with exercise physiologist | | | Baseline | 12 months
Halbert, 2000^44^ Australia Fair | N=299 46% male Mean age 68 Race/ethnicity NR Selected for sedentary behavior and age 60 years or older | One visit with exercise physiologist | | [underlined: N] | [underlined: Median] | [underlined: Median (IQR)]
Halbert, 2000^44^ Australia Fair | N=299 46% male Mean age 68 Race/ethnicity NR Selected for sedentary behavior and age 60 years or older | One visit with exercise physiologist | Walking frequency, sessions/week
Halbert, 2000^44^ Australia Fair | N=299 46% male Mean age 68 Race/ethnicity NR Selected for sedentary behavior and age 60 years or older | One visit with exercise physiologist | IG | 149 | 0 | 3 (1–4)*
Halbert, 2000^44^ Australia Fair | N=299 46% male Mean age 68 Race/ethnicity NR Selected for sedentary behavior and age 60 years or older | One visit with exercise physiologist | CG | 150 | 0 | 2 (1–3)
Halbert, 2000^44^ Australia Fair | N=299 46% male Mean age 68 Race/ethnicity NR Selected for sedentary behavior and age 60 years or older | One visit with exercise physiologist | * p<0.05
Katz, 2008^52^ US Fair | N=316 33% men Mean age NR 65% nonwhite Selected for age 18 years or older | Special training for primary care residents | | Baseline | | 12 months
Katz, 2008^52^ US Fair | N=316 33% men Mean age NR 65% nonwhite Selected for age 18 years or older | Special training for primary care residents | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Katz, 2008^52^ US Fair | N=316 33% men Mean age NR 65% nonwhite Selected for age 18 years or older | Special training for primary care residents | Yale Physical Activity Survey, total index score
Katz, 2008^52^ US Fair | N=316 33% men Mean age NR 65% nonwhite Selected for age 18 years or older | Special training for primary care residents | IG | 195 | 27.1 | 185 | 1.9 (14.5)
Katz, 2008^52^ US Fair | N=316 33% men Mean age NR 65% nonwhite Selected for age 18 years or older | Special training for primary care residents | CG | 121 | 28.1 | 117 | 1.0 (16.4)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | | | Baseline | 12 months
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | Physical activity, minutes/week
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | IG | 81 | 20.2 | 142.2 (164.6)*
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | CG | 78 | 19.4 | 62.5 (123.3)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | VO _2_ max, mL/kg/minute
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | IG | 81 | 26.0 | 1.1 (8.9)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | CG | 78 | 25.6 | 0.7 (7.0)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | | [underlined: N] | [underlined: Mean] | [underlined: Mean (SD)]
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | Meeting physical activity recommendation, percent †
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | IG | 81 | -- | 49 (--)*
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | CG | 78 | -- | 17 (--)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for sedentary behavior and age 18–65 years | Mailed booklets and fourteen tailored reports | * p<0.01
Marshall, 2003^61^ Australia Fair | N=462 42% men Mean age 49 Race/ethnicity NR Selected for age 40–60 years | Mailed booklets and tailored letter | | | Baseline | 6 months
Marshall, 2003^61^ Australia Fair | N=462 42% men Mean age 49 Race/ethnicity NR Selected for age 40–60 years | Mailed booklets and tailored letter | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Marshall, 2003^61^ Australia Fair | N=462 42% men Mean age 49 Race/ethnicity NR Selected for age 40–60 years | Mailed booklets and tailored letter | Total physical activity, minutes/week
Marshall, 2003^61^ Australia Fair | N=462 42% men Mean age 49 Race/ethnicity NR Selected for age 40–60 years | Mailed booklets and tailored letter | IG | 227 | 3.0 | 18 (--)
Marshall, 2003^61^ Australia Fair | N=462 42% men Mean age 49 Race/ethnicity NR Selected for age 40–60 years | Mailed booklets and tailored letter | CG | 235 | 3.3 | −12 (--)
Marshall, 2003^61^ Australia Fair | N=462 42% men Mean age 49 Race/ethnicity NR Selected for age 40–60 years | Mailed booklets and tailored letter | Meeting physical activity recommendation, percent †
Marshall, 2003^61^ Australia Fair | N=462 42% men Mean age 49 Race/ethnicity NR Selected for age 40–60 years | Mailed booklets and tailored letter | IG | 227 | 26 | 14 (--)
Marshall, 2003^61^ Australia Fair | N=462 42% men Mean age 49 Race/ethnicity NR Selected for age 40–60 years | Mailed booklets and tailored letter | CG | 235 | 28 | 3 (--)
Napolitano, 2006^66^ US Fair | N=280 0% men Mean age NR 5% nonwhite Selected for sedentary behavior | Personalized letter with AHA booklet and another group received 4 tailored reports plus booklets | | | Baseline | 12 months
Napolitano, 2006^66^ US Fair | N=280 0% men Mean age NR 5% nonwhite Selected for sedentary behavior | Personalized letter with AHA booklet and another group received 4 tailored reports plus booklets | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Napolitano, 2006^66^ US Fair | N=280 0% men Mean age NR 5% nonwhite Selected for sedentary behavior | Personalized letter with AHA booklet and another group received 4 tailored reports plus booklets | Total physical activity, minutes/week
Napolitano, 2006^66^ US Fair | N=280 0% men Mean age NR 5% nonwhite Selected for sedentary behavior | Personalized letter with AHA booklet and another group received 4 tailored reports plus booklets | IG | 188 | 49.6 | 102.1 (209.1)
Napolitano, 2006^66^ US Fair | N=280 0% men Mean age NR 5% nonwhite Selected for sedentary behavior | Personalized letter with AHA booklet and another group received 4 tailored reports plus booklets | CG | 92 | 33.6 | 105.9 (182.1)
Napolitano, 2006^66^ US Fair | N=280 0% men Mean age NR 5% nonwhite Selected for sedentary behavior | Personalized letter with AHA booklet and another group received 4 tailored reports plus booklets | p=NS
Pekmezi, 2009^75^ US Fair | N=93 0% men Mean age 41 100% nonwhite Selected for sedentary behavior | Six monthly mailings including tailored manuals, pedometer, physical activity logs, and tip sheets | | | Baseline | 6 months
Pekmezi, 2009^75^ US Fair | N=93 0% men Mean age 41 100% nonwhite Selected for sedentary behavior | Six monthly mailings including tailored manuals, pedometer, physical activity logs, and tip sheets | | [underlined: N] | [underlined: Mean] | [underlined: Mean (SD)]
Pekmezi, 2009^75^ US Fair | N=93 0% men Mean age 41 100% nonwhite Selected for sedentary behavior | Six monthly mailings including tailored manuals, pedometer, physical activity logs, and tip sheets | Moderate- or vigorous-intensity physical activity, minutes/week
Pekmezi, 2009^75^ US Fair | N=93 0% men Mean age 41 100% nonwhite Selected for sedentary behavior | Six monthly mailings including tailored manuals, pedometer, physical activity logs, and tip sheets | IG | 45 | 16.56 | 147.27 (241.55)
Pekmezi, 2009^75^ US Fair | N=93 0% men Mean age 41 100% nonwhite Selected for sedentary behavior | Six monthly mailings including tailored manuals, pedometer, physical activity logs, and tip sheets | CG | 48 | 11.88 | 96.79 (118.49)
Pekmezi, 2009^75^ US Fair | N=93 0% men Mean age 41 100% nonwhite Selected for sedentary behavior | Six monthly mailings including tailored manuals, pedometer, physical activity logs, and tip sheets | p=NS
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | | | Baseline | 12 months
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | VO _2_ , mL/kg/minute at 2.0 mmol/L lactate concentration
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | IG | 23 | 21.5 | 1.4 (6.2)
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | CG | 18 | 20.3 | −1.5 (4.2)
Stensel, 1994^70^ UK Fair | N=72 100% men Mean age 51 Race/ethnicity NR Selected for sedentary behavior and age 42–59 years | Not described | * p<0.05 for change over time
Medium-intensity interventions (estimated 31–360 minutes)
Connell, 2009^74^ US Fair | N=157 0% men Mean age 67 7% nonwhite Unselected | 14 individualized counseling phone calls over 6 months, videos, pamphlet, workbooks, and newsletters | | Baseline | | 6 months | | 12 months
Connell, 2009^74^ US Fair | N=157 0% men Mean age 67 7% nonwhite Unselected | 14 individualized counseling phone calls over 6 months, videos, pamphlet, workbooks, and newsletters | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean (SD)] | [underlined: N] | [underlined: Mean (SD)]
Connell, 2009^74^ US Fair | N=157 0% men Mean age 67 7% nonwhite Unselected | 14 individualized counseling phone calls over 6 months, videos, pamphlet, workbooks, and newsletters | Total exercise/week score*
Connell, 2009^74^ US Fair | N=157 0% men Mean age 67 7% nonwhite Unselected | 14 individualized counseling phone calls over 6 months, videos, pamphlet, workbooks, and newsletters | IG | 74 | 5.2 | 74 | 7.0 (2.7)** | 69 | 6.1 (2.5)
Connell, 2009^74^ US Fair | N=157 0% men Mean age 67 7% nonwhite Unselected | 14 individualized counseling phone calls over 6 months, videos, pamphlet, workbooks, and newsletters | CG | 63 | 5.4 | 63 | 5.8 (2.7) | 61 | 5.9 (2.8)
Connell, 2009^74^ US Fair | N=157 0% men Mean age 67 7% nonwhite Unselected | 14 individualized counseling phone calls over 6 months, videos, pamphlet, workbooks, and newsletters | *Time spent in aerobic exercise, stretching, and strengthening was summed to yield a total exercise per week score. Scale values: 1=none, 2=<30 minutes, 3=30–60 minutes, 4=1–3 hours, 5=>3 hours ** p=0.01
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | | Baseline | | 6 months
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | Daily expenditure, kcal/kg/day
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | IG | 150 | 33.2 | 112 | 0.6 (3.1)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | CG | 148 | 33.5 | 131 | 0.1 (2.5)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | Meeting physical activity recommendation, percent †
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | IG | 150 | 16 | 112 | 13 (--)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | CG | 148 | 24 | 131 | 11 (--)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for sedentary behavior and suboptimal diet | 18 automated 10-minute phone calls over 6 months using phone-linked expert system | p=NS
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | | | Baseline | 12 months
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | | N | Mean | Mean change (SD)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | Exercise, minutes/week
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | IG | 451 | 11.3 | 54.6 (206.6)*
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | CG | 427 | 12.0 | 16.8 (139.2)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | Meeting physical activity recommendation, percent †
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | IG | 451 | 18 | 14 (--)*
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | CG | 427 | 21 | 5 (--)
Elley, 2003^36^ New Zealand Good | N=878 34% men Mean age 58 23% nonwhite Selected for sedentary behavior and age 40–79 years | One brief visit with general practitioner plus PA prescription, 3 phone calls from exercise physiologist, quarterly newsletters | * p<0.05
Green, 2002^41^ US Fair | N=316 48% men Mean age 44 8% nonwhite Selected for sedentary behavior and age 20–64 years | Tailored report from PCP, self-help workbook, three 20-to 30-minute phone calls | | | Baseline | 6 months
Green, 2002^41^ US Fair | N=316 48% men Mean age 44 8% nonwhite Selected for sedentary behavior and age 20–64 years | Tailored report from PCP, self-help workbook, three 20-to 30-minute phone calls | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Green, 2002^41^ US Fair | N=316 48% men Mean age 44 8% nonwhite Selected for sedentary behavior and age 20–64 years | Tailored report from PCP, self-help workbook, three 20-to 30-minute phone calls | PACE, score
Green, 2002^41^ US Fair | N=316 48% men Mean age 44 8% nonwhite Selected for sedentary behavior and age 20–64 years | Tailored report from PCP, self-help workbook, three 20-to 30-minute phone calls | IG | 128 | 5.0 | 0.4 (1.8)
Green, 2002^41^ US Fair | N=316 48% men Mean age 44 8% nonwhite Selected for sedentary behavior and age 20–64 years | Tailored report from PCP, self-help workbook, three 20-to 30-minute phone calls | CG | 128 | 4.7 | 0.1 (1.8)
Green, 2002^41^ US Fair | N=316 48% men Mean age 44 8% nonwhite Selected for sedentary behavior and age 20–64 years | Tailored report from PCP, self-help workbook, three 20-to 30-minute phone calls | p=NS
Greene, 2008^42^ US Fair | N=1.280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | Stage-based manual plus 9 newsletters, 3 phone calls with mailed tailored reports | | | Baseline | 12 months | 24 months
Greene, 2008^42^ US Fair | N=1.280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | Stage-based manual plus 9 newsletters, 3 phone calls with mailed tailored reports | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change]
Greene, 2008^42^ US Fair | N=1.280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | Stage-based manual plus 9 newsletters, 3 phone calls with mailed tailored reports | Yale Physical Activity Survey, summary score
Greene, 2008^42^ US Fair | N=1.280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | Stage-based manual plus 9 newsletters, 3 phone calls with mailed tailored reports | IG | 470 | 46 | 0.0 (38.0) | 1.0
Greene, 2008^42^ US Fair | N=1.280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | Stage-based manual plus 9 newsletters, 3 phone calls with mailed tailored reports | CG | 496 | 46 | 1.0 (33.0) | 1.0
Greene, 2008^42^ US Fair | N=1.280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | Stage-based manual plus 9 newsletters, 3 phone calls with mailed tailored reports | p=NS
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | IG1: Report from PCP, 40-minute motivational interview with specialty provider IG2: IG1 + 30 vouchers for community leisure centers IG3: IG1 + 5 additional visits with specialty provider IG4: IG3 + 30 vouchers for community leisure centers | | | Baseline | 12 months
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | | | [underlined: N] | [underlined: N (percent)] | [underlined: N (percent)]
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | | Increased physical activity by one or more levels
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | | IG1 | 96 | -- (--) | 22 (23)
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | | IG2 | 88 | -- (--) | 22 (26)
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | | IG3 | 88 | -- (--) | 27 (31)
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | | IG4 | 79 | -- (--) | 21 (27)
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | | CG | 91 | -- (--) | 21 (23)
Harland, 1999^46^ UK Fair | N=520 42% men Mean age NR Race/ethnicity NR Selected for age 40–64 years | | p=NS
Hellenius, 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | | | Baseline | 6 months
Hellenius, 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Hellenius, 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | Exercise sessions, number/month
Hellenius, 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | IG | 39 | 5.1 | 6.6 (9.4)*
Hellenius, 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | CG | 39 | 5.3 | 0.1 (8.9)
Hellenius, 1993^47^ Sweden Fair | N=79 100% men Mean age 45 Race/ethnicity NR Selected for slightly elevated total cholesterol | One counseling visit with physician, offered aerobic exercise class 2–3 times per week (attendance not required) | * p<0.05
Kallings, 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, 1 individual counseling session with specialty provider including PA prescription | | | Baseline | 6 months
Kallings, 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, 1 individual counseling session with specialty provider including PA prescription | | [underlined: N] | [underlined: Median] | [underlined: Median change (IQR)]
Kallings, 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, 1 individual counseling session with specialty provider including PA prescription | Moderate- or vigorous-intensity physical activity, sessions/week
Kallings, 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, 1 individual counseling session with specialty provider including PA prescription | IG | 41 | 2 | 1 (0–430)*
Kallings, 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, 1 individual counseling session with specialty provider including PA prescription | CG | 50 | 2 | -- (--)
Kallings, 2009^50^ Sweden Good | N=101 43% men Mean age NR Selected for age 64–74 years (calc), sedentary behavior, and overweight | One group session with physician, 1 individual counseling session with specialty provider including PA prescription | * p<0.001
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for being post-menopausal, age 50 years or older (46 years or older with a hysterectomy), and sedentary behavior | One 30- to 40-minute counseling session with specialty provider, 14 15- to 20-minute phone calls | | | Baseline | 12 months
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for being post-menopausal, age 50 years or older (46 years or older with a hysterectomy), and sedentary behavior | One 30- to 40-minute counseling session with specialty provider, 14 15- to 20-minute phone calls | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for being post-menopausal, age 50 years or older (46 years or older with a hysterectomy), and sedentary behavior | One 30- to 40-minute counseling session with specialty provider, 14 15- to 20-minute phone calls | Total physical activity, minutes/week
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for being post-menopausal, age 50 years or older (46 years or older with a hysterectomy), and sedentary behavior | One 30- to 40-minute counseling session with specialty provider, 14 15- to 20-minute phone calls | IG | 45 | 186 | 114 (354)*
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for being post-menopausal, age 50 years or older (46 years or older with a hysterectomy), and sedentary behavior | One 30- to 40-minute counseling session with specialty provider, 14 15- to 20-minute phone calls | CG | 40 | 168 | 6 (268)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for being post-menopausal, age 50 years or older (46 years or older with a hysterectomy), and sedentary behavior | One 30- to 40-minute counseling session with specialty provider, 14 15- to 20-minute phone calls | * p<0.03
King, 2007^55^ US Fair | N=218 30% men Mean age 62 12% nonwhite Selected for age 55 years or older and sedentary behavior | Four 45-minute and two 15-minute counseling phone calls, multiple mailings | | | Baseline | 12 months
King, 2007^55^ US Fair | N=218 30% men Mean age 62 12% nonwhite Selected for age 55 years or older and sedentary behavior | Four 45-minute and two 15-minute counseling phone calls, multiple mailings | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
King, 2007^55^ US Fair | N=218 30% men Mean age 62 12% nonwhite Selected for age 55 years or older and sedentary behavior | Four 45-minute and two 15-minute counseling phone calls, multiple mailings | CHAMPS moderate- or vigorous-intensity physical activity, minutes/week
King, 2007^55^ US Fair | N=218 30% men Mean age 62 12% nonwhite Selected for age 55 years or older and sedentary behavior | Four 45-minute and two 15-minute counseling phone calls, multiple mailings | IG | 127 | 160.0 | 211.1 (297.0)*
King, 2007^55^ US Fair | N=218 30% men Mean age 62 12% nonwhite Selected for age 55 years or older and sedentary behavior | Four 45-minute and two 15-minute counseling phone calls, multiple mailings | CG | 62 | 156.3 | 97.7 (252.4)
King, 2007^55^ US Fair | N=218 30% men Mean age 62 12% nonwhite Selected for age 55 years or older and sedentary behavior | Four 45-minute and two 15-minute counseling phone calls, multiple mailings | * p<0.05
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | | | Baseline | 12 months
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | Total reported activity, MET hours/week
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | IG | 107 | 89.3 | 15.9 (69.7)
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | CG | 111 | 84.4 | 17.0 (70.0)
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | VO _2_ max, L/minute
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | IG | 107 | 3.24 | 0.2 (1.3)
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | CG | 111 | 3.16 | 0.0 (1.1)
Kinmonth, 2008^56^ UK Fair | N=365 % men NR Mean age NR Race/ethnicity NR Selected for age 30–50 years and a parental history of type 2 diabetes | Four 45-minute and two 15-minute counseling phone calls, postal contact for 7 months | p=NS
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | | | Baseline | 12 months
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | Total leisure physical activity, minutes/week
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | IG | 83 | 165.5 | 78.5 (407.7)
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | CG | 82 | 121.0 | −3.8 (192.6)
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | Meeting physical activity recommendation, percent †
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | IG | 83 | 24 | 11*
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | CG | 82 | 21 | 2
Kolt, 2007^58^ New Zealand Good | N=186 44% men Mean age 74 Race/ethnicity NR Selected for age 65 years and older and sedentary behavior | 8 phone counseling sessions, mailed materials | * p<0.05
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | | | Baseline | 12 months | 24 months
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | | [underlined: N] | [underlined: Median] | [underlined: Median change (est SD)] | [underlined: Median change]
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | Physical activity, minutes/week
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | IG | 544 | 30 | 90.0 (297.1) | 75.0
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | CG | 545 | 30 | 45.0 (231.3) | 60.0
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change]
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | Meeting physical activity recommendation, percent †
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | IG | 544 | 10.3 | 32.5 (--) | 29.0*
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | CG | 545 | 11.4 | 18.9 (--) | 21.4
Lawton, 2008^59^ New Zealand Good | N=1089 0% men Mean age 59 Race/ethnicity NR Selected for age 40–74 years and sedentary behavior | 1 brief motivational interview including PA prescription and 30-minute followup visit with primary care nurse; five 15-minute calls, from community exercise specialist | * p<0.05 for change over time
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | | | Baseline | 12 months
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | Physical activity, minutes/week
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | IG | 80 | 19.8 | 80.8 (120.0)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | CG | 78 | 19.4 | 62.6 (123.3)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | VO _2_ max, mL/kg/minute
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | IG | 80 | 25.3 | 1.9 (9.7)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | CG | 78 | 25.6 | 0.7 (7.0)
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | Meeting physical activity recommendation, percent †
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | IG | 80 | 0 | 21
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | CG | 78 | 0 | 17
Marcus, 2007^60^ US Fair | N=159 18% men Mean age 44 14% nonwhite Selected for age 18–65 years and sedentary behavior | Mailed booklets, 14 counseling phone calls | p=NS
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | | | Baseline | 6 months
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | Total physical activity, kcal/week
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | IG | 495 | 4643 | −94 (3456)*
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | CG | 491 | 4781 | −673 (3255)
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | Meeting physical activity recommendation, percent †
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | IG | 495 | 21.4 | 12.1 (--)*
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | CG | 491 | 27.8 | 0.7 (--)
Martinson, 2008^62^ US Good | N=1049 28% men Mean age 57 6% nonwhite Selected for age 50–70 years and increasing levels of physical activity | 4 lectures, 1 group orientation, 23 phone calls, library or materials available for use, 3 motivational contests over 24 months, but not all completed at 6-month assessment | * p<0.004
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | | Baseline | | 12 months
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | Endurance physical activity, minutes/week
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | IG | 199 | 37.9 | 178 | 34.4 (134.7)*
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | CG | 199 | 35.8 | 177 | 7.9 (113.8)
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | 2-minute walk, meters
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | IG | 199 | 146.0 | 178 | 4.9 (50.2)
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | CG | 199 | 145.4 | 177 | 2.1 (41.4)
Morey, 2009^64^ US Good | N=398 100% men Mean age 78 23% nonwhite Selected for age 70 years or older and sedentary behavior | One visit and 13 phone calls with health counselor, workbook, exercise bands, in-person endorsement and individualized automated phone calls from PCP, quarterly tailored mailings | * p<0.005
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | | Baseline | | 6 months
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | Total physical activity, minutes/week
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | IG | 384 | 240.0 | 362 | 91.1 (451.3)
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | CG | 463 | 272.2 | 460 | 58.5 (431.6)
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | Meeting physical activity recommendation, percent †
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | IG | 384 | 46.1 | 362 | 19.4
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | CG | 463 | 49.8 | 460 | 10.6
Norris, 2000^68^ US Fair | N=847 48% men Mean age 55 9% nonwhite Selected for age 30 years or older | Counseling visit with PCP, phone call from research assistant; a subset received 3 additional phone calls | p=NS
Pinto, 2005^69^ US Fair | N=100 36% men Mean age 68 15% nonwhite Selected for age 60 years or older and sedentary behavior | Brief advice by clinician, 3 in-person and 12 phone counseling sessions with health educator; mailed materials | | | Baseline | 6 months
Pinto, 2005^69^ US Fair | N=100 36% men Mean age 68 15% nonwhite Selected for age 60 years or older and sedentary behavior | Brief advice by clinician, 3 in-person and 12 phone counseling sessions with health educator; mailed materials | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Pinto, 2005^69^ US Fair | N=100 36% men Mean age 68 15% nonwhite Selected for age 60 years or older and sedentary behavior | Brief advice by clinician, 3 in-person and 12 phone counseling sessions with health educator; mailed materials | Moderate-intensity physical activity, minutes/week
Pinto, 2005^69^ US Fair | N=100 36% men Mean age 68 15% nonwhite Selected for age 60 years or older and sedentary behavior | Brief advice by clinician, 3 in-person and 12 phone counseling sessions with health educator; mailed materials | IG | 49 | 38.1 | 62.8 (84.7)*
Pinto, 2005^69^ US Fair | N=100 36% men Mean age 68 15% nonwhite Selected for age 60 years or older and sedentary behavior | Brief advice by clinician, 3 in-person and 12 phone counseling sessions with health educator; mailed materials | CG | 44 | 45.3 | 16.6 (84.9)
Pinto, 2005^69^ US Fair | N=100 36% men Mean age 68 15% nonwhite Selected for age 60 years or older and sedentary behavior | Brief advice by clinician, 3 in-person and 12 phone counseling sessions with health educator; mailed materials | * p<0.05
Yates, 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions and a subset received a pedometer | | Baseline | | 12 months
Yates, 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions and a subset received a pedometer | | [underlined: N] | [underlined: Median] | [underlined: N] | [underlined: Mean change (SD)]
Yates, 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions and a subset received a pedometer | Total moderate- and vigorous-intensity physical activity, MET minutes/week
Yates, 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions and a subset received a pedometer | IG | 58 | 2920 | 50 | 1491 (3347)*
Yates, 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions and a subset received a pedometer | CG | 29 | 2335 | 26 | −1377 (3837)
Yates, 2009^72^ UK Fair | N=98 66% men Mean age 65 25% nonwhite Selected for BMI and IGT | 3-hour group session, two 10-minute followup sessions and a subset received a pedometer | * p<0.05
High-intensity interventions (estimated >360 minutes)
Stewart, 2001^71^ US Fair | N=173 34% men Mean age 74 Race/ethnicity NR Selected for sedentary behavior and Medicare enrollment | 11 group sessions, one individual session, booklets, phone calls from counselor, monthly newsletters | | | Baseline | 12 months
Stewart, 2001^71^ US Fair | N=173 34% men Mean age 74 Race/ethnicity NR Selected for sedentary behavior and Medicare enrollment | 11 group sessions, one individual session, booklets, phone calls from counselor, monthly newsletters | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Stewart, 2001^71^ US Fair | N=173 34% men Mean age 74 Race/ethnicity NR Selected for sedentary behavior and Medicare enrollment | 11 group sessions, one individual session, booklets, phone calls from counselor, monthly newsletters | Total physical activity, kcal/week
Stewart, 2001^71^ US Fair | N=173 34% men Mean age 74 Race/ethnicity NR Selected for sedentary behavior and Medicare enrollment | 11 group sessions, one individual session, booklets, phone calls from counselor, monthly newsletters | IG | 81 | 1935 | 687 (--)*
Stewart, 2001^71^ US Fair | N=173 34% men Mean age 74 Race/ethnicity NR Selected for sedentary behavior and Medicare enrollment | 11 group sessions, one individual session, booklets, phone calls from counselor, monthly newsletters | CG | 83 | 2057 | −9 (--)
Stewart, 2001^71^ US Fair | N=173 34% men Mean age 74 Race/ethnicity NR Selected for sedentary behavior and Medicare enrollment | 11 group sessions, one individual session, booklets, phone calls from counselor, monthly newsletters | * p<0.005

AHA – American Heart Association; BMI – body mass index; calc – calculated; CG – control group; CHAMPS – Community Healthy Activities Model Program for Seniors; est – estimated; IG – intervention group; IGT – impaired glucose tolerance; IQR – interquartile range; kcal – kilocalorie; kg – kilogram; L – liter; MET – metabolic equivalent; mL – milliliter; mmol – millimole; N – number randomized; NR – not reported; NS – not significant; PA – physical activity; PACE – Physician-Based Assessment and Counseling for Exercise; PASE – Physical Activity Scale for the Elderly; PCP – primary care practitioner; SD – standard deviation; UK – United Kingdom; US – United States

† Recommendation may be ACSM/CDC guideline, or study-specific recommendation

The majority of these trials selected participants who were below some defined threshold of physical activity, usually less than 90 to 150 minutes of medium-intensity physical activity per week. Some studies simply described participants as “sedentary” or “inactive.” Only seven trials included participants regardless of their baseline physical activity level.33,41,52,62,64,68,70 Three trials limited their samples to overweight or obese participants,50 participants with impaired glucose tolerance,72 or participants with elevated total cholesterol.47 Summarizing baseline activity levels over this body of literature as a whole is difficult due to differences in the measurement of physical activity. Only four trials36,59–61 reported baseline activity levels of 30 minutes per week or less, although not all trials reported baseline levels in minutes per week. Six trials32,33,53,55,58,68 reported 2 or more hours per week of physical activity (of any kind or limited to moderate-intensity activity or higher) at baseline. One of these was an outlier, reporting an average of over 2,700 minutes/week of physical activity at baseline, including 7 or more hours of moderate-intensity physical activity and 2 hours of walking each week.33 The remaining trials used various other measures of physical activity and were therefore difficult to compare in terms of baseline activity level.

The data for low-intensity interventions were mixed. Four of the 11 trials of low-intensity interventions increased some measure of physical activity.40,44,60,70 One of these40 was a good-quality trial with an effect that was not statistically significant in our meta-analysis, but the original publication reported statistically significant group differences after adjusting for 11 potential confounding variables. The remaining seven trials failed to find group differences in any of the physical activity behavioral outcomes.32,33,38,52,61,66,75 The meta-analysis of the low-intensity trials with self-reported physical activity (e.g., minutes per week) showed no overall effect (SMD, 0.08 [95% CI, −0.01 to 0.18]; I^2^=40.7%; k=8; N=6,288) (Figure 26). The only low-intensity study rated as good quality reported a statistically significant increase of 17.5 minutes/week in the intervention group compared with the control group. Low-intensity interventions generally improved participants’ chances of meeting recommended physical activity levels. The three studies reporting sufficient data to be include in the meta-analysis showed that those in the intervention groups were 25 percent more likely to meet physical activity recommendations at 6- to 12-month followup than those in the control groups (pooled risk ratio [RR], 1.25 [95% CI, 1.11 to 1.41]; I^2^=0.0%; n=4,289) (Figure 27). This represented an absolute risk difference of four percentage points, which translated to a number-needed-to-treat of 25 for one additional person to meet physical activity guidelines. Low-intensity interventions, as measured by VO_2_max, were unlikely to affect fitness. The pooled effect size for VO_2_max was 0.05 ml/kg/min (95% CI, −0.11 to 0.20; I^2^=26.1%; k=3; N=4,518) (Figure 28).

Figure 26 Meta-Analysis of Physical Activity Trials By Intensity of Counseling (KQ3): Self-Reported Physical Activity

Figure 26 displays a forest plot of physical activity trials reporting between-group differences in self-reported physical activity (for example, minutes per week). Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (8 trials) the combined standardized mean difference was 0.08 (95% CI, −0.01 to 0.18). In the moderate-intensity (31 to 360 minutes) subgroup (17 trials) the combined standardized mean difference was 0.19 (95% CI, 0.12 to 0.27). The overall standardized mean difference for all 25 physical activity trials was 0.16 (95% CI, 0.10 to 0.22), indicating that there was not a statistically significant effect on self-reported physical activity. There was moderate statistical heterogeneity, both within the low-intensity subgroup (chi-square=40.7%; p=0.107) and the moderate-intensity subgroup (chi-square=49.9%; p=0.010), and between the two subgroups (chi-square=54.7%; p=0.001).

Figure 27 Meta-Analysis of Physical Activity Trials By Intensity of Counseling (KQ3): Percent Meeting Physical Activity Recommendations

Figure 27 displays a forest plot of physical activity trials reporting between-group differences in the percentage of participants who met recommended physical activity levels. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (3 trials) the pooled risk ratio was 1.25 (95% CI, 1.11 to 1.41). In the moderate-intensity (31 to 360 minutes) subgroup (6 trials) the pooled risk ratio was 1.22 (95% CI, 1.07 to 1.40). The overall pooled risk ratio for all 9 physical activity trials was 1.23 (95% CI, 1.12 to 1.34), indicating that the interventions generally improved the participants’ chances of meeting recommended physical activity levels. There was moderate statistical heterogeneity within the moderate-intensity subgroup (chi-square=59.0%; p=0.032), but not between the low- and moderate-intensity subgroups (chi-square=37.9%; p=0.116).

Figure 28 Meta-Analysis of Physical Activity Trials By Intensity of Counseling (KQ3): Fitness Measures

Figure 28 displays a forest plot of physical activity trials reporting between-group differences in fitness measures (reported as VO2max or maximal oxygen uptake). Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (3 trials) the combined standardized mean difference was 0.05 (95% CI, −0.11 to 0.20). In the moderate-intensity (31 to 360 minutes) subgroup (3 trials) the combined standardized mean difference was 0.11 (95% CI, −0.04 to 0.25). The overall standardized mean difference for all 6 physical activity trials was 0.03 (95% CI, −0.02 to 0.08), indicating that the interventions were unlikely to affect fitness (as measured by VO2max). There was no statistical heterogeneity between the subgroups (chi-square=0.0%; p=0.501).

Only one of the low-intensity trials was rated as good quality. Most of the fair-quality trials failed to report whether allocation and/or assessment were blinded, and many had additional quality issues, such as randomization procedures that were not clearly random,32 fairly high attrition rates,33,61 potentially important baseline group differences,38,60 or no information on baseline comparability.66

Medium-intensity interventions increased the level of self-reported physical activity at 6 to 12 months (SMD, 0.19 [95% CI, 0.12 to 0.27]; I^2^=49.9%; k=17; N=6,808) (Figure 26). Among the nine studies reporting minutes per week of physical activity (as opposed to measures such as MET-min or scale scores), this change amounted to 38 additional minutes of physical activity per week for those in the intervention group (WMD, 38.3 minutes [95% CI, 25.9 to 50.7]; I^2^=0.0%; k=9; N=3,855). One of these trials examined whether ongoing support improved maintenance of recent physical activity changes. The authors found that participants in the medium-intensity intervention maintained their activity levels, while control-group participants did not.62 Changes were maintained at the 24-month followup.76

Participants in medium-intensity interventions also had a 22 percent greater chance of meeting physical activity guidelines after 6 to 12 months, compared with control participants (pooled RR, 1.22 [95% CI, 1.07 to 1.40]; I^2^=59.0%; k=6; N=4,183) (Figure 27). This difference translated to an absolute risk difference of seven percentage points and a number-needed-to-treat of 14 to 15 for one additional person to meet physical activity guidelines. Medium-intensity interventions, however, did not appear to increase fitness (SMD, 0.11 [95% CI, −0.04 to 0.25]; I^2^=0.0%; k=3; N=731) (Figure 28), although this outcome was only reported in three of the 17 trials.

Egger’s test of small study effects was statistically significant for the medium-intensity trials. The three trials with the largest effect sizes (all rated as fair quality)47,69,72 were also among the four trials with the fewest participants. We conducted a sensitivity analysis that excluded these three trials from the meta-analysis and the results still showed a statistically significant positive effect of physical activity counseling (SMD, 0.14 [95% CI, 0.9 to 0.20]; I^2^=16.9%; k=14). Only one of these three trials reported change in physical activity in minutes per week. Thus, the estimated 38-minute difference appears not to have been substantially biased by the inclusion of these small trials with relatively large effects.

The one physical activity trial using a high-intensity intervention71 reported an increase in physical activity. This 6-month intervention included monthly group meetings, staff-initiated phone calls, an initial individual session, booklets, and monthly newsletters. Participants in this intervention increased their physical activity by an average of 687 kilocalories per week, while those in the waitlist control group slightly reduced their activity level by 9 kilocalories per week.

### Healthful Diet

Overall, dietary counseling improved self-reported dietary intake of energy, fats, fruits and vegetables, and objectively measured urinary sodium. All 25 trials of healthful diet counseling interventions meeting our inclusion criteria reported behavioral health outcomes of dietary intake (Table 7). Three of these trials evaluated low-sodium dietary counseling,87,98,101 three trials evaluated fruits and vegetables dietary counseling,42,90,92 and 19 trials evaluated general heart-healthy dietary counseling, including low-fat dietary changes.34,47,53,77–83,86,91,93–97,104,108

Table 7 Randomized Controlled Trials for Healthful Diet Counseling Interventions: Behavioral Outcomes

Author, year Country Quality | Population details | Intervention details | Behavioral outcomes (self-reported unless otherwise noted)
Salt only dietary counseling
High-intensity interventions (estimated >360 minutes)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months, plus ongoing maintenance for trial duration | Sodium excretion (mmol/8 h)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months, plus ongoing maintenance for trial duration | | Baseline | | 6 months | | 36 months
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months, plus ongoing maintenance for trial duration | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months, plus ongoing maintenance for trial duration | IG1+2 | 391 | 42.45 | 391 | −10.4 (16.80) | 391 | −5.02 (NR)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months, plus ongoing maintenance for trial duration | CG | 196 | 43.4 | 185 | −3.9 (17.70) | 155 | 0.0 (NR)
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months, plus ongoing maintenance for trial duration | p IG2 v. IG1 | | | | 0.452 | | 0.332
HPT, 1990^87^ US Good | N=841 65% men Mean age 39 18% nonwhite Selected for DBP 78–89 | 12 group sessions in 4 months, plus ongoing maintenance for trial duration | p IG1 v. CG | | | | 0.002 | | 0.053
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 group/individual sessions in 3 months, plus ongoing maintenance for trial duration | Sodium excretion (mmol/24 h)
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 group/individual sessions in 3 months, plus ongoing maintenance for trial duration | | Baseline | | 12 months | | 18 months
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 group/individual sessions in 3 months, plus ongoing maintenance for trial duration | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 group/individual sessions in 3 months, plus ongoing maintenance for trial duration | IG | 314 | 154.6 | 244 | −54.4 (66.2)* | 242 | −55.2 (76.9)*
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 group/individual sessions in 3 months, plus ongoing maintenance for trial duration | CG | 401 | 156.4 | 342 | −4.3 (68.0) | 341 | −11.3 (77.7)
TOHP I, 1992^98^ US Fair | N=744 71% men Mean age 43 23% nonwhite Selected for DBP 80–89 | 10 group/individual sessions in 3 months, plus ongoing maintenance for trial duration | * p<0.01 for the mean difference between IG and CG
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | | Baseline | | 18 months | | 36 months
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | Sodium excretion (mmol/24 h)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | IG | 594 | 186.1 | 450 | −59.5 (91.7)* | 470 | −50.9 (86.3)*
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | CG | 596 | 188.0 | 467 | −16.8 (94.8) | 482 | −10.5 (88.5)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | Calories**
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | IG | NR | NR | NR | −284.3 (1002) | NR | −414.9 (907.1)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | CG | NR | NR | NR | −113.2 (938) | NR | −162.2 (946.1)
TOHP II, 1997^101^ US Good | N=1190 67% men Mean age 44 20% nonwhite Selected for DBP 83–89 | 10 group sessions in 3 months, plus ongoing maintenance for trial duration | * p<0.001 for the mean difference between IG and CG ** Conducted on a random subsample of participants
Fruits and vegetables only dietary counseling
Low-intensity interventions (estimated 0–30 minutes)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | Fruits and vegetables, portions/day
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | | Baseline | | 6 months
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | IG | 329 | 3.4 | 329 | 1.4 (1.7)*
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | CG | 326 | 3.4 | 326 | 0.1 (1.3)
John, 2002^90^ UK Fair | N=729 49% men Mean age 46 NR nonwhite Unselected | 25-minute session, plus followup phone call and mailed booklet over 3 months | * p<0.0001 for mean difference between IG and CG adjusted for baseline value, sex
Lutz, 1999^92^ US Fair | N=710 36% men Mean age 39 22% nonwhite Unselected | Four mailed booklets over 4 months IG1: nontailored IG2: tailored, no goal setting IG3: tailored + goal setting | Fruits and vegetables, servings/day
Lutz, 1999^92^ US Fair | N=710 36% men Mean age 39 22% nonwhite Unselected | Four mailed booklets over 4 months IG1: nontailored IG2: tailored, no goal setting IG3: tailored + goal setting | | Baseline | | 6 months
Lutz, 1999^92^ US Fair | N=710 36% men Mean age 39 22% nonwhite Unselected | Four mailed booklets over 4 months IG1: nontailored IG2: tailored, no goal setting IG3: tailored + goal setting | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Lutz, 1999^92^ US Fair | N=710 36% men Mean age 39 22% nonwhite Unselected | Four mailed booklets over 4 months IG1: nontailored IG2: tailored, no goal setting IG3: tailored + goal setting | IG2+3 | 282 | 3.40 | 282 | 0.86 (2.45)
Lutz, 1999^92^ US Fair | N=710 36% men Mean age 39 22% nonwhite Unselected | Four mailed booklets over 4 months IG1: nontailored IG2: tailored, no goal setting IG3: tailored + goal setting | CG | 151 | 3.5 | 151 | 0.10 (1.92)
Medium-intensity interventions (estimated 31–360 minutes)
Greene, 2008^42^ US Fair | N=1280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | 9 mailed newsletters, 3 tailored reports, and 3 phone calls over 12 months | Fruits and vegetables, servings/day
Greene, 2008^42^ US Fair | N=1280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | 9 mailed newsletters, 3 tailored reports, and 3 phone calls over 12 months | | Baseline | | 12 months | | 24 months
Greene, 2008^42^ US Fair | N=1280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | 9 mailed newsletters, 3 tailored reports, and 3 phone calls over 12 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
Greene, 2008^42^ US Fair | N=1280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | 9 mailed newsletters, 3 tailored reports, and 3 phone calls over 12 months | IG | 410 | 8.0 | 410 | 2.10 (4.15) | 410 | 2.20 (NR)
Greene, 2008^42^ US Fair | N=1280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | 9 mailed newsletters, 3 tailored reports, and 3 phone calls over 12 months | CG | 424 | 7.7 | 424 | 0.80 (3.03) | 424 | 1.60 (NR)
Greene, 2008^42^ US Fair | N=1280 27% men Mean age 75 20% nonwhite Selected for age 60 years or older | 9 mailed newsletters, 3 tailored reports, and 3 phone calls over 12 months | p<0.001
Fats only dietary counseling
High-intensity interventions (estimated >360 minutes)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | | [underlined: N] | [underlined: Mean change (SD) at 12 months]
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | Calories from total fats, percent
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 95 | −6.90 (7.80)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 91 | −0.40 (6.30)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | Calories from saturated fats, percent
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 95 | −2.92 (3.00)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 91 | 0.10 (2.60)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | Cholesterol intake, mg/day
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 95 | −85.09 (NR)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 91 | 3.91 (NR)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | Calories
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | IG | 95 | −253.70 (459.20)
Stefanick, 1998^96^ US Fair | N=377 51% men Mean age 52 NR nonwhite Selected for slightly elevated LDL | 9 group/individual sessions in 3 months, plus ongoing maintenance over 8 months | CG | 91 | −21.9 (426.40)
Multiple message or general cardiovascular dietary counseling
Low-intensity interventions (estimated 0–30 minutes)
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | | Baseline | | 12 months
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | | [underlined: N] | [underlined: Mean*] | [underlined: N] | [underlined: Mean change (SD)]
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | Calories from fat, percent
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | IG | 859 | 37.6 | 859 | −1.54 (5.16)
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | CG | 959 | 37.5 | 959 | −0.34 (5.13)
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | Intervention effect (95% CI): −1.20 (−1.68, −0.73)**
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | Fiber, g/1000 kcal
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | IG | 859 | 10 | 859 | 0.55 (0.27, 0.83)
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | CG | 959 | 10 | 959 | 0.22 (−0.03, 0.49)
Beresford, 1997^79^ US Fair | N=4778 32% men 26% age 65+ 9% nonwhite Uselected | 3-minute session with PCP with self-help booklet, plus followup mail reminder | Intervention effect (95% CI): 0.32 (−0.06, 0.70) *Adjusted for clinic and practice effects, age, and gender ** p<0.01
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | | Baseline | | 12 months
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | Dietary Fat Behavior score
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | IG | 280 | 2.03 | 238 | −0.16 (0.25)
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | CG | 342 | 2.05 | 278 | −0.10 (0.27)
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | ANCOVA p= 0.0027*
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | Dietary Fiber Behavior score
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | IG | 280 | 2.24 | 238 | −0.12 (0.26)
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | CG | 342 | 2.24 | 278 | −0.08 (0.30)
Fries, 2005^86^ US Fair | N=754 36% men Mean age 47 40% nonwhite Unselected | Mailed tailored report, plus phone call at 2 weeks and five booklets over 5 weeks | ANCOVA p=0.0862* *Adjusted for physician practice and baseline value
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | | Baseline | | 12 months
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | Fat-related score (1.0 low fat to 4.0 high fat)
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | IG | 601 | 2.29 | 604 | −0.09 (0.38)
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | CG | 604 | 2.30 | 604 | −0.00 (0.40)
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | Intervention effect: −0.10 (0.2)*
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | Fruits and vegetables, servings/day
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | IG | 604 | 3.62 | 604 | 0.47 (1.83)
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | CG | 604 | 3.47 | 604 | 0.14 (1.80)
Kristal, 2000^91^ US Fair | N=1459 51% men Mean age 45 14% nonwhite Unselected | Mailed materials, plus phone call at 1 month and semi-monthly newsletters over 12 months | Intervention effect: 0.46 (0.10)* Intervention effect adjusted for baseline value, age, sex, race, BMI, and income * p<0.0001
Prochaska, 2005^93^ US Fair | N=5407 30% men Mean age 45 3% nonwhite Selected for suboptimal dietary behavior | 3 mailed tailored reports over 12 months | | Baseline | | 12 months | | 24 months
Prochaska, 2005^93^ US Fair | N=5407 30% men Mean age 45 3% nonwhite Selected for suboptimal dietary behavior | 3 mailed tailored reports over 12 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
Prochaska, 2005^93^ US Fair | N=5407 30% men Mean age 45 3% nonwhite Selected for suboptimal dietary behavior | 3 mailed tailored reports over 12 months | Fruit and Vegetable Subscale of the Dietary Behavior Questionnaire
Prochaska, 2005^93^ US Fair | N=5407 30% men Mean age 45 3% nonwhite Selected for suboptimal dietary behavior | 3 mailed tailored reports over 12 months | IG | 1781 | 22.5 | 1781 | 1.00 (4.70) | 1781 | 1.00 (NR)
Prochaska, 2005^93^ US Fair | N=5407 30% men Mean age 45 3% nonwhite Selected for suboptimal dietary behavior | 3 mailed tailored reports over 12 months | CG | 1920 | 22.2 | 1920 | 0.20 (3.91) | 1920 | 0.20 (NR)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | | Baseline | | 12 months
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Calories from fat, percent
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | IG | 473 | 34.3 | 401 | −2.4 (6.90)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | CG | 483 | 34.2 | 352 | −0.9 (6.70)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Mean difference (95% CI): −1.4 (−2.2, −0.7)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Calories from saturated fat, percent
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | IG | 473 | 13.7 | 401 | −1.5 (3.94)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | CG | 483 | 14.0 | 352 | −0.6 (3.90)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Mean difference (95% CI): −0.09 (−1.15, −0.2)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Fiber, g/day
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | IG | 473 | 23.3 | 401 | 0.86 (8.76)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | CG | 483 | 23.2 | 352 | −0.19 (9.30)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Mean difference (95% CI): 1.02 (−0.20, 2.23)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Fruits, portions/week
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | IG | NR | NR | 401 | 0.76 (--)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | CG | NR | NR | 352 | 0.28 (--)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Mean difference (95% CI): 0.44(−0.24, 1.11)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Vegetables, portions/week
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | IG | NR | NR | 401 | 0.33 (--)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | CG | NR | NR | 352 | 0.33 (--)
Roderick, 1997^94^ UK Fair | N=956 50% men Mean age 47 NR nonwhite Unselected | Minimum one session with nurse, followup session in 1 month if needed | Mean difference (95% CI): 0.50 (−0.9, 1.9)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 45 NR nonwhite Unselected | 15-minute session with PCP with brochure | | Baseline | | 12 months
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 45 NR nonwhite Unselected | 15-minute session with PCP with brochure | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 45 NR nonwhite Unselected | 15-minute session with PCP with brochure | Fruits and vegetables, servings/week
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 45 NR nonwhite Unselected | 15-minute session with PCP with brochure | IG | 1592 | 19.1 | 1488 | 2.90 (7.24)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 45 NR nonwhite Unselected | 15-minute session with PCP with brochure | CG | 1587 | 19.3 | 1489 | 1.60 (6.58)
Sacerdote, 2005^95^ Italy Fair | N=3179 50% men Mean age 45 NR nonwhite Unselected | 15-minute session with PCP with brochure | Intervention effect: F=2.88, p=0.09 Intervention effect adjusted for sex, BMI, education, and time
Medium-intensity interventions (estimated 31–360 minutes)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | | Baseline | | 12 months
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean]
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | Dietary fiber, g/day
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | IG | 186 | 19.68 | 121 | 2.37 (NR)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | CG | 181 | 35.17 | 137 | −17.40 (NR)
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | | Baseline | | 12 months
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | | [underlined: N] | Percent | [underlined: N] | Percent
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | Using saturated fat for frying
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | IG | 187 | 23 | 160 | 8
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | CG | 181 | 21 | 164 | 20
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | Using saturated fat for spreading
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | IG | 187 | 36 | 166 | 4
Baron, 1990^78^ UK Fair | N=368 51% men Mean age 42 NR nonwhite Unselected | 3 individual/group visits over 3 months | CG | 181 | 30 | 168 | 30
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | | Baseline | | 6 months
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Adjusted mean change (SD)]
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | Fat, g/day
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | IG | 38 | 56 | 38 | 5 (18.00)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | CG | 32 | 61 | 32 | −0.8 (22.80)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | Fiber, g/day
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | IG | 38 | 17 | 38 | 4 (5.00)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | CG | 32 | 18 | 32 | 2 (4.00)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | Cholesterol, mg
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | IG | 38 | 203 | 38 | 17 (NR)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | CG | 32 | 200 | 32 | −2 (NR)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | Fruits and vegetables servings/day
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | IG | 38 | 5.1 | 38 | 2.2 (2.13)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | CG | 32 | 5.8 | 32 | 0.2 (1.81)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | Calories
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | IG | 38 | 1620 | 38 | 218 (400.10)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | CG | 32 | 1708 | 32 | 31 (446.90)
Bernstein, 2002^80^ US Fair | N=70 20% men Mean age 78 3% nonwhite Selected for age 70+ and sedentary behavior | 8 home visits over 6 months, plus bi-weekly phone calls and monthly newsletters | Adjusted for age, sex, and BMI
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | | Baseline | | 12 months
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | Calories from fat, percent
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 35.8 | 24 | −5.3 (6.40)*
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 34.7 | 19 | −0.5 (7.20)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | Calories from saturated fat, percent
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 15.0 | 24 | −4.7 (3.50)*
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 14.1 | 19 | −0.6 (3.70)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | Fiber, g/1000 kcal
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 9.3 | 24 | 3.5 (4.60)*
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 9.7 | 19 | −0.5 (2.60)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | Calories
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | IG | 24 | 2547 | 24 | −505 (632.40)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | CG | 19 | 2482 | 19 | −243 (620.60)
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relative with DM, otherwise unselected | 2 individual sessions plus followup phone calls for 8 months | * p<0.05
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | | Baseline | | 6 months
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | Fruits and vegetables, serving/day
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | IG | 148 | 1.1 | 148 | 0.6 (NR)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | CG | 150 | 1.2 | 150 | 0.2 (NR)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | Mean intake dietary fiber, g
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | IG | 148 | 6.2 | 148 | 1.10 (NR)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | CG | 150 | 6.0 | 150 | 0.20 (NR)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | Adjusted difference (95% CI): 1.0 (0.4, 1.6)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | Calories from saturated fat, percent
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | IG | 148 | 12.6 | 148 | −1.90 (NR)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | CG | 150 | 12.2 | 150 | −0.70 (NR)
Delichatsios, 2001^34^ US Fair | N=298 28% men Mean age 46 55% nonwhite Selected for suboptimal diet | ~24 phone calls over 6 months | Adjusted difference (95% CI): −1.0 (−1.9, −0.2)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | | Baseline | | 6 months
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | Calories from fat, percent
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 34 | 37 | 34 | −3.00 (4.30)*
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 33 | 36 | 33 | −3.00 (4.30)*
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | Calories
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 34 | 1950 | 34 | −87.20 (392.24)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 33 | 2244 | 33 | −152.4 (550.53)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | *p<0.05
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | | Baseline | | 12 months
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Adjusted mean change (SD)]
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | Calories from fat, percent
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | IG | 45 | 33.3 | 45 | −3.70 (8.41)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | CG | 40 | 31.6 | 40 | 0.20 (6.02)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | p<0.01
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | Calories from saturated fat, percent
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | IG | 45 | 10.9 | 45 | −1.40 (3.07)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | CG | 40 | 10.2 | 40 | 0.10 (2.25)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | p<0.01
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | Fruits and vegetables, servings/day
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | IG | 45 | 4.20 | 45 | 0.70 (1.66)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | CG | 40 | 4.70 | 40 | 0.10 (1.58)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | Calories
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | IG | 45 | 1700 | 45 | −267.80 (574.56)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | CG | 40 | 1757 | 40 | −57.5 (508.81)
King, 2002^53^ US Fair | N=100 0% men Mean age 63 14% nonwhite Selected for post-menopausal women and sedentary lifestyle | One individual session plus 14 phone calls and food logs mailed monthly over 12 months | Adjusted for baseline values
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | | Baseline | | 12 months
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | | [underlined: N] | [underlined: Mean] | [underlined: N] [underlined: *] | [underlined: Adjusted mean (SD)]
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | Calories from fat, percent
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | IG | 308 | 40.60 | 274 | −5.74 (7.59)**
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | CG | 308 | 39.41 | 262 | −0.80 (6.43)
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | Fruits and vegetables, servings/day
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | IG | 308 | 3.09 | 274 | 1.24 (1.74)**
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | CG | 308 | 3.21 | 262 | 0.19 (1.50)
Stevens, 2003^97^ US Fair | N=616 0% men Mean age 54 7% nonwhite Selected for age 40–70 and slightly elevated cholesterol | Two individual sessions over 1 month, plus 2 followup phone calls over 1 month | Adjusted for baseline values *Present at 12-month data collection (N analyzed at 12 months NR) ** p<0.001
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | One individual session, plus mailed tailored booklet at 1 month | Daily “overintake/underintake fraction” for total energy intake, percent
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | One individual session, plus mailed tailored booklet at 1 month | | Baseline | | 12 months
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | One individual session, plus mailed tailored booklet at 1 month | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Adjusted mean change (SD)]
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | One individual session, plus mailed tailored booklet at 1 month | IG | 78 | 21.6 | 78 | −1.8 (1.5)
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | One individual session, plus mailed tailored booklet at 1 month | CG | 77 | 19.9 | 77 | 4.0 (1.4)
Watanabe, 2003^108^ Japan Fair | N=173 100% men Mean age 55 NR nonwhite Selected for IFG | One individual session, plus mailed tailored booklet at 1 month | Adjusted mean difference (95% CI): −6.0 (−9.8, −2.2) p=0.002 for the adjusted difference between groups at 12 months Adjusted for baseline value
High-intensity interventions (estimated >360 minutes)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | | Baseline | | 12 months
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | Calories from fat, percent
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 33.99 | 95 | −5.30 (7.60)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 33 | 51 | −2.51 (7.90)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | Calories from saturated fat, percent
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 11 | 95 | −2.51 (3.15)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 11 | 51 | −1.00 (3.57)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | Dietary cholesterol, mg
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 254.07 | 95 | −67.99 (NR)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 267 | 51 | −48.00 (NR)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | Total fiber, g
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 18 | 95 | 4.31 (11.30)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 17 | 51 | 0.10 (10.00)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | Calories
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | IG1+2 | 95 | 2020 | 95 | −59.21 (503.60)
Anderson, 1992^77^ US Fair | N=177 60% men Mean age 41 0% nonwhite Selected for slightly elevated total cholesterol | 10 group sessions over 2.5 months plus 4 home visits over 12 months | CG | 51 | 2177 | 51 | −166.0 (620.60)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | | Baseline | | 6 months
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Adjusted mean change (SD)]
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | Fruits and vegetables score
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | IG1+2 | 60 | 5.9 | 60 | 0.89 (2.36)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | CG | 33 | 7.8 | 33 | −1.12 (2.42)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | Total fat score
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | IG1+2 | 60 | 6.41 | 60 | −1.96 (3.44)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | CG | 33 | 5.6 | 33 | −0.39 (3.53)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | Saturated fat score
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | IG1+2 | 60 | 7.30 | 60 | −1.24 (3.36)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | CG | 33 | 6.8 | 33 | −0.59 (3.44)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | Cholesterol score
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | IG1+2 | 60 | 7.51 | 60 | 0.58 (NR)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | CG | 33 | 8.2 | 33 | 0.88 (NR)
Carpenter, 2004^82^ US Fair | N= 98 36% men Mean age 50 13% nonwhite Unselected | IG1: 20 group sessions over 6 months IG2: 24 mailed curricula over 6 months, with reminders | Adjusted for baseline measurement, age, gender, education, and baseline caloric intake
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | | Baseline | | 6 months
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | Calories from fat, percent
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 39.7 | 1324 | −13.3 (7.78)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 39.1 | 883 | −2.3 (7.00)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | Calories from saturated fat, percent
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 13.26 | 1324 | −4.21 (3.11)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 12.97 | 883 | −0.71 (2.82)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | Cholesterol, mg/day
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 273.3 | 1324 | 107.0 (NR)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 260.2 | 883 | −28.6 (NR)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | Fruits and vegetables, servings/day
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 3.15 | 1324 | 0.66 (1.82)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 3.17 | 883 | 0.05 (1.46)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | Calories
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | IG | 1324 | 1834 | 1324 | −538 (927)
Coates, 1999^83^ US Fair | N=2207 0% men Mean age 60 45% nonwhite Selected for post menopausal women, and fat >30% energy intake | 20 group sessions over 18 months | CG | 883 | 1766 | 883 | −171 (747)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | | Baseline | | 12 months | | 72 months
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change (SD)]
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | Calories from fat, percent
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | IG | 18,306 | 37.7 | 17,117 | −13.50 (7.08) | 14,117 | −9.10 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | CG | 27,435 | 37.7 | 25,182 | −2.70 (6.17) | 21,759 | −0.80 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | Calories from saturated fat, percent
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | IG | 18,306 | 12.7 | 17,117 | −4.70 (2.91) | 14,117 | −3.20 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | CG | 27,435 | 12.7 | 25,182 | −1.00 (2.72) | 21,759 | −0.30 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | Vegetables or fruits, servings/day
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | IG | 18,306 | 3.6 | 17,117 | 1.50 (1.99) | 14,117 | 1.40 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | CG | 27,435 | 3.6 | 25,182 | 0.30 (1.48) | 21,759 | 0.20 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | Fiber, g/1000 kcal
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | IG | 18,306 | 8.8 | 17,117 | 3.5 (3.44) | 14,117 | 3.20 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | CG | 27,435 | 8.8 | 25,182 | 0.90 (2.82) | 21,759 | 0.80 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | Calories
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | IG | 18,306 | 1790 | 17,117 | −288.0 (641.71) | 14,117 | −355 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | CG | 27,435 | 1788 | 25,182 | −194.0 (601.14) | 21,759 | −240 (NR)
Tinker, 2008^104^ US Good | N=48,835 0% men Mean age 62 18% nonwhite Selected for postmenopausal women and dietary fat intake >30% | 18 group sessions and one individual session over 12 months, plus ongoing maintenance for trial duration | p<0.001

ID - identification; HPT - Hypertension Prevention Trial; US - United States; N - number; mmol - millimoles; h - hour; IG - intervention group; CG - control group; SE - standard error; SD - standard deviation; TOHP - Trial of Hypertension Prevention; UK - United Kingdom; NR - not reported (or only noncomparable behavioral outcomes reported); mo - month; CI - confidence interval; PCP - primary care physician; BMI - body mass index

Low-sodium only dietary counseling. Three fair-to-good-quality trials evaluated intensive low-sodium dietary counseling aimed at persons with mildly elevated diastolic blood pressure.87,98,101 All three trials were conducted in the United States among middle-aged persons. The populations for these trials were approximately two thirds men and one fifth nonwhite. Meta-analyses pooling objectively measured sodium intake at 6 to 18 months showed a statistically significant reduction in urinary sodium (SMD, −0.53 [95% CI, −0.73 to −0.32]; I^2^=79.9%; k=3; N=2,023) (Figure 29). Given the high statistical heterogeneity, the certainty of the pooled estimate for the reduction in urine sodium was not reliable. The reduction in urinary sodium in each of the three trials, however, was consistent with the main outcome the—reduction in blood pressure (refer to Key Question 2).

Figure 29 Meta-Analysis of Healthful Diet Trials, Salt Reduction Counseling (KQ3): Urinary Sodium

Figure 29 displays a forest plot of healthful diet trials reporting between-group differences in urinary sodium levels after low-sodium dietary counseling. Data for the figure are presented alongside the forest plot. The overall standardized mean difference for all 3 healthful diet trials was −0.53 (95% CI, −0.73 to −0.32), indicating that there was a statistically significant reduction in urinary sodium levels. However, the certainty of this pooled estimate is not reliable, given the high statistical heterogeneity (chi-square=79.9%; p=0.007).

Fruits and vegetables only dietary counseling. Three fair-quality trials evaluated behavioral counseling interventions designed to increase fruit and vegetable consumption.42,90,92 These counseling interventions generally included mailed health education, telephone followup, and less than 45 minutes of in-person or phone counseling. One trial targeted older adults with a mean age of 75 years.42 All the trials included a self-reported measure of fruit and vegetable intake per day. Meta-analyses pooling fruit and vegetable intake at 6 or 12 months showed a statistically significant increase in fruit and vegetable intake (SMD, 0.52 [95% CI, 0.18 to 0.86]; I^2^=92.3%; k=3; N=1,922) (Figure 30). Overall, the mean change in fruit and vegetable intake was approximately one serving per day.

Figure 30 Meta-Analysis of Healthful Diet Trials, Fruits and Vegetables Counseling (KQ3): Fruits and Vegetables

Figure 30 displays a forest plot of healthful diet trials reporting between-group differences in self-reported fruit and vegetable consumption after dietary counseling designed to increase fruit and vegetable intake. Data for the figure are presented alongside the forest plot. The overall standardized mean difference for all 3 healthful diet trials was 0.52 (95% CI, 0.18 to 0.86), indicating that there was a statistically significant increase in fruit and vegetable consumption. However, there was substantial statistical heterogeneity across the trials (chi-square=92.3%; p=0.000).

These three trials evaluating only fruits and vegetables dietary counseling were only fair quality and did not describe randomization or report if randomization allocation was concealed. One trial did not describe if significant baseline differences were present between groups and had low followup at 24 months.42 All three trials conducted true intention-to-treat analyses with either imputed values or last observation carried forward. Two trials only had 6-month followup data.90,92

Low-fat and general heart-healthy dietary counseling. All 19 trials evaluating low-fat and general heart-healthy dietary counseling reported some type of self-reported dietary intake outcome (Table 7).34,47,53,77–83,86,91,93–97,104,108 There was a large variation in type of dietary outcome reported, however, and it is not clear if the included dietary outcomes were the primary or secondary outcomes, or if these trials selectively reported outcomes. On occasion, trials were excluded from meta-analyses if they included noncomparable outcome measures or the data reported were not sufficient to enter into the meta-analyses. In addition, there was a large variation in intensity of counseling interventions, which ranged from brief counseling conducted in a single session to counseling conducted over multiple sessions (up to 18 sessions over 12 months). Interventions primarily targeted unselected middle-aged adults, except for four trials that targeted post-menopausal women or older adults,53,80,83,104 and six trials that targeted persons with slightly elevated cholesterol, glucose tolerance, or high dietary fat intake.34,47,77,83,97,108

High-intensity counseling interventions generally reduced caloric intake. Ten of the 19 trials reported some measure of overall energy intake.34,47,53,77,80,81,83,96,104,108 Only one of these trials was rated as good quality.104 Meta-analyses pooling all eight of the medium- and high-intensity trials with comparable outcome measures showed no group differences in energy intake at 6 to 12 months, with very high statistical heterogeneity (I^2^=91%) (Figure 31). There was a large variation, however, in setting, age, and level of intervention intensity across these trials. While the medium-intensity trials uniformly found no intervention effect, three of the four high-intensity interventions did show a statistically significant reduction in caloric intake. These results are consistent with small but statistically significant reductions seen in adiposity.

Figure 31 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ3): Energy

Figure 31 displays a forest plot of healthful diet trials reporting between-group differences in overall energy intake (reported as caloric intake) after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −30.92 (95% CI, −242.63 to 180.79). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined unstandardized weighted mean difference was −159.51 (95% CI, −335.02 to 15.99). The overall unstandardized weighted mean difference for all 8 healthful diet trials was −106.79 (95% CI, −236.00 to 22.41), indicating that there was not a statistically significant reduction in energy intake. There was substantial statistical heterogeneity between the two subgroups (chi-square=90.8%; p=0.000).

Sixteen of the 19 trials reported some measure of total fat or saturated fat intake.34,47,53,77–83,86,91,94,96,97,104 High-intensity trials were highly variable in effect size and had high statistical heterogeneity, but three of five trials showed statistically significant reductions in total and saturated fat (Figures 32 and 33). Meta-analyses showed statistically significant reductions in self-reported total fat intake in low- (total fat SMD, −0.25 [95% CI, −0.31 to −0.19]; I^2^=0.0%; k=5; N=4,357) and medium-intensity interventions (total fat SMD, −0.46 [95% CI, −0.81 to −0.011]; I^2^=73.3%; k=5; N=801) (Figure 32). Meta-analyses for self-reported saturated fat intake included only two trials per intervention intensity category. Total fat and saturated fat intake was reported as total intake per day, percent energy from fat or saturated fat, or commonly recognized fat or saturated fat score. Selected trials also reported measures of cholesterol,77,80,82,83,96 polyunsaturated fat,77,78,96,104 monounsaturated fat,77,81,96 and trans fat intake.104 While low-intensity interventions appeared to have a statistically significant reduction in self-reported fat intake, there was evidence for publication bias (Eggers p=0.003).

Figure 32 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ3): Fat

Figure 32 displays a forest plot of healthful diet trials reporting between-group differences in total fat intake (reported as total intake per day, percent energy from fat, or commonly recognized fat score) after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (5 trials) the combined standardized mean difference was −0.25 (95% CI, −0.31 to −0.19). In the moderate-intensity (31 to 360 minutes) subgroup (5 trials) the combined standardized mean difference was −0.46 (95% CI, −0.81 to −0.11). In the high-intensity (more than 360 minutes) subgroup (5 trials) the combined standardized mean difference was −1.05 (95% CI, −1.36 to −0.74). The overall standardized mean difference for all 15 healthful diet trials was −0.56 (95% CI, −0.97 to −0.14), indicating that there was a statistically significant reduction in total fat intake. However, there was substantial statistical heterogeneity in the moderate-intensity subgroup (chi-square=73.3%; p=0.005) and the high-intensity subgroup (chi-square=96.3%; p=0.000), as well across the 3 subgroups (chi-square=99.3%; p=0.000).

Figure 33 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ3): Saturated Fat

Figure 33 displays a forest plot of healthful diet trials reporting between-group differences in saturated fat intake (reported as total intake per day, percent energy from saturated fat, or commonly recognized saturated fat score) after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (2 trials) the combined standardized mean difference was −0.23 (95% CI, −0.36 to −0.09). In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined standardized mean difference was −0.80 (95% CI, −1.36 to −0.23). In the high-intensity (more than 360 minutes) subgroup (5 trials) the combined standardized mean difference was −1.09 (95% CI, −1.37 to −0.82). The overall standardized mean difference for all 9 healthful diet trials was −0.81 (95% CI, −1.15 to −0.47), indicating that there was a statistically significant reduction in saturated fat intake. However, there was substantial statistical heterogeneity in the high-intensity subgroup (chi-square=94.7%; p=0.000), as well across the 3 subgroups (chi-square=97.6%; p=0.000).

Eleven of the 19 trials reported fruit and vegetable intake, and found that overall the counseling interventions increased fruit and vegetable intake.34,53,80,82,83,91,93–95,97,104 Only one trial, the WHI, was rated as good quality.104 Meta-analyses of nine of the trials that reported total fruit and vegetable intake at 6 or 12 months had very high statistical heterogeneity (I^2^=98%; n=53,206) (Figure 34). Stratified meta-analyses by intervention intensity accounted for some of the heterogeneity. Low- (low-intensity SMD, 0.19 [95% CI, 0.14 to 0.23]; I^2^=0.0%; k=4; N=7,948) and medium-intensity (medium-intensity SMD, 0.65 [95% CI, 0.38 to 0.92]; I^2^=44%; k=3; N=691) interventions appeared to generate a statistically significant increase in self-reported fruit and vegetable intake. Overall, the mean change in fruit and vegetable intake ranged from 0.4 to 2 servings per day.

Figure 34 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ3): Fruits and Vegetables

Figure 34 displays a forest plot of healthful diet trials reporting between-group differences in self-reported fruit and vegetable consumption after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (4 trials) the combined standardized mean difference was 0.19 (95% CI, 0.14 to 0.23). In the moderate-intensity (31 to 360 minutes) subgroup (3 trials) the combined standardized mean difference was 0.65 (95% CI, 0.38 to 0.92). In the high-intensity (more than 360 minutes) subgroup (3 trials) the combined standardized mean difference was 0.68 (95% CI, 0.37 to 0.99). The overall standardized mean difference for all 10 healthful diet trials was 0.49 (95% CI, 0.27 to 0.70), indicating that there was a statistically significant increase in fruit and vegetable intake. However, there was substantial statistical heterogeneity in the high-intensity subgroup (chi-square=96.8%; p=0.000) and across all trials (chi-square=98.1%; p=0.000).

Nine of the 19 trials reported fiber intake.34,77–81,86,94,104 Only one trial, the WHI, was rated as good quality.104 Meta-analyses showed a very high statistical heterogeneity (I^2^=99%; n=44,892) (Figure 35). None of the low-intensity interventions showed group differences, while four of six medium- or high-intensity trials did improve fiber intake.

Figure 35 Meta-Analysis of Healthful Diet Trials, General Counseling (KQ3): Fiber

Figure 35 displays a forest plot of healthful diet trials reporting between-group differences in fiber intake after low-fat and general heart-healthy dietary counseling. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (3 trials) the combined standardized mean difference was 0.03 (95% CI, −0.10 to 0.15). In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined standardized mean difference was 0.70 (95% CI, 0.11 to 1.28). In the high-intensity (more than 360 minutes) subgroup (2 trials) the combined standardized mean difference was 0.65 (95% CI, 0.21 to 1.09). The overall standardized mean difference for all 7 healthful diet trials was 0.37 (95% CI, −0.05 to 0.79), indicating that there was a statistically significant increase in fiber intake. However, there was substantial statistical heterogeneity across all trials (chi-square=98.7%; p=0.000).

The majority of trials were only of fair quality, and there was significant clinical and statistical heterogeneity amongst the trials. Some of this heterogeneity could be attributed to different levels of intensity of counseling. However, because intervention intensity generally corresponded with population risk for CVD or how the population was selected (e.g., low-intensity interventions were generally conducted in unselected persons), it is unclear if the heterogeneity stemmed from intensity or population risk. However, very high statistical heterogeneity was apparent even within intensity categories for self-reported behavioral outcomes. The best evidence for high-intensity counseling on self-reported dietary intake comes from two trials conducted in exclusively post-menopausal women.83,104 Longer-term evidence for sustained change in dietary behavior was limited to one trial, in which changes in self-reported energy intake, total and saturated fat intake, fruit and vegetable intake, and fiber intake were statistically significant up to 72 months followup.104 We found evidence for statistically significant publication bias based on the Egger’s test for the self-reported total fat intake, but not for the other self-reported measures, including saturated fat intake.

### Combined Lifestyle

Overall, combined lifestyle counseling did improve self-reported dietary and physical activity behavior. However, in general, pooled results for dietary outcomes had very high statistical heterogeneity. All 17 trials evaluating combined lifestyle counseling interventions that met our inclusion criteria reported behavioral health outcomes of dietary intake or physical activity outcomes (Table 8). Only three trials were good quality.122,124,131 Nine were conducted in the United States,110,114–116,120–122,124,127 seven were conducted in general-risk populations,110,116,119,120,124,127,130 and seven were conducted in populations with patient populations selected from primary care.47,112,114,115,117,121,122 Ten of the trials selected patients based on elevated CVD risk.47,81,112,114,115,117,121–123,131 While most trials were conducted in middle-aged adults, one trial conducted in Japan used a population with a mean age of 64 years,112 and two trials had a mean age of 20 years.116,119 There was a very wide range in intervention intensity, and only one trial was a low-intensity counseling intervention that included monthly mailed newsletters over the 36-month trial.120 The other trials evaluated counseling interventions with greater than 30 minutes of contact, ranging from two to 30 sessions. Individual trial details are summarized in Table 8.

Table 8 Randomized Controlled Trials for Combined Lifestyle Counseling Interventions: Behavioral Outcomes

Author, year Country Quality | Population details | Intervention details | Behavioral outcomes (self-reported unless otherwise noted)
Author, year Country Quality | Population details | Intervention details | Dietary | | | | | | Physical activity
Low-intensity interventions (estimated 0–30 minutes)
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | | | Baseline | 12 months | 36 months | | | | Baseline | 12 months | 36 months
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change (SE)] | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change (SE)]
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | Energy intake, kcal/day | | | | | | Exercise, metabolic equivalent units
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | IG | 395 | 1717 | −143 (1068) | −198 (1095) | | IG | 395 | 45.5 | 0.55 (30.9) | −0.70 (29.5)
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | CG | 414 | 1702 | −122 (1058) | −130 (1099) | | CG | 414 | 46.6 | −1.2 (31.5) | −4.5 (30.5)
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | Fat intake, % of energy | | | | | | p=NS
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | IG | 395 | 34.0 | −1.75 (7.0) | −1.35 (8.4) | | p=NS
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | CG | 414 | 34.0 | −0.6 (8.1) | −1.1 (8.1) | | p=NS
Jeffery, 1999^120^ US Fair | N=809 20% men Mean age 38 10% nonwhite Unselected | 36 monthly newsletters plus additional activities offered every 6 months over 36 months | p=NS | | | | | | p=NS
Medium intensity interventions (estimated 31–360 minutes)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | | | Baseline | 12 months | | | | | Baseline | 12 months
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | | [underlined: N] | [underlined: Number (%)] | [underlined: Number (%)] | | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | ≥2 meals/day with vegetable servings | | | | | | Number of steps
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 34 (73.9) | 40 (87.0) | | | IG | 46 | 7345 | 3028 (5355)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 29 (70.7) | 30 (73.2) | | | CG | 41 | 7196 | −381 (4355)
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | | | p<0.001
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | Energy intake, kcal | | | | | | p<0.001
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | IG | 46 | 1931 | −63 (497) | | | p<0.001
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | CG | 41 | 1859 | −44 (407) | | | p<0.001
Babazono, 2007^112^ Japan Fair | N=99 42% men Mean age 64 NR nonwhite Selected for SBP 130−159, DBP 85–99, or A1c 5.6+ | 2 home visits, plus reinforcement at 2 data collection visits over 6 months | p=NS | | | | | | p<0.001
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | | | Baseline | 12 months | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Total energy intake, kcal | | | | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG | 25 | 2341 | −323 (522) | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 2482 | −243 (608) | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Fat, % intake | | | | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG | 25 | 34.9 | −5.1 (6.4)* | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 34.7 | −0.5 (7.2) | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Saturated fatty acids, % intake | | | | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG | 25 | 13.8 | −3.9 (4.0)* | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 14.1 | −0.6 (3.7) | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Monounsaturated fatty acids, % intake | | | | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG | 25 | 13.3 | −1.6 (2.3)* | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 12.6 | 0.4 (3.1) | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | Fiber, g/1000 kcal | | | | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | IG | 25 | 8.6 | 2.5 (3.8)* | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | CG | 19 | 9.7 | −0.5 (2.6) | | | NR
Brekke, 2005^81^ Sweden Fair | N=77 63% men Mean age 43 NR nonwhite Relatives with DM, otherwise unselected | 2 individual sessions, plus followup phone calls over 8 months | * p<0.05 | | | | | | NR
Eakin 2007^114^ US Fair | N=200 22% men Mean age 50 85% nonwhite Selected for one or more chronic conditions (including BMI or non-CV conditions) | 2 individual sessions, plus 3 followup phone calls over 3 months | | | Baseline | 6 months | | | | | Baseline | 6 months
Eakin 2007^114^ US Fair | N=200 22% men Mean age 50 85% nonwhite Selected for one or more chronic conditions (including BMI or non-CV conditions) | 2 individual sessions, plus 3 followup phone calls over 3 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | | | | [underlined: N] | [underlined: Median] | [underlined: Mean change (SD)]
Eakin 2007^114^ US Fair | N=200 22% men Mean age 50 85% nonwhite Selected for one or more chronic conditions (including BMI or non-CV conditions) | 2 individual sessions, plus 3 followup phone calls over 3 months | Dietary behavior† | | | | | | Total walking, minutes/week
Eakin 2007^114^ US Fair | N=200 22% men Mean age 50 85% nonwhite Selected for one or more chronic conditions (including BMI or non-CV conditions) | 2 individual sessions, plus 3 followup phone calls over 3 months | IG | 84 | 2.47 | −0.23 (--)* | | | IG | 101 | 60 | 16 (183)
Eakin 2007^114^ US Fair | N=200 22% men Mean age 50 85% nonwhite Selected for one or more chronic conditions (including BMI or non-CV conditions) | 2 individual sessions, plus 3 followup phone calls over 3 months | CG | 78 | 2.48 | −0.05 (--) | | | CG | 99 | 70 | −11 (203)
Eakin 2007^114^ US Fair | N=200 22% men Mean age 50 85% nonwhite Selected for one or more chronic conditions (including BMI or non-CV conditions) | 2 individual sessions, plus 3 followup phone calls over 3 months | † Lower scores indicate better dietary behavior change, range 1–4
Eakin 2007^114^ US Fair | N=200 22% men Mean age 50 85% nonwhite Selected for one or more chronic conditions (including BMI or non-CV conditions) | 2 individual sessions, plus 3 followup phone calls over 3 months | *p<0.05
Franko, 2008^116^ US Fair | N=476 43% men Mean age 20 41% nonwhite Unselected | IG1: 2 Web sessions (45 minutes each) over 2 weeks IG2: 3 Web sessions (45 minutes each) over 5 weeks | | Baseline | | 6 months | | | | Baseline | | 6 months
Franko, 2008^116^ US Fair | N=476 43% men Mean age 20 41% nonwhite Unselected | IG1: 2 Web sessions (45 minutes each) over 2 weeks IG2: 3 Web sessions (45 minutes each) over 5 weeks | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change] | | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change]
Franko, 2008^116^ US Fair | N=476 43% men Mean age 20 41% nonwhite Unselected | IG1: 2 Web sessions (45 minutes each) over 2 weeks IG2: 3 Web sessions (45 minutes each) over 5 weeks | Fruit and vegetables, servings/day | | | | | | Total MET minutes/week
Franko, 2008^116^ US Fair | N=476 43% men Mean age 20 41% nonwhite Unselected | IG1: 2 Web sessions (45 minutes each) over 2 weeks IG2: 3 Web sessions (45 minutes each) over 5 weeks | IG | 329 | 5.3 | 287 | −0.25 | | IG | 329 | 1798 | 287 | 123.4
Franko, 2008^116^ US Fair | N=476 43% men Mean age 20 41% nonwhite Unselected | IG1: 2 Web sessions (45 minutes each) over 2 weeks IG2: 3 Web sessions (45 minutes each) over 5 weeks | CG | 147 | 5.1 | 135 | −0.18 | | CG | 147 | 1820 | 135 | −68.0
Franko, 2008^116^ US Fair | N=476 43% men Mean age 20 41% nonwhite Unselected | IG1: 2 Web sessions (45 minutes each) over 2 weeks IG2: 3 Web sessions (45 minutes each) over 5 weeks | Energy from fat, percent
Franko, 2008^116^ US Fair | N=476 43% men Mean age 20 41% nonwhite Unselected | IG1: 2 Web sessions (45 minutes each) over 2 weeks IG2: 3 Web sessions (45 minutes each) over 5 weeks | IG | 329 | 31.1 | 287 | −0.02
Franko, 2008^116^ US Fair | N=476 43% men Mean age 20 41% nonwhite Unselected | IG1: 2 Web sessions (45 minutes each) over 2 weeks IG2: 3 Web sessions (45 minutes each) over 5 weeks | CG | 147 | 31.9 | 135 | −0.46
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | | | Baseline | 6 months | | | | | Baseline | 6 months
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | Fat intake, % fat intake per day | | | | | | Total physical activity, MET-min/week
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 23.85 | −0.92 (6.13)** | | | IG | 203 | 2039 | 245 (1482)*
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 23.72 | −2.92 (6.87) | | | CG | 131 | 2320 | −122 (1808)
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | Fruit and vegetable intake, portions per day | | | | | | * p<0.05 for t-value between IG and CG
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | IG | 203 | 6.41 | 1.05 (4.27) | | | ** p<0.01 for t-value between IG and CG
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | CG | 131 | 6.88 | 0.73 (5.04) | | | ** p<0.01 for t-value between IG and CG
Hardcastle, 2008^117^ UK Fair | N=334 NR % men Mean age 50 NR nonwhite Selected for 1 or more CV risk factors (including BMI) | Up to 5 individual sessions (30 minutes each) over 6 months (average 2 sessions) | ** p<0.01 for t-value between IG and CG | | | | | | ** p<0.01 for t-value between IG and CG
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | | | Baseline | 6 months | | | | | Baseline | 6 months
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | Total energy intake, kcal | | | | | | Number of exercise sessions/month
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 2064 | −222 (452)* | | | IG | 39 | 5.1 | 4.8 (9.5)*
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 2245 | −153 (551) | | | CG | 39 | 5.3 | 0.1 (8.9)
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | Fat, % intake | | | | | | *p<0.01
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | IG | 39 | 36 | −3 (5.6)* | | | *p<0.01
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | CG | 39 | 36 | 0 (5.9) | | | *p<0.01
Hellenius, 1993^47^ Sweden Fair | N=158 100% men Mean age 45 NR nonwhite Selected for slightly elevated total cholesterol | One session with PCP and one session with dietitian over 2 weeks | *p<0.05 | | | | | | *p<0.01
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | | Baseline | | 12 months | | | | Baseline | | 12 months
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)] | | | [underlined: N] | [underlined: Mean] | [underlined: N] | [underlined: Mean change (SD)]
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | Dietary risk assessment, total score | | | | | | Physical activity assessment (self-reported), all activity
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | IG | 102 | 34.2 | 85 | 5.0 (--)* | | IG | 107 | 29.4 | 86 | 0.4 (9.3)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | CG | 108 | 34.2 | 89 | −1.4 (--) | | CG | 111 | 29.2 | 90 | −0.6 (8.3)
Keyserling, 2008^121^ US Fair | N=236 0% men Mean age 53 42% nonwhite Selected for at or below 200% FPL | 2 individual counseling and 3 group sessions, plus 10 followup phone calls over 10 months | | | | | | | *p<0.05
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | | | Baseline | 12 months | | | | Baseline | | 12 months
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | Total fat, % total intake | | | | | | Activity, days/week
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 37.7 | −0.90 (7.7) | | | IG | 232 | 1.9 | 0.6 (2.9)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 37.8 | −1.3 (7.0) | | | CG | 232 | 1.6 | 0.4 (2.4)
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | Fruit/vegetables, servings/day | | | | | | p=NS
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | IG | 232 | 4.8 | −0.1 (2.2) | | | p=NS
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | CG | 232 | 4.9 | 0.0 (2.1) | | | p=NS
Mosca, 2008^122^ US Good | N=501 34% men Mean age 48 36% nonwhite Family with acute CV event, otherwise unselected | 5 in-person or phone sessions over 10 months | p= NS | | | | | | p=NS
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | | | Baseline | 6 months | | | | | Baseline | 6 months
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | Total fat intake, g/day | | | | | | Total physical activity, minutes/week
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | IG | 370 | 114 | −14.7 (39.7) | | | IG | 369 | 523 | 193 (643)
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | CG | 195 | 101 | −7.0 (36.4) | | | CG | 204 | 720 | 14 (613)
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | Energy from fat, % | | | | | | p=NS
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | IG | 370 | 34.8 | −1.3 (--) | | | p=NS
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | CG | 195 | 35.3 | −2.1 (--) | | | p=NS
Vandelanotte, 2005^130^ Belgium Fair | N=1023 36% men Mean age 39 NR nonwhite Unselected | 1 computer session (50 minutes) IG1: HD and PA counseling at one time IG2: PA then HD counseling IG3: HD then PA counseling | p<0.001 for time × group for both | | | | | | p=NS
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | | | Baseline | 12 months | | | | | Baseline | 12 months
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (95% CI)] | | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (95% CI)]
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | Nutrition level (ordinal measure treated continuously) | | | | | | Physical activity (ordinal measure treated continuously)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | IG | 157 | -- | 0.30 (0.13, 0.47) | | | IG | 157 | -- | 0.17 (−0.06, 0.40)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | CG | 158 | -- | −0.05 (−0.22, 0.12)* | | | CG | 158 | -- | 0.16 (−0.08, 0.40)
Wister, 2007^131^ Canada Good | N=611 42% men Mean age 55 NR nonwhite Selected for Framingham risk score of 10%+ over 10 years | 2 individual sessions (30 minutes each) over 1 year plus “annual report card” | * p<0.01
High-intensity interventions (estimated >360 minutes)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | | | Baseline | 6 months | | | | | Baseline | 6 months
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | | [underlined: N] | [underlined: Mean] | [underlined: Mean Change (SD)] | | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)]
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | Kcal intake/day | | | | | | Total steps/day
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | IG | 174 | 2092 | −558 (779)* | | | IG | 174 | 5797 | 1767 (2559)*
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | CG | 174 | 1919 | −63 (497) | | | CG | 174 | 6267 | 809 (2589)
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | Fat, % intake | | | | | | *p<0.0002
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | IG | 174 | 36.7 | −8.2 (7.7)* | | | *p<0.0002
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | CG | 174 | 34.6 | 1.0 (6.9) | | | *p<0.0002
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | Fruit and vegetable, servings/day | | | | | | *p<0.0002
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | IG | 174 | 4.6 | 2.3 (3.3)* | | | *p<0.0002
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | CG | 174 | 5.0 | 0.1 (3.2) | | | *p<0.0002
Aldana, 2006^110^ US Fair | N=348 28% men Mean age 50 6% nonwhite Unselected | Four group sessions (120 minutes each) over 4 weeks | *p<0.01 | | | | | | *p<0.0002
Edelman 2005^115^ US Fair | N=294 20% men Mean age 53 23% nonwhite Selected for 1 or more CV risk factors (including BMI) | 2 individual sessions and 28 group sessions, plus 20 followup phone calls over 10 months | NR | | | | | | Data primarily reported in a figure. Days of exercise were significantly increased in IG compared with CG (3.7 v. 2.4 days, p=0.002).
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | | | Baseline | 12 months | 24 months | | | | Baseline | 12 months | 24 months
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change (SD)] | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change (SE)]
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | Total caloric intake, kcal/day | | | | | | Physical activity, kcal/kg/year
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 2051 | −194 (503) | −224 (556) | | IG | 58 | 1216 | −81 (701) | −89(967)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 2016 | −112 (506) | −229 (604) | | CG | 57 | 1378 | −260 (838) | −292 (830)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | % of lipids | | | | | | VO _2_ max
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | IG | 58 | 29.5 | −0.9 (7.6) | 0.6 (9.1) | | IG | 58 | 39.0 | −0.31 (2.6) | 0.28 (2.6)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | CG | 57 | 30.1 | −1.4 (7.6) | 0.0 (7.6) | | CG | 57 | 38.8 | −0.96 (3.5) | 0.31 (3.2)
Hivert, 2007^119^ Canada Fair | N=115 18% men Mean age 20 7% nonwhite Unselected | 23 group sessions over 2 years | p=NS | | | | | | p=NS
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | | | Baseline | 12 months | 24 months | | | | Baseline | 12 months | 24 months
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change (SD)] | | | [underlined: N] | [underlined: Percent] | [underlined: Percent (SD)] | [underlined: Percent (SD)]
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | Energy, kcal/day | | | | | | Regular activity at least once per week
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 33 | 1988 | −199 (580) | -- | | IG | 30 | 25.0 | -- | 57.1 (16)*
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 32 | 2137 | 7 (582) | -- | | CG | 24 | 50.0 | -- | 45.8 (11)
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | Total fat, g/day | | | | | | * p<0.05
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | IG | 33 | 85.4 | −16.7 (26.5)* | −24.4 (24.5)* | | * p<0.05
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | CG | 32 | 84.7 | −0.43 (33.5) | −6.5 (30.9) | | * p<0.05
Oldroyd, 2001^123^ UK Fair | N=78 57% men Mean age 58 NR nonwhite Selected for IFG | 18 individual sessions (20 minutes each) over 24 months | * p<0.05 | | | | | | * p<0.05
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | | | Baseline | 18 months | 54 months | | | | Baseline | 18 months | 54 months
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change] | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: N] | [underlined: Mean change]
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | Total energy intake, kcal | | | | | | Total physical activity, kcal
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | IG | 236 | 1492 | −189 (514)* | 246 | −160* | IG | 236 | 1217 | 432(1647)* | 246 | 275*
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | CG | 253 | 1427 | −79 (456) | 263 | −25 | CG | 253 | 1389 | 43 (1677) | 263 | −113
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | Fat, % | | | | | | * p<0.05
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | IG | 236 | 32.5 | −9.2 (7.2)* | -- | -- | * p<0.05
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | CG | 253 | 32.4 | −1.8 (7.6) | -- | -- | * p<0.05
Simkin-Silverman, 1998^124^ US Good | N=535 0% men Mean age 47 8% nonwhite Selected for women age 44–50 | 15 group sessions over 5 months, plus group, mail or phone followup after initial 5 months | * p<0.05 | | | | | | * p<0.05
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | | | Baseline | 12 months | 18 months | | | | Baseline | 12 months | 18 months
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change] | | | [underlined: N] | [underlined: Mean] | [underlined: Mean change (SD)] | [underlined: Mean change]
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | Total energy intake, kcal/day | | | | | | Total leisure-time activity, minutes/week
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 96 | 2201.3 | −355.1 (871.1) | −318.0* | | IG | 100 | 303.6 | 1.2 (397) | −7.2
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 95 | 2191.8 | −215.6 (827.5) | −497.0 | | CG | 100 | 366.0 | −48.6 (421) | −52.8
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | Total fat intake, g/day | | | | | | Peak VO _2_ , L/minute
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 96 | 94.9 | −14.7 (44.4) | −13.9* | | IG | 98 | 2.08 | −0.02 (--) | −0.03
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 95 | 96.6 | −8.8 (47.1) | −10.3 | | CG | 99 | 1.20 | 0.78 (--) | 0.74
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | Fruit and vegetable intake, servings/day | | | | | | p=NS
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | IG | 96 | 3.93 | 0.11 (2.09) | 0.55 | | p=NS
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | CG | 95 | 3.85 | −0.09 (1.73) | 0.1 | | p=NS
Thompson, 2008^127^ US Fair | N=200 0% men Mean age 29 100% nonwhite Selected for American Indian women | 5 group sessions (150 minutes each) over 5 months | * RM ANOVA effect of visit p<0.001 | | | | | | p=NS

BMI – body mass index; CV – cardiovascular; DBP – diastolic blood pressure; DM – diabetes mellitus; FPL – federal poverty level; A1c – hemoglobin A1c; HD – healthful diet; IFG – impaired fasting glucose; NR – not reported; NS – not significant; PA – physical activity; PCP – primary care physician; SBP – systolic blood pressure; SD – standard deviation; US – United States; UK – United Kingdom

Dietary intake behavior change. Sixteen of the 17 trials of combined lifestyle counseling provided some type of self-reported dietary behavioral outcome. Nine of the 16 trials reported some measure of overall energy intake.47,81,110,112,119,120,123,124,127 Meta-analyses showed a statistically significant decrease in energy intake (WMD, −131 kcal/day [95% CI, −224 to −37]; I^2^=58.6 %; n=2,226) (Figure 36). However, stratified analyses showed a statistically significant effect only in high-intensity trials (WMD, −192 kcal/day [95% CI, −332 to −52]; k=5; N=1,208) (Figure 36), although statistical heterogeneity was quite high (I^2^=70.8%). We found a large variation in setting, age, and level of intervention intensity across these trials. None of the counseling interventions focused on calorie restriction or weight loss, and therefore were not primarily intended to reduce overall energy intake. This change in caloric intake is consistent with the change in adiposity described in Key Question 2.

Figure 36 Meta-Analysis of Combined Lifestyle Trials (KQ3): Energy

Figure 36 displays a forest plot of combined lifestyle trials reporting between-group differences in overall energy intake (reported as caloric intake). Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (1 trial) the unstandardized weighted mean difference was −20.86 (95% CI, −167.43 to 125.71). In the moderate-intensity (31 to 360 minutes) subgroup (3 trials) the combined unstandardized weighted mean difference was −46.07 (95% CI, −179.45 to 87.31). In the high-intensity (more than 360 minutes) subgroup (5 trials) the combined unstandardized weighted mean difference was −191.86 (95% CI, −331.62 to −52.11). The overall unstandardized weighted mean difference for all 9 combined lifestyle trials was −130.55 (95% CI, −224.30 to −36.81), indicating that there was a statistically significant decrease in energy intake. However, there was substantial statistical heterogeneity in the high-intensity subgroup (chi-square=70.8%; p=0.008).

Twelve trials reported some measure of dietary intake of fat, showing highly variable results.47,81,110,116,117,119,120,122–124,127,130 Seven of the trials showed statistically significant results, including low-, medium-, and high-intensity interventions. Meta-analyses pooling the 11 trials that reported total fat intake at 6 or 12 months had very high statistical heterogeneity (I^2^=94%; n=3,502) (Figure 37). Stratified meta-analyses by intervention intensity and population risk did not reduce the amount of statistical heterogeneity among subgroups.

Figure 37 Meta-Analysis of Combined Lifestyle Trials (KQ3): Dietary Fat

Figure 37 displays a forest plot of combined lifestyle trials reporting between-group differences in dietary fat intake. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (1 trial) the standardized mean difference was −0.15 (95% CI, −0.29 to −0.01). In the moderate-intensity (31 to 360 minutes) subgroup (5 trials) the combined standardized mean difference was −0.24 (95% CI, −0.65 to 0.16). In the high-intensity (more than 360 minutes) subgroup (5 trials) the combined standardized mean difference was −0.61 (95% CI, −1.11 to −0.11). The overall standardized mean difference for all 11 combined lifestyle trials was −0.41 (95% CI, −0.72 to −0.10), indicating that there was a statistically significant decrease in fat intake. However, there was substantial statistical heterogeneity across the trials (chi-square=94.5%; p=0.000).

Only six of the 16 trials reported fruit and vegetable intake, only one of which showed statistically significant group differences.111,112,116,117,122,127 Meta-analyses pooling the four trials that reported usable total fruit and vegetable intake at 6 or 12 months had very high statistical heterogeneity (I^2^=89%; n=1,337) (Figure 38). One fair-quality trial (n=348) showed a statistically significant increase in fruit and vegetable intake at 6 months, a mean difference of 0.9 servings of fruit/day (95% CI, 0.6 to 1.1) and 1.3 servings of vegetable/day (95% CI, 0.9 to 1.9) between groups among unselected middle-aged adults.111 None of the other trials demonstrated a statistically significant increase in fruit and vegetable intake.

Figure 38 Meta-Analysis of Combined Lifestyle Trials (KQ3): Fruits and Vegetables

Figure 38 displays a forest plot of combined lifestyle trials reporting between-group differences in fruit and vegetable consumption. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined standardized mean difference was 0.00 (95% CI, −0.14 to 0.14). In the high-intensity (more than 360 minutes) subgroup (2 trials) the combined standardized mean difference was 0.40 (95% CI, −0.16 to 0.96). The overall standardized mean difference for all 4 combined lifestyle trials was 0.20 (95% CI, −0.13 to 0.54), indicating that there was not a statistically significant increase in fruit and vegetable intake. There was substantial statistical heterogeneity across the trials (chi-square=89.2%; p=0.000).

Three trials reported dietary fiber outcomes,81,122,123 only one of which (n=52) showed a statistically significant increase in fiber intake of about 2.5g/day (95% CI, 1.0 to 4.0) at 12 months.81 Selected trials also included self-reported measures of protein and carbohydrate intake.47,81,110,119 Counseling interventions did not generally focus on these types of dietary intake and are briefly discussed in Key Question 4.

The majority of trials were only of fair quality and there was significant clinical and statistical heterogeneity. There was still significant heterogeneity after accounting for differences in intensity of counseling interventions and population risk, and there is limited evidence for behavioral change beyond 12 months. Only two trials (combined n=735), both conducted exclusively in women, showed that decreased energy intake was still statistically significant at 18 months127 and 54 months124 followup. Three trials (combined n=813) showed that decreased total fat and saturated fat intake was still statistically significant at 18 and 24 months.123,124,127

Physical activity behavior change. Sixteen of the 17 trials evaluating combined lifestyle counseling provided some type of physical activity behavioral outcome. Meta-analyses combining 13 of the 16 trials reporting sufficient data to be included in the analysis of self-reported amount of physical activity demonstrated a small, but statistically significant, effect (SMD, 0.19 [95% CI, 0.11 to 0.28]; I^2^=39.2%; n=4,150) (Figure 39). Only one of these studies provided a low-intensity intervention. This study found no differences between treatment and control group participants at 12-month followup. The combined effects of the medium- and high-intensity trials were both statistically significant (medium-intensity SMD, 0.20 [95% CI, 0.08 to 0.33]; I^2^=45.7%; k=8; N=2,189; high-intensity SMD, 0.26 [95% CI, 0.14 to 0.37]; I^2^=0.0%; k=4; N=1,152).

Figure 39 Meta-Analysis of Combined Lifestyle Trials (KQ3): Self-Reported Physical Activity

Figure 39 displays a forest plot of combined lifestyle trials reporting between-group differences in self-reported physical activity (for example, minutes per week). Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (1 trial) the standardized mean difference was 0.06 (95% CI, −0.08 to 0.19). In the moderate-intensity (31 to 360 minutes) subgroup (8 trials) the combined standardized mean difference was 0.20 (95% CI, 0.08 to 0.33). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined standardized mean difference was 0.26 (95% CI, 0.14 to 0.37). The overall standardized mean difference for all 13 combined lifestyle trials was 0.19 (95% CI, 0.11 to 0.28), indicating a small but statistically significant increase in self-reported physical activity. There was moderate statistical heterogeneity across the trials (chi-square=39.2%; p=0.072).

It is difficult to interpret these effect sizes due to enormous variability in measures. The standardized effect size of the medium-intensity interventions in these trials, however, is identical to the effect size of medium-intensity interventions that focused solely on physical activity, which were estimated to have resulted in approximately 38 more minutes of physical activity per week among intervention participants than control participants. High-intensity interventions had a slightly larger combined effect size, and thus may have an even larger effect than 38 additional minutes of physical activity per week.

As with the dietary outcomes, the majority of trials were only of fair quality and there was significant clinical heterogeneity amongst the trials. Combined effects were very similar in unselected samples and those selected for either behavioral or physiologic cardiovascular risk factors.

### Exploring Heterogeneity

Meta-regressions examining the effects of study characteristics on behavioral outcomes (i.e., self-reported physical activity, fat intake, and fruit and vegetable intake) were conducted using all data available in any of the 66 included studies. As with the intermediate health outcomes, we conducted multivariate meta-regression models including each of the four primary predictor variables (intervention target, risk status of the sample, intensity of the intervention, and recruitment strategy [self-identified vs. study-identified]) for each of the three outcomes.

Both intervention target and intensity predicted fat intake in a multivariate regression model, such that greater effects were seen in high-intensity trials. Exploratory analysis showed that a number of other factors also appeared to modify the size of the effect on fruit and vegetable and/or fat intake after adjusting for the four primary predictors, including: age (trials limited to older adults reported smaller reductions in fat intake); time to followup (fruit and vegetable effect sizes were larger with shorter followup); and race in U.S.-based trials (a higher proportion of nonwhite participants was associated with smaller average effect for both fat and fruit and vegetable intake). Effect sizes were not associated with whether the sample was recruited from primary care, whether it was conducted in the United States, average baseline BMI, percent male, year of publication, or quality of the trial. These effects, however, should be interpreted with caution as they were purely exploratory, and using patient-level characteristics such as percent male and percent nonwhite are subject to the bias of ecological fallacy (i.e., results of analyses of individual patients within trials may show entirely different results). The degree of estimation required for inclusion in the meta-analysis did predict the effect size for fruit and vegetable consumption. Trials requiring a high degree of estimation showed smaller average effects, suggesting that our estimation approach was conservative.

We examined the effects of different types of self-reported outcome measures on effect size to help determine whether it was acceptable to combine disparate self-report measures in the meta-analyses. For self-reported physical activity, fat intake, and fruit and vegetable intake, we grouped similar types of outcomes and created indicator variables to test differences. For example, for physical activity we combined all trials reporting some measure of minutes per week of physical activity as the first group, trials reporting other measures of amount of physical activity (e.g., sessions per week, MET-minutes per week) as a second group, and trials reporting scores on physical activity scales as a third group, and ran meta-regression with two indicator variables, using the group reporting minutes/week as the reference group. Similar approaches were used for self-reported measures of fat and fruit and vegetable intake. The type of measure did have an impact on both physical activity and fruit and vegetable intake effect sizes. Trials reporting minutes per week generally showed greater average increases in amount of physical activity than trials reporting other measures of physical activity. Trials reporting servings per day reported larger effects than those reporting a score on a constructed scale. However, only three trials reported a scale score rather than servings per day, so these results should also be viewed as purely exploratory.

Finally, as with the intermediate health outcomes, we ran meta-analyses combining trials from all three intervention targets, stratified by intervention intensity to aid visual exploration of these effects. These forest plots are included in Appendix G.

## Key Question 4. What are the adverse effects of primary care relevant behavioral counseling interventions for physical activity and/or healthful diet?

Only two of the trials meeting our inclusion criteria for testing the efficacy of physical activity counseling (with or without dietary counseling) reported adverse events.32,55 Both of these trials reported that mild muscular fatigue, strain, or soreness were relatively common in the intervention groups, occurring in 22 to 24 percent of intervention participants. Three other studies reported falls,36,58,59 two of which also reported injuries related to falls. All of these studies found physical activity to either have no effect or to have a protective effect on falls and injuries.

We also searched for comparative observational studies demonstrating a link between physical activity and cardiac events. We found seven studies that conducted case-crossover analyses to determine whether cardiac events (sudden death or myocardial infarction) were more likely to occur during periods of vigorous physical exertion.133–139 Some of these studies also conducted case-control analyses, but the focus of this review remains on the case-crossover analyses due to the difficulty of assembling truly comparable controls and the fact that these studies did not link cardiac events with physical activity at the time of the event.

All seven studies showed that the risk of a cardiac event increased during vigorous exertion, with a range of two- to 17-fold increase in risk (Appendix C Table 4). When analyses were stratified by level of habitual activity, however, this increased risk was much greater for people with low levels of regular activity. In some cases, no increased risk was apparent in people with moderate-to-high levels of usual activity, while the risk of cardiac events were seven to 107 times higher in the presence of vigorous exertion for people with very low levels of habitual activity. Nevertheless, the absolute risk during physical activity was very low. One of these studies133 estimated that the incidence of sudden death associated with vigorous physical activity was 1/1.42 million person-hours of exertion (based on a study of 21,481 men). This incident was not reported separately by level of habitual activity.

Other harms that may be associated with physical activity are injuries and arthritis. We did not comprehensively search for evidence in these areas as it was beyond the focus of this review. However, we discuss the findings of a recent DHHS report covering these areas in the discussion section of this review.141

We found no studies designed to assess the adverse effects of dietary counseling or the adverse effects of increasing fruits and vegetables, increasing fiber, decreasing sodium, or decreasing fat intake. None of the healthful diet counseling trials reported specific adverse events. One potential adverse effect of dietary counseling is unintended changes in other food or nutrient intake, such as low-fat counseling increasing carbohydrate intake. None of the included healthful diet counseling trials showed a statistically significant increase in overall energy intake, decrease in fruit or vegetable, increase in sodium, or increase in fat or saturated fat intake. Very few trials reported monounsaturated fat, polyunsaturated fat, or carbohydrate or sugar intake.47,77,78,80,81,96,104,110,119 Only two of the eight trials that reported carbohydrate or sugar intake showed a statistically significant increase in carbohydrate intake. One trial showed an increase in self-reported carbohydrate intake at 6 months—an 11.9 percent (95% CI, 10.1 to 13.6) increase in percent energy intake due to carbohydrates.110 In the WHI, the intervention group had an approximate 10 percent increase in energy from carbohydrates as compared to the control group at 12 and 72 months.104 In both these trials, however, there was a statistically significant decrease in overall energy intake. In two trials, it appears that low-fat dietary counseling statistically significantly reduced intake of both saturated and unsaturated fats.96,104 Another trial showed a statistically significant increase in the use of polyunsaturated fats,78 and a third trial found a nonstatistically significant change in unsaturated fats.81 It is likely that use of unsaturated fats, both polyunsaturated and monounsaturated, may lower cholesterol when used in place of saturated fats.