# Methods

The previous USPSTF reviews addressing behavioral counseling for physical activity and healthful diet were independently conducted in 2002^24^ and 2003.^26^ After consulting with the USPSTF liaisons, we decided to coordinate the update of these two topics due to the significant overlap in literature and their similar implications for clinical practice. This decision also allowed us to review the body of literature that addressed combined physical activity and healthful diet counseling, which was not thoroughly addressed in the previous reviews. To accomplish this, we developed an analytic framework and four key questions (Figure 1) to guide our review. We present the results for each of the key questions according to the intervention’s target (i.e., physical activity, healthful diet, or combined physical activity and healthful diet, referred to as combined lifestyle). We reviewed the literature on health outcomes (key question 1 [KQ1]), intermediate outcomes (key question 2 [KQ2]), and harms of the counseling interventions (key question 4 [KQ4]), as opposed to the previous reviews’ focus on only behavioral outcomes (key question 3 [KQ3]). Other important differences between these reviews include:

1. For dietary interventions, behavioral outcomes could include: appropriate energy content, balance of fats, increased fruits and vegetables, increased legumes and lean proteins, increased fiber, increased non- or low-fat dairy, balance of carbohydrates, and reduced sodium. The previous dietary counseling review was limited to interventions that primarily focused on fat, fruits and vegetables, and dietary fiber intake.
2. Primary care-relevant counseling interventions that included both diet and physical activity counseling were included. The previous healthy diet review was limited to trials focusing primarily on diet.
3. Both randomized and nonrandomized controlled trial evidence will be included on counseling interventions to improve diet. The previous healthful diet review included only randomized controlled trials, and the previous physical activity review accepted observational designs in addition to controlled trials.
4. The current review included trials that were feasible for primary care or referable from primary care, and did not require that a primary care clinician be directly involved in the intervention delivery. Interventions included in the previous physical activity review were limited to studies in which at least one component was delivered by a primary care clinician.

Figure 1 Analytic Framework and Key Questions

Figure 1 is an analytic framework that depicts the events that individuals experience while undergoing counseling for a healthy lifestyle for the purposes of improving cardiovascular health outcomes. The framework includes 6 headers: Patient Population, Counseling Intervention, Intermediate Outcomes, Behavioral Outcomes, Health Outcomes, and Adverse Effects. The patient population is adults and older adults both with and without cardiovascular risk factors. The intervention is behavioral counseling for healthful diet and/or physical activity. The intermediate outcomes, which are used to determine if the counseling is effective, include blood pressure, cholesterol, glucose tolerance, weight, and body mass index. The behavioral outcomes include physical activity and dietary intake. The health outcomes include decreased cardiovascular risk and related morbidity and mortality. Adverse effects of counseling for physical activity include mild muscle fatigue or soreness, injuries, and falls. Adverse effects of counseling for a healthful diet include unintended changes in other food or nutrient intake.

## Data Sources and Searches

In addition to evaluating all trials included in the previous reviews, we searched for systematic reviews from January 2001 through July 2008 in MEDLINE, the Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effects, and publications from IOM, Agency for Healthcare Research and Quality (AHRQ), and National Institute of Health and Clinical Excellence (Appendix B Table 2) to locate trials that were excluded from the prior reviews because they did not report a behavioral outcome. In addition, we searched (Appendix B) MEDLINE, PsycInfo, and the Cochrane Central Register of Controlled Trials to locate relevant trials for all key questions published since the previous reviews were conducted from January 2001 through the end of 2009. We supplemented our searches with suggestions from experts and a review of reference lists from other relevant publications.

## Study Selection

Two investigators independently reviewed 13,562 abstracts and 474 articles (Appendix B Figure 1) against the specified inclusion criteria (Appendix B Table 1). Discrepancies were resolved by consensus. Articles excluded for not meeting inclusion criteria for poor quality are listed in Appendix D Tables 1–5.

The current review targeted behaviorally-based counseling interventions for physical activity, healthful diet, or both. Interventions of primary prevention of obesity, hypertension, hyperlipidemia, diabetes, or CVD were considered to be within scope of this review. Interventions aimed at weight loss were excluded, as were those providing controlled diets or supervised physical activity. We included physical activity interventions that incorporated activities such as walking, cycling, swimming, or resistance training. We included healthful diet interventions aiming to change dietary behavior or improve or maintain cardiovascular health through a balanced diet (e.g., appropriate calorie intake; increased fruits and vegetables, whole grains, and fiber; balanced intake of balanced fats; and decreased sodium).

Study designs were limited to randomized controlled trials or controlled clinical trials comparing an active intervention against a usual-care, a minimal-intervention, or an attention-control group. Studies were considered for key questions addressing efficacy or effectiveness of healthful diet, physical activity, or combined healthy lifestyle counseling (KQ1–KQ3). We also included observational studies reporting serious cardiovascular harms (KQ4), such as acute cardiac events during or immediately after physical activity. Trial participants were limited to unselected adults (i.e., those who were not screened for CVD risk factors) or individuals who were screened and did not meet criteria for hypertension, hyperlipidemia, diabetes, or CVD. We excluded trials in which more than 50 percent of the population had diabetes, hypertension (or using hypertension medications), dyslipidemia (or using dyslipidemia medications), or heart disease. We excluded trials in which the average total cholesterol of participants was >6.21 mmol/L (240 mg/dL), average triglycerides was ≥2.26 mmol/L (200 mg/dL), average LDL was ≥4.14 mmol/L (160 mg/dL), average systolic blood pressure was ≥140 mmHg, or average diastolic blood pressure was ≥90 mmHg. We excluded studies conducted in settings that were not generalizable to primary care, including inpatient care, emergency departments, or occupational settings. We included studies with interventions that were conducted over the phone or electronically. We also included studies that tested interventions that were referable from primary care or considered feasible to conduct within primary care settings (see Appendix B Table 1 for more detail on what is considered primary care-feasible or referable).

We required that duration of followup be 6 months or longer. We examined health outcomes including morbidity or mortality related to CVD. Intermediate health outcomes included blood pressure, total cholesterol, LDL cholesterol, HDL cholesterol, fasting serum glucose, glucose tolerance, hemoglobin A1C, weight, and body mass index (BMI). Consistent with current USPSTF methods, incidence of disease (e.g., diabetes, hypertension) was also considered an intermediate health outcome. We accepted a number of behavioral outcomes, including self-reported dietary intake, self-reported physical activity, or objectively measured markers of behavior change, such as VO_2_max and urinary sodium.

## Data Extraction and Quality Assessment

We extracted study setting, population details, intervention details, and outcomes from included studies into standardized evidence tables for each intervention category (Appendix C Tables 1–4). Trials with multiple intervention arms may appear in multiple tables, if appropriate. A second reviewer verified all extracted data.

Articles meeting inclusion criteria were independently critically appraised by two reviewers using the USPSTF’s design-specific quality criteria27 supplemented with the National Institute for Health and Clinical Excellence methodology checklists.28 Articles were rated as good-, fair-, or poor-quality. In general, a good-quality study met all criteria well. A fair-quality study did not meet, or it was unclear if it met, at least one criterion, but also had no known important limitations that could invalidate its results. A poor-quality study had important limitations. We excluded poor-quality studies from this review.

## Data Synthesis and Analysis

We separately synthesized identified evidence for three types of interventions: those focused on increasing physical activity, those focused on eating a healthful diet, and those focused on both physical activity and healthful diet counseling.

We conducted random effects meta-analyses to estimate the effect size of counseling on both intermediate health outcomes (adiposity, systolic and diastolic blood pressure, total cholesterol, HDL, LDL, triglycerides, and glucose) and behavioral outcomes (self-reported physical activity; objectively measured fitness; intake of total energy, fat, saturated fat, fiber, fruits and vegetables; and urinary sodium as a measure of sodium intake). We conducted separate analyses for each of the three intervention categories, and further grouped the dietary trials by intervention target (sodium reduction, fruit and vegetable only focus, or general low-fat/heart-healthy dietary counseling). Analyses were also stratified by intervention intensity. Low-intensity trials were estimated to involve 30 minutes or less of contact with providers. These trials generally included only a single contact, two very brief contacts, or mail-only interventions. Medium-intensity trials were estimated to involve more than 30 minutes but less than 6 hours of contact with providers (e.g., 1-hour group meeting monthly for up to 6 months). High-intensity trials were those that were estimated to involve more than 6 hours of contact. Because many articles did not report detailed information about the time of contact, these categorizations often involved reviewer judgment. As such, at least one other team member reviewed the studies’ categorizations, and discrepancies were resolved through discussion. Trials were also categorized by how participants were selected: 1) participants were unselected or selected based on age only; 2) participants were selected for sub-optimal behavior (i.e., sedentary behavior or poor dietary intake); and 3) participants were selected for individual or population risk factor for increased incidence of CVD (e.g., mildly elevated diastolic blood pressure, fasting glucose, serum lipids, increased BMI, poverty or poor access to health care). Details of the meta-analysis and calculations are included in Appendix E. Briefly, we combined intervention arms within trials with multiple active treatment arms meeting our inclusion criteria that were of similar intensity to calculate standard deviations based on the information provided in the individual articles. We converted measurements into common units using standard conversion factors, which are provided in Appendix E. We also adjusted results for studies that were cluster randomized, but did not report adjusting for the clustering effect.

We assessed the presence of statistical heterogeneity among the studies using standard χ^2^ tests and the magnitude of heterogeneity was estimated using the I^2^ statistic.29 With 10 or more studies, we assessed for publication bias and whether the distribution of the effect sizes was symmetric with respect to the precision measure by using funnel plots and Egger’s linear regression method.30,31

We ran meta-regressions combining all studies included for KQ1–KQ3 (studies reporting treatment efficacy) to examine the effect of four a priori-specified primary sources of heterogeneity on effect size: intervention intensity (low, medium, high), intervention target (physical activity, healthful diet, combined lifestyle), study population risk (unselected, selected for behavioral factors, selected for increased cardiovascular risk), and recruitment method (self-identified, such as through media advertisements, vs. study-identified). Two dummy variables were entered for predictors with three levels; reference categories were low intensity, combined lifestyle target, and unselected for risk. In addition, we ran a series of exploratory meta-regressions to examine the effects on effect size of: study design (months of followup, overall methodological quality of the study), year of publication, measurement (type of self-report measure of physical activity, fat intake, and fruit and vegetable intake), degree of estimation (calculation needed to use each study’s data in the meta-analysis), setting (United States vs. not United States, whether the sample was selected from primary care or not), and population characteristics (average age, percent male, percent nonwhite, average baseline BMI). To accomplish this, we included a single exploratory factor in each meta-regression model, controlling for the four a priori predictors (intensity, target, risk status, and recruitment approach).

All analyses were performed using Stata 10.0 (StataCorp LP, College Station, Texas).

## USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions, to address methodological decisions on applicable evidence, and to resolve issues around scope for the final evidence synthesis. This research was funded by AHRQ under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, reviewed the draft report, and assisted in external review of the draft evidence synthesis.