# Introduction

## Scope and Purpose

In 2002 and 2003, the U.S. Preventive Services Task Force (USPSTF) made recommendations on counseling to improve physical activity and healthful diet based on two separate systematic reviews of the literature. We undertook the current review to assist the USPSTF in updating these recommendations. This review combined both topics and evaluates the effectiveness and adverse effects of physical activity and dietary counseling interventions to prevent cardiovascular disease (CVD) in adults. In addition, this review focuses on the effectiveness of behavioral counseling as primary prevention for CVD and therefore does not include counseling interventions targeted to persons with known CVD, diabetes, hypertension, or dyslipidemia. Trials focusing on weight loss or weight management in adults are addressed in a separate USPSTF review on adult obesity, which is currently being updated.

## Background

### Condition Definition

Physical activity has been defined as “bodily movement produced by the contraction of skeletal muscle that increases energy expenditure above the basal level.” 1 This review operationalized this definition to include interventions promoting aerobic- or strength-related physical activity. We did not review interventions focusing primarily on flexibility or balance.

A healthful diet promotes health and reduces risk of chronic disease through nutritious eating patterns. For this review, we considered dietary counseling that promoted a balanced diet (e.g., appropriate energy content); balance of fats (e.g., consumption of mono- and polyunsaturated fats, omega-3 fats, avoidance of excess saturated fat, avoidance of trans fats); increased consumption of fruits and vegetables; increased consumption of legumes; increased consumption of lean proteins; increased consumption of non- or low-fat dairy; diet balanced in carbohydrates (e.g., consumption of whole grain and fiber, avoidance of excess refined carbohydrates, including excess sweetened beverages); and avoidance of excess sodium. We did not review dietary counseling that focused only on micronutrient intake, vitamin and/or antioxidant supplementation, or alcohol moderation.

### Burden of Disease

Diseases associated with physical inactivity and poor diet rank among the leading causes of illness and death in the United States,2,3 and are well established determinants in many chronic diseases, including cardiovascular and cerebrovascular disease, hypertension, dyslipidemia, and type 2 diabetes.2,4–6

Convincing evidence suggests that regular physical activity decreases CVD risk5,6 and numerous studies have shown an inverse relationship between exercise and heart disease mortality.6,7 Similarly, regular exercise increases high-density lipoprotein (HDL) cholesterol and decreases triglycerides, blood pressure, and risk of CVD events.6 Studies have also shown that diet clearly affects cardiovascular health. Diets high in fruits and vegetables can decrease CVD.5 Evidence also suggests that saturated and trans fatty acids increase CVD while linoleic acid, fish oils, plant sterols and stanols, alpha-linolenic acid, oleic acid, and nuts decrease CVD.5 Likewise, there is convincing evidence that high sodium intake increases high blood pressure, while potassium can decrease blood pressure.5

Available evidence strongly suggests that regular physical activity decreases an individual’s risk for type 2 diabetes,5,6 likely through improving insulin sensitivity and reduced total and abdominal adiposity.4 Similarly, excess energy intake increases obesity, which may increase the risk for type 2 diabetes. While there is little evidence that total carbohydrate intake is associated with diabetes, high glycemic index of a diet may be a risk factor.4 Evidence also suggests that saturated fatty acids can increase the risk for type 2 diabetes, while a high intake of fruits, vegetables, and dietary fiber can decrease type 2 diabetes risk.5

### Prevalence of Physical Activity and Healthful Dietary Behaviors

The U.S. Department of Health and Human Services’ (DHHS) 2008 report on physical activity concluded that individuals of all ages benefit from regular exercise, and that substantial health benefits can be obtained from moderate-to-vigorous physical activity. Moderate physical activity is defined as 3.0 to 5.9 metabolic equivalent units (METs) (e.g., walking at a pace of 3 miles per hour).6 Vigorous physical activity is defined as 6.0 METs or greater (e.g., walking uphill at a pace of 3.5 miles per hour).6 According to the DHHS Physical Activity Guidelines, adults should engage in at least 150 minutes of moderate-intensity or 75 minutes of vigorous-intensity aerobic physical activity per week (or an equivalent combination of moderate- and vigorous-intensity aerobic activity) to obtain substantial health benefits, in addition to strengthening activities at least twice per week. The American College of Sports Medicine, the American Heart Association (AHA), and the Centers for Disease Control and Prevention (CDC) have issued very similar guidelines.8–10 However, Americans generally do not meet these physical activity guidelines. According to the Healthy People 2010 midcourse review,11 39 percent of Americans aged 18 years or older reported no leisure time physical activity, while 31 percent met the Healthy People 2010 objectives for moderate or vigorous exercise during 2006. Physical activity declines with age: 38 percent of 18- to 24-year-olds reported regular moderate or vigorous physical activity, while only 29 percent of 45- to 64-year-olds reported this level of activity. Rates were even lower in older adults: 26 percent of 65- to 74-year-olds and 17 percent of persons aged 75 or older reported moderate or vigorous physical activity.

In light of the significant impact diet and nutrition have on health, multiple national and international agencies have developed guidelines for dietary intake of macronutrients, including the Institute of Medicine (IOM), World Health Organization (WHO), DHHS, U.S. Department of Agriculture (USDA), American Dietetic Association, CDC, AHA, American Cancer Society (ACS), and American Diabetes Association (ADA). Although there are subtle differences among these groups’ recommendations, they all generally recommended higher consumption of fruits, vegetables, polyunsaturated and monounsaturated fatty acids, fish, whole grains, and fiber. These recommendations also include lower consumption of fat, saturated fatty acids, sodium, and refined sugars. The 2005 Dietary Guidelines for Americans, for example, recommend five to 13 daily servings of fruits and vegetables, depending on caloric needs.12 It also recommends a diet that acquires less than 10 percent of its total calories from saturated fat, less than 20 to 35 percent from total fat, and a limited amount of trans fatty acids. However, most Americans’ diets are drastically out of line with these recommended levels. In 2005, the USDA reported that based on the Dietary Guidelines for Americans recommendations, Americans over-consumed refined grains, sugars, meats, and fats, and under-consumed whole grains and fruits and vegetables.13 Data from the 2005 Behavioral Risk Factor Surveillance System indicates that only 33 percent of adults consumed at least two servings of fruits and only 27 percent consumed at least three daily servings of vegetables.14

### Risk Factors for Poor Diet and Low Physical Activity

People of lower socioeconomic status tend to exercise less and eat fewer fruits, vegetables, and foods rich in dietary fiber, compared with people in a higher socioeconomic position.15,16 Major barriers to a healthful diet include low income, marketing of unhealthy foods, lack of accessible and accurate information on what constitutes a healthful diet, poor access to affordable healthy foods, lack of opportunity to develop healthy cooking skills, and sociocultural factors (e.g., family or cultural food norms, family resistance, lack of support, and childcare demands).17 Major barriers to physical activity in adults include the high costs of exercise facilities, equipment, and sports teams; poor access to facilities; unsafe environments for physical activity; and urban designs that discourage walking.15,18,19 Psychosocial barriers to physical activity include anxiety about unfamiliar settings for physical activity, poor body image, lack of social support for physical activity, low self-efficacy for maintaining a physical activity program, and lack of belief in the benefits of physical activity.15

### Current Clinical Practice

Although patients perceive family doctors as one of the most reliable sources of information on food and nutrition, data on dietary counseling practices of primary care clinicians indicate that providers pay limited attention to diet modification.20 In a 1999–2000 survey of U.S. adults, only 33 percent of respondents reported that their physician had advised them to eat more fruits and vegetables during the previous year, and 29 percent reported receiving similar advice to reduce dietary fat.21 In another recent survey, 25 percent of adult patients from four community-based, family medicine clinics indicated that their physicians had advised them to limit or reduce the amount of fat in their diets.22 Similarly, 28 percent of respondents to a national household survey reported that their health care provider had advised them to increase their level of physical activity. Only half of those receiving advice, however, also received help in developing physical activity program or followup support.21 Data from Canada are consistent with these findings: 38 percent of adults reported “often” or “always” receiving advice from their physicians on diet or healthful eating.23 This survey also reported that 42 percent of respondents received advice on physical activity “often” or “always”.

### Previous USPSTF Recommendations

In 2002, the USPSTF concluded that there was insufficient evidence to recommend for or against behavioral counseling in primary care settings to promote physical activity (I recommendation). Data included in the 2002 physical activity counseling review24 were limited to trials conducted, at least in part, by primary care staff. Thus, trials in which research staff conducted the intervention were excluded, even if they were conducted in primary care settings using methods that were feasible for use in primary care.

Available data on the feasibility and potential harms of routine physical activity counseling in primary care settings were also limited in the 2002 review. Only the Activity Counseling Trial reported rates of physical harm during the 2 years following counseling.25 Based on this paucity of data, the USPSTF concluded that the balance of benefits and harms, as well as approaches to preventing adverse effects (particularly among older adults and those less fit), needed further exploration.

In 2003, the USPSTF concluded that there was insufficient evidence to recommend for or against routine behavioral counseling to promote a healthful diet in unselected patients in primary care (I recommendation). In addition, the Task Force recommended intensive behavioral dietary counseling for adult patients with hyperlipidemia and other known risk factors for cardiovascular and diet-related chronic disease. This intensive counseling could be delivered by primary care clinicians or referral to other specialists, such as nutritionists or dietitians (B recommendation).

The prior evidence review on dietary counseling found that counseling patients can improve dietary behaviors, including reduction in total and saturated fat consumption and increases in fruit and vegetable intake.26 The previous review found insufficient evidence to determine the effectiveness of counseling in changing consumption of whole grains, fiber, calcium, sodium, or fish. The strength of this evidence was also limited by reliance on self-reported dietary outcomes, limited followup, and enrollment of participants who were not necessarily representative of primary care patients. Intensive interventions were more likely to produce important changes, but lower-intensity interventions did result in smaller positive changes in dietary behavior. Although the largest effect of dietary counseling in asymptomatic adults has been observed with more intensive interventions among patients with risk factors for diet-related chronic disease, it is unknown whether similar approaches are effective among unselected adults. Additionally, because there was little direct evidence regarding the effect of dietary changes on health outcomes, it is unclear if small changes in dietary behavior seen in lower-intensity trials translate into changes in the incidence of chronic disease.