# Figures 1–16. Forest Plots of All Trials

Appendix G Figure 1 Meta-Analysis of All Trials Combined, By Intervention Intensity (KQ2): Adiposity

Appendix G Figure 1 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in adiposity (reported as either body mass index or weight). Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (5 trials) the combined standardized mean difference was −0.10 (95% CI, −0.22 to 0.02). In the moderate-intensity (31 to 360 minutes) subgroup (12 trials) the combined standardized mean difference was −0.14 (95% CI, −0.27 to −0.01). In the high-intensity (more than 360 minutes) subgroup (9 trials) the combined standardized mean difference was −0.48 (95% CI, −0.64 to −0.32). The overall standardized mean difference for all 26 trials reporting adiposity was −0.25 (95% CI, −0.33 to −0.17). There was significant statistical heterogeneity across the trials (chi-square=86.6%; p=0.000).

Appendix G Figure 2 Meta-Analysis of All Trials Combined, US Trials Only (KQ2): Adiposity

Appendix G Figure 2 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in adiposity (reported as either body mass index or weight) and took place in the United States. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (1 trial) the standardized mean difference was −0.04 (95% CI, −0.17 to 0.10). In the moderate-intensity (31 to 360 minutes) subgroup (3 trials) the combined standardized mean difference was −0.03 (95% CI, −0.13 to 0.06). In the high-intensity (more than 360 minutes) subgroup (7 trials) the combined standardized mean difference was −0.49 (95% CI, −0.67 to −0.32). The overall standardized mean difference for all 11 U.S. trials reporting adiposity was −0.32 (95% CI, −0.45 to −0.18). There was significant statistical heterogeneity across the trials (chi-square=91.3%; p=0.000).

Appendix G Figure 3 Meta-Analysis of All Trials Combined, By Intervention Intensity (KQ2): Systolic Blood Pressure

Appendix G Figure 3 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in systolic blood pressure. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (3 trials) the combined unstandardized weighted mean difference was −1.15 (95% CI, −3.34 to 1.03). In the moderate-intensity (31 to 360 minutes) subgroup (11 trials) the combined unstandardized weighted mean difference was −0.52 (95% CI, −1.79 to 0.75). In the high-intensity (more than 360 minutes) subgroup (10 trials) the combined unstandardized weighted mean difference was −1.53 (95% CI, −2.13 to −0.93). The overall unstandardized weighted mean difference for all 24 trials reporting systolic blood pressure was −1.23 (95% CI, −1.75 to −0.70). There was moderate statistical heterogeneity across the trials (chi-square=49.9%; p=0.003).

Appendix G Figure 4 Meta-Analysis of All Trials Combined, US Trials Only (KQ2): Systolic Blood Pressure

Appendix G Figure 4 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in systolic blood pressure and took place in the United States. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was 1.48 (95% CI, −2.78 to 5.75). In the high-intensity (more than 360 minutes) subgroup (9 trials) the combined unstandardized weighted mean difference was −1.46 (95% CI, −2.02 to −0.91). The overall unstandardized weighted mean difference for all 11 U.S. trials reporting systolic blood pressure was −1.35 (95% CI, −1.95 to −0.75). There was moderate statistical heterogeneity across the trials (chi-square=49.9%; p=0.030).

Appendix G Figure 5 Meta-Analysis of All Trials Combined (KQ2): Diastolic Blood Pressure

Appendix G Figure 5 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in diastolic blood pressure. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (3 trials) the combined unstandardized weighted mean difference was −0.47 (95% CI, −1.17 to 0.22). In the moderate-intensity (31 to 360 minutes) subgroup (9 trials) the combined unstandardized weighted mean difference was −0.27 (95% CI, −1.37 to 0.83). In the high-intensity (more than 360 minutes) subgroup (10 trials) the combined unstandardized weighted mean difference was −0.73 (95% CI, −0.87 to −0.59). The overall unstandardized weighted mean difference for all 22 trials reporting diastolic blood pressure was −0.72 (95% CI, −1.04 to −0.40). There was slight statistical heterogeneity across the trials (chi-square=37.6%; p=0.039).

Appendix G Figure 6 Meta-Analysis of All Trials Combined, US Trials Only (KQ2): Diastolic Blood Pressure

Appendix G Figure 6 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in diastolic blood pressure and took place in the United States. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was 1.01 (95% CI, −2.71 to 4.73). In the high-intensity (more than 360 minutes) subgroup (9 trials) the combined unstandardized weighted mean difference was −0.73 (95% CI, −0.87 to −0.58). The overall unstandardized weighted mean difference for all 11 U.S. trials reporting diastolic blood pressure was −0.75 (95% CI, −1.08 to −0.41). There was no statistical heterogeneity across the trials (chi-square=30.4%; p=0.157).

Appendix G Figure 7 Meta-Analysis of All Trials Combined (KQ2): Total Cholesterol

Appendix G Figure 7 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in total cholesterol. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (1 trial) the unstandardized weighted mean difference was 0.02 (95% CI, −0.09 to 0.13). In the moderate-intensity (31 to 360 minutes) subgroup (14 trials) the combined unstandardized weighted mean difference was −0.04 (95% CI, −0.11 to 0.02). In the high-intensity (more than 360 minutes) subgroup (6 trials) the combined unstandardized weighted mean difference was −0.17 (95% CI, −0.25 to −0.09). The overall unstandardized weighted mean difference for all 21 trials reporting total cholesterol was −0.08 (95% CI, −0.13 to −0.02). There was moderate statistical heterogeneity across the trials (chi-square=56.9%; p=0.001).

Appendix G Figure 8 Meta-Analysis of All Trials Combined, US Trials Only (KQ2): Total Cholesterol

Appendix G Figure 8 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in total cholesterol and took place in the United States. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (3 trials) the combined unstandardized weighted mean difference was 0.07 (95% CI, −0.08 to 0.23). In the high-intensity (more than 360 minutes) subgroup (5 trials) the combined unstandardized weighted mean difference was −0.18 (95% CI, −0.26 to −0.09). The overall unstandardized weighted mean difference for all 8 U.S. trials reporting total cholesterol was −0.08 (95% CI, −0.19 to 0.03). There was significant statistical heterogeneity across the trials (chi-square=76.0%; p=0.000).

Appendix G Figure 9 Meta-Analysis of All Trials Combined, By Intervention Intensity (KQ2): Low-Density Lipoproteins

Appendix G Figure 9 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in low-density lipoprotein (LDL) cholesterol. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (9 trials) the combined unstandardized weighted mean difference was −0.01 (95% CI, −0.10 to 0.08). In the high-intensity (more than 360 minutes) subgroup (6 trials) the combined unstandardized weighted mean difference was −0.13 (95% CI, −0.21 to −0.06). The overall unstandardized weighted mean difference for all 15 trials reporting LDL cholesterol was −0.07 (95% CI, −0.14 to 0.00). There was moderate statistical heterogeneity across the trials (chi-square=51.9%; p=0.010).

Appendix G Figure 10 Meta-Analysis of All Trials Combined, US Trials Only (KQ2): Low-Density Lipoproteins

Appendix G Figure 10 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in low-density lipoprotein (LDL) cholesterol and took place in the United States. Data for the figure are presented alongside the forest plot. In the moderate-intensity (31 to 360 minutes) subgroup (2 trials) the combined unstandardized weighted mean difference was 0.12 (95% CI, −0.04 to 0.29). In the high-intensity (more than 360 minutes) subgroup (5 trials) the combined unstandardized weighted mean difference was −0.14 (95% CI, −0.21 to −0.07). The overall unstandardized weighted mean difference for all 7 U.S. trials reporting LDL cholesterol was −0.07 (95% CI, −0.17 to 0.04). There was significant statistical heterogeneity across the trials (chi-square=74.5%; p=0.001).

Appendix G Figure 11 Meta-Analysis of All Trials Combined, By Intervention Intensity (KQ3): Self-Reported Fat Intake

Appendix G Figure 11 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in self-reported fat intake. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (6 trials) the combined standardized mean difference was −0.23 (95% CI, −0.29 to −0.18). In the moderate-intensity (31 to 360 minutes) subgroup (8 trials) the combined standardized mean difference was −0.28 (95% CI, −0.61 to 0.04). In the high-intensity (more than 360 minutes) subgroup (9 trials) the combined standardized mean difference was −0.85 (95% CI, −1.18 to −0.52). The overall standardized mean difference for all 23 trials reporting fat intake was −0.48 (95% CI, −0.83 to −0.14). There was significant statistical heterogeneity across the trials (chi-square=99.3%; p=0.000).

Appendix G Figure 12 Meta-Analysis of All Trials Combined, US Trials Only (KQ3): Self-Reported Fat Intake

Appendix G Figure 12 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in self-reported fat intake and took place in the United States. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (5 trials) the combined standardized mean difference was −0.22 (95% CI, −0.27 to −0.16). In the moderate-intensity (31 to 360 minutes) subgroup (4 trials) the combined standardized mean difference was −0.23 (95% CI, −0.73 to 0.26). In the high-intensity (more than 360 minutes) subgroup (7 trials) the combined standardized mean difference was −0.99 (95% CI, −1.31 to −0.67). The overall standardized mean difference for all 16 U.S. trials reporting fat intake was −0.55 (95% CI, −0.96 to −0.14). There was significant statistical heterogeneity across the trials (chi-square=99.4%; p=0.000).

Appendix G Figure 13 Meta-Analysis of All Trials Combined, By Intervention Intensity (KQ3): Self-Reported Fruits and Vegetables Intake

Appendix G Figure 13 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in self-reported fruit and vegetable intake. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (6 trials) the combined standardized mean difference was 0.34 (95% CI, 0.17 to 0.52). In the moderate-intensity (31 to 360 minutes) subgroup (6 trials) the combined standardized mean difference was 0.36 (95% CI, 0.10 to 0.62). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined standardized mean difference was 0.48 (95% CI, 0.23 to 0.73). The overall standardized mean difference for all 16 trials reporting fruit and vegetable intake was 0.39 (95% CI, 0.22 to 0.55). There was significant statistical heterogeneity across the trials (chi-square=97.4%; p=0.000).

Appendix G Figure 14 Meta-Analysis of All Trials Combined, US Trials Only (KQ3): Self-Reported Fruits and Vegetables Intake

Appendix G Figure 14 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in self-reported fruit and vegetable intake and took place in the United States. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (4 trials) the combined standardized mean difference was 0.20 (95% CI, 0.14 to 0.25). In the moderate-intensity (31 to 360 minutes) subgroup (5 trials) the combined standardized mean difference was 0.43 (95% CI, 0.13 to 0.73). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined standardized mean difference was 0.48 (95% CI, 0.23 to 0.73). The overall standardized mean difference for all 13 U.S. trials reporting fruit and vegetable intake was 0.39 (95% CI, 0.21 to 0.57). There was significant statistical heterogeneity across the trials (chi-square=97.2%; p=0.000).

Appendix G Figure 15 Meta-Analysis of All Trials Combined, By Intervention Intensity (KQ3): Self-Reported Physical Activity

Appendix G Figure 15 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in self-reported physical activity. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (9 trials) the combined standardized mean difference was 0.07 (95% CI, 0.00 to 0.15). In the moderate-intensity (31 to 360 minutes) subgroup (23 trials) the combined standardized mean difference was 0.18 (95% CI, 0.12 to 0.25). In the high-intensity (more than 360 minutes) subgroup (4 trials) the combined standardized mean difference was 0.26 (95% CI, 0.14 to 0.37). The overall standardized mean difference for all 36 trials reporting physical activity was 0.16 (95% CI, 0.11 to 0.21). There was moderate statistical heterogeneity across the trials (chi-square=50.3%; p=0.000).

Appendix G Figure 16 Meta-Analysis of All Trials Combined, US Trials Only (KQ3): Self-Reported Physical Activity

Appendix G Figure 16 displays a forest plot combining trials from all 3 intervention targets (physical activity, healthful diet, and combined lifestyle) that reported between-group differences in self-reported physical activity and took place in the United States. Data for the figure are presented alongside the forest plot. In the low-intensity (30 minutes or less) subgroup (6 trials) the combined standardized mean difference was 0.12 (95% CI, −0.02 to 0.25). In the moderate-intensity (31 to 360 minutes) subgroup (13 trials) the combined standardized mean difference was 0.14 (95% CI, 0.07 to 0.21). In the high-intensity (more than 360 minutes) subgroup (3 trials) the combined standardized mean difference was 0.26 (95% CI, 0.13 to 0.38). The overall standardized mean difference for all 22 U.S. trials reporting physical was 0.15 (95% CI, 0.09 to 0.21). There was no significant statistical heterogeneity across the trials (chi-square=36.6%; p=0.045).