# Previous and Pending Studies

Appendix F Table 1 Studies included in the Previous Reviews

Studies included in the previous healthy diet counseling review
Study ID | Current review
Baron 1990^78^ | Included
Beresford 1992^157^ | Excluded for <6 months of followup
Beresford 1997^79^ | Included
Campbell 1994^158^ | Excluded for <6 months of followup
Coates 1999^83^ | Included
Delichatsios, Friedman et al 2001^34^ | Included
Delichatsios, Hunt et al 2001^159^ | Excluded for <6 months of followup
Henderson 1990^160^ | Excluded for targeting a noncardiovascular-related condition
Keyserling 1997^161^ | Excluded for population >50% with hypertension or dyslipidemia
Knutsen 1991^162^ | Excluded for population >50% with hypertension or dyslipidemia
Kristal 2000^91^ | Included
Lindholm 1995^163^ | Excluded for population >50% with hypertension or dyslipidemia
Lutz 1999^92^ | Included
Maskarinec 1999^164^ | Excluded for comparative-effectiveness study design
Mojonnier 1980^165^ | Excluded at abstract phase (coversheet says I4 – hyperchol)
Neaton 1981^166^ | Excluded for population >50% with hypertension or dyslipidemia
Ockene 1996^167^ | Excluded for population >50% with hypertension or dyslipidemia
Roderick 1997^94^ | Included
Siero 2000^168^ | Excluded for <6 months of followup
Simkin-Silverman 1995^124^ | Included for lifestyle counseling review
Steptoe 1999^169^ | Excluded for high or differential attrition

Studies included in the previous physical activity counseling review
Study ID | Current review
Activity Counseling Trial 2001^25^ | Excluded for comparative-effectiveness study design
Burton 1995^170^ | Excluded for other quality issues
Goldstein 1999^38^ | Included
Kerse 1999^171^ | Excluded for not focusing on counseling interventions to improve physical activity to reduce cardiovascular risk
Norris 2000^68^ | Included
Smith 2000^172^ | Excluded for other quality issues
Steptoe 1999^169^ | Excluded for high or differential attrition
Swinburn 1998^173^ | Excluded for <6 months of followup

Appendix F Table 2 Trials Pending Assessment

Investigator, study name | Location | Number of participants | Intervention | Outcomes | 2010 Status
Dr. Nabila El Bassel174 Project Eban Health Promotion Intervention | Columbia University, Emory University, University of California at Los Angeles, and the University of Pennsylvania | -- | Counseling African American couples on healthful behaviors including physical activity, healthful dietary practices, ceasing cigarette smoking and alcohol abuse, and practicing early detection and screening behaviors | -- | Outcomes of interest not yet published
Dr. Masanori Munakata175 Japanese study to organize proper lifestyle modifications for metabolic syndrome (J- STOP-MetS 2) | Japan | 2000 | Individualized guidance for life style modification | Body weight, waist circumference, body composition, blood pressure, arterial stiffness, fasting blood | Outcomes of interest not yet published
Dr. Iris Groeneveld176 The Health Under Construction Study | The Netherlands | 692 | Counseling to increase physical activity and improve dietary behavior and/or smoking cessation | Behavior change, body mass index, systolic and diastolic blood pressure, total and HDL blood cholesterol, Hba 1 c and cardio-respiratory fitness | Outcomes of interest not yet published
Dr. Hilde van Keulen177 Vitalum study | The Netherlands | 2881 | Print and telephone counseling for physical activity and nutrition behavior | Behavior change, saturated fat intake, health-related quality of life, body mass index, and cognitive behavioral determinants | Outcomes of interest not yet published
Dr. Karen Hosper178 Exercise on Prescription | The Netherlands | 360 | Weekly supervised exercise sessions during 20 weeks | Minutes of self-reported physical activity per week, wellbeing, perceived health, fitness, body size, use of primary health care | Planned closing date December 2010
Dr. Maria Gine-Garriga179 | Spain | 424 | Two, 60-minute physical activity sessions per week for 12 weeks | Health-related quality of life, physical activity stage of change, level of physical activity, change in perception of health, level of social support for the physical activity practice, control based on analysis | Not yet recruiting, estimated completion December 2010
Dr. Claire F. Fitzsimons180 Walking for Wellbeing in the West | Scotland | 79 | Pedometer-based walking program in combination with a physical activity consultation | Pedometer step counts, physical activity recall, stage of change, mood, quality of life, body composition, blood pressure, heart rate, total cholesterol, HDL cholesterol, insulin and glucose, circulating measures of inflammatory markers, perceived environmental barriers or facilitators to activity, social context, cost-effectiveness | Trial completed, 12-week outcomes published, awaiting full length of followup
Dr. Corinne Voils 181 | Durham, NC | 250 couples | Monthly telephone-based intervention administered to couples to lower above-goal LDL through medication adherence, diet, exercise, and patient- physician communication. | LDL, dietary and physical activity behavior. | Trial completion expected August 2010