# Meta-Analysis Details

For trials with multiple intervention arms, we combined intervention arms when the interventions were in the same intensity category, and analyzed the arms separately if they fell into different intensity categories. We used the following formulae to calculate combined means and standard deviations:154

Mean_combined_ = N_1_ M_1_ + N_2_ M_2_ / N_1_ + N_2_ SD_combined_ = sqrt((( N_1_ - 1 ) SD_1_^2^ + ( N_2_ - 1 ) SD_2_^2^ + (N_1_ N_2_)/(N_1_ + N_2_) ( M_1_^2^ + M_2_^2^ - 2 M_1_ M_2_ ))/(N_1_ + N_2_ - 1))

All but one of the outcomes we examined were continuous, and we analyzed the change from baseline in all of these cases, using random effects models. If both adjusted and unadjusted change from baseline were reported in a trial, we selected the adjusted estimate. We used standard calculations to convert standard errors and 95% confidence intervals to standard deviations:

SD_mean_ = SE_mean_ · sqrt ( n ) or SD_mean_ = ( CI_upper_ - CI_Lower_ ) * sqrt ( n ) / 3.29

If only baseline and followup values were reported, we calculated the crude mean change by subtracting the baseline mean from the follow-up mean for each group, and estimated the standard deviation using the following formula:

SD_change_ = Sqrt ( SD^2^_base_ + SD^2^_post_ - 2 * SD_base_ * SD_post_ * r_base , post_ )

In order to use this formula, we estimated the correlation between baseline and followup for each outcome. To do this, we examined studies that reported mean change as well as baseline and followup means and used the formula above to determine the correlations in their samples. These studies were quite variable in the resulting correlations, the time of followup, the quality of the study, and the number of estimates we were able to find. Because of this variability both in quality of the estimate and the absolute value of the correlations, we grouped like outcomes and used what we believed to be reasonable, somewhat conservative (lower) values for that set of outcomes. We assigned larger discrepancies between intervention and control group estimates for behavioral variables than the intermediate health outcomes, since we reasoned that behavior would be more likely to be affected by the interventions. See Appendix E Table 1 for the final values we chose.

Appendix E Table 1 Meta-Analysis Correlations

Outcome (treatment group) | Range of correlations in identified publications (number of estimates found)^*^ | Correlation used in data calculations for meta-analysis
Adiposity (CG) | 0.98–0.99 (2) | 0.90
Adiposity (IG) | 0.97–0.98 (2) | 0.90
Systolic BP (CG) | 0.57–0.82 (2) | 0.65
Systolic BP (IG) | 0.64–0.77 (2) | 0.60
Diastolic BP (CG) | 0.48–0.68 (2) | 0.65
Diastolic BP (IG) | 0.58–0.64 (2) | 0.60
Total Cholesterol (CG) | 0.44–0.83 (3) | 0.65
Total Cholesterol (IG) | 0.39–0.89 (4) | 0.60
High-Density Lipoproteins (CG) | 0.50–0.91 (3) | 0.75
High-Density Lipoproteins (IG) | 0.50–0.90 (4) | 0.70
Low-Density Lipoproteins (CG) | 0.67–0.88 (3) | 0.65
Low-Density Lipoproteins (IG) | 0.68–0.92 (4) | 0.60
Triglycerides (CG) | (none found) | 0.65
Triglycerides (IG) | (none found) | 0.60
Glucose (CG) | (none found) | 0.65
Glucose (IG) | (none found) | 0.60
Total Energy (CG) | 0.49–0.60 (2) | 0.60
Total Energy (IG) | 0.48–0.71 (2) | 0.50
Percent Fat/Saturated Fat (CG) | 0.27–0.55 (3) | 0.50
Percent Fat/Saturated Fat (IG) | 0.11–0.74 (5) | 0.40
Fiber (CG) | 0.46–0.84 (2) | 0.50
Fiber (IG) | 0.29–0.60 (3) | 0.40
Fruits and Vegetables (CG) | 0.73–0.75 (2) | 0.70
Fruits and Vegetables (IG) | 0.56–0.68 (3) | 0.55
Urinary Sodium (CG) | (none found) | 0.50
Urinary Sodium (IG) | (none found) | 0.40
Self-reported physical activity (CG) | 0.28–0.96 (4) 0.28–0.33 (3) | 0.25
Self-reported physical activity (IG) | 0.03–0.92 (10) 0.03–0.27 (9) | 0.10
Fitness (CG) | (none found) | 0.25
Fitness (IG) | (none found) | 0.10

* Estimates reported in trials included in the review

One test of the accuracy of our estimates is whether the statistical significance of the difference in our calculated change scores was generally consistent with the statistical tests run by the authors on the unadjusted baseline and follow-up means. Differences may suggest a mismatch between our estimated correlations and the study sample. We found this to have occurred only rarely, and when we tested higher (less conservative) correlations that were still in the range of our studies, these differences persisted. We therefore, concluded that our estimates were adequate.

We converted to common metrics for ease of interpretation of the meta-analysis. See Table 1 for the conversion factors we used.

Table 1 Conversion Factors

Measure | Original Metric | Final Metric | Conversion Factor
Total Cholesterol | mg/dl | mmol/l | 38.67
High-Density Lipoproteins | mg/dl | mmol/l | 38.67
Low-Density Lipoproteins | mg/dl | mmol/l | 38.67
Triglycerides | mg/dl | mmol/l | 88.57
Glucose | mg/dl | mmol/l | 18.0
Energy | kJ | kcal | 4.184
Weight | pounds | kg | 2.2

Data Substitutions. In one case,59 we used the median to estimate the mean, and 1.35 times the interquartile range to estimate the standard deviation.154 We only did this in the one case where the interquartile range was relatively symmetrical around the median and did not appear to have marked ceiling or floor effect. In one case,127 the standard deviation of the triglycerides in the control group at baseline was approximately five times larger than all other standard deviations, so we assume that was a typo and substituted baseline intervention group standard deviation instead.

Studies missing standard deviations at followup were examined to see if a standard deviation from another time point could be substituted. Acknowledging that this was likely a conservative substitution (since baseline standard deviations tend to be large than standard deviation of change), substitution of standard deviations was allowed in three cases.68,83,94

The only non-continuous outcome was the proportion of people meeting recommended level physical activity. We calculated a relative risk and its standard error using the raw numbers reported from each study and combined using a random effects model.155,156 One study reported an odds ratio rather than raw data or a relative risk,60 so we also ran a meta-analysis model that calculated and analyzed odds ratios in order to see if this study was consistent with those providing raw data. We also ran a meta-analysis model that calculated and analyzed absolute risk difference. We then used the estimated absolute risk difference to calculate the number needed to treat to get one more person to meet recommended levels of physical activity using the formula 1/absolute risk difference.

For studies with clustered randomization, we used the reported estimate if the study reported an estimate adjusted for clustering effect. Three studies used clustered randomization, but did not report outcomes that adjusted for clustering.32,36,52 We adjusted for clustering effect by multiplying the standard deviation by the square root of the design effect. Here, design effect = 1+(m-1), where m is the average cluster size and ρ is the intracluster correlation coefficient. We assumed ρ to be 0.05 for all three studies, which clustered at the level of the physician or clinic.

We ran a series of meta-regression to examine the effects of measurement, population, setting, and other study characteristics on effect size. To do this, we included a single factor of interest in each meta-regression model, controlling for intervention intensity, intervention target, risk status of the sample, and volunteer status of sample (whether participants were recruited through screening or other outreach, vs. participants proactively volunteering for the study). We selected these four control variables a priori on the basis of clinical judgment.

In this way we explored sample characteristics (percent male, percent non-white, baseline BMI), design characteristics (months of followup, whether the trial was conducted in the U.S., whether the sample was selected from a primary care setting or among health plan enrollees, whether the study targeted older adults, overall methodological quality of the study), and other characteristics (year published, degree of calculation and/or estimation needed to use a study’s data in the meta-analysis (0=none, 1=direct calculation (e.g. confidence interval to standard deviation), 2=some estimate required (e.g., calculating standard deviation of change from baseline and followup scores, or calculating combined effects from two groups reported separately), 3=some judgment involved (e.g., using baseline standard deviation to estimate followup standard deviation))). To explore the effects of using different measures on self-reported physical activity, fat intake, and fruit-and-vegetable intake, we grouped like measures and then ran adjusted meta-regressions using measure type to predict the effect size. Two-level variables were entered as 1/0 dummy variables and 3-level variables were converted to two 1/0 dummy variables with reference groups selected on the basis of interpretability of results.