# Excluded Studies

Appendix D Table 1 Healthful Diet Studies Excluded From the Review for Key Questions 1–3

Reference | Reason for exclusion
Aberegg, Scott K. and Majure, David T. “Low-Fat Dietary Pattern and Risk of Cardiovascular Disease: The Women’s Health Initiative Randomized Controlled Dietary Modification Trial”: Comment. JAMA: Journal of the American Medical Association 296[3], 280. 2006. | No relevant outcomes
Alli C, Avanzini F, Bettelli G et al. Feasibility of a long-term low-sodium diet in mild hypertension. J Hum Hypertens. 1992;6:281–286. | Population > 50% hypertension or dyslipidemia
Ammerman AS, Keyserling TC, Atwood JR, Hosking JD, Zayed H, Krasny C. A randomized controlled trial of a public health nurse directed treatment program for rural patients with high blood cholesterol. Prev Med. 2003;36:340–351. | Population > 50% hypertension or dyslipidemia
Anderson, Cheryl A. M. and Appell, Lawrence J. Dietary Modification and CVD Prevention: A Matter of Fat. [References]. JAMA: Journal of the American Medical Association 295[6], 693–695. 2006. | No relevant outcomes
Anderson JV, Bybee DI, Brown RM et al. 5 a day fruit and vegetable intervention improves consumption in a low income population. Journal of the American Dietetic Association. 2001;101:195–202. | Less than 6 months of followup
Anderssen S, Holme I, Urdal P, Hjermann I. Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4:343–349. | Population > 50% hypertension or dyslipidemia
Anderssen SA, Hjermann I, Urdal P, Torjesen PA, Holme I. Improved carbohydrate metabolism after physical training and dietary intervention in individuals with the “atherothrombogenic syndrome’. Oslo Diet and Exercise Study (ODES). A randomized trial. J Intern Med. 1996;240:203–209. | Population > 50% hypertension or dyslipidemia
Anderssen SA, Carroll S, Urdal P, Holme I. Combined diet and exercise intervention reverses the metabolic syndrome in middle-aged males: results from the Oslo Diet and Exercise Study. Scandinavian Journal of Medicine & Science in Sports. 2007;17:687–695. | Population > 50% hypertension or dyslipidemia
Anderssen SA, Haaland A Hjerman I Urdal P Gjesdal K Holme I. Oslo diet and exercise study: a one year randomized intervention trial. Efect on Haemostatic variables and other coronary risk factors. Nutrition, Metabolism & Cardiovascular Diseases. 1995;5:189–200. | Population > 50% hypertension or dyslipidemia
Appel LJ, Hebert PR, Cohen JD et al. Baseline characteristics of participants in phase II of the Trials of Hypertension Prevention (TOHP II). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5:149–155. | No relevant outcomes
Appel LJ, Champagne CM, Harsha DW et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289:2083–2093. | Comparative-effectiveness
Appel LJ, Espeland M, Whelton PK et al. Trial of Nonpharmacologic Intervention in the Elderly (TONE). Design and rationale of a blood pressure control trial. Ann Epidemiol. 1995;5:119–129. | Population > 50% hypertension or dyslipidemia
Appel LJ, Espeland MA, Easter L, Wilson AC, Folmar S, Lacy CR. Effects of reduced sodium intake on hypertension control in older individuals: results from the Trial of Nonpharmacologic Interventions in the Elderly (TONE). Arch Intern Med. 2001;161:685–693. | Population > 50% hypertension or dyslipidemia
Applegate WB, Miller ST, Elam JT et al. Nonpharmacologic intervention to reduce blood pressure in older patients with mild hypertension. Arch Intern Med. 1992;152:1162–1166. | Population > 50% hypertension or dyslipidemia
Armitage CJ, Conner M. Efficacy of a minimal intervention to reduce fat intake. Social Science & Medicine. 2001;52:1517–1524. | Less than 6 months of followup
Armitage, Christopher J. Effects of an implementation intention-based intervention on fruit consumption. Psychology & Health. 2007;22(8):917–928. 2007. | Less than 6 months of followup
Arroll B, Beaglehole R. Salt restriction and physical activity in treated hypertensives. N Z Med J. 1995;108:266–268. | Population > 50% hypertension or dyslipidemia
Bahnson JL, Whelton PK, Appel LJ et al. Baseline characteristics of randomized participants in the Trial of Nonpharmacologic Intervention in the Elderly (TONE). Disease Management and Clinical Outcomes. 1997;1:61–68. | Population > 50% hypertension or dyslipidemia
Bakx JC, Stafleu A, Van Staveren WA, Van den Hoogen HJ, van WC. Long-term effect of nutritional counseling: a study in family medicine. Am J Clin Nutr. 1997;65:1946S–1950S. | Population > 50% hypertension or dyslipidemia
Barclay C, Procter KL, Glendenning R, Marsh P, Freeman J, Mathers N. Can type 2 diabetes be prevented in UK general practice? A lifestyle-change feasibility study (ISAIAH). Br J Gen Pract. 2008;58:541–547. | Intervention involves supervised physical activity or medications
Beckmann SL, Os I, Kjeldsen SE, Eide IK, Westheim AS, Hjermann I. Effect of dietary counselling on blood pressure and arterial plasma catecholamines in primary hypertension. Am J Hypertens. 1995;8:704–711. | Population > 50% hypertension or dyslipidemia
Beresford SA, Farmer EM, Feingold L, Graves KL, Sumner SK, Baker RM. Evaluation of a self-help dietary intervention in a primary care setting. Am J Public Health. 1992;82:79–84. | Less than 6 months of followup
Blaufox MD, Lee HB, Davis B, Oberman A, Wassertheil-Smoller S, Langford H. Renin predicts diastolic blood pressure response to nonpharmacologic and pharmacologic therapy. JAMA. 1992;267:1221–1225. | Population > 50% hypertension or dyslipidemia
Block G, Wakimoto P, Metz D et al. A randomized trial of the Little by Little CD-ROM: demonstrated effectiveness in increasing fruit and vegetable intake in a low-income population. Preventing Chronic Disease. 2004;1:A08. | Less than 6 months of followup
Bloemberg BP, Kromhout D, Goddijn HE, Jansen A, Obermann-de Boer GL. The impact of the Guidelines for a Healthy Diet of The Netherlands Nutrition Council on total and high density lipoprotein cholesterol in hypercholesterolemic free-living men. Am J Epidemiol. 1991;134:39–48. | Population > 50% hypertension or dyslipidemia
Blumenthal JA, Sherwood A, Gullette EC et al. Exercise and weight loss reduce blood pressure in men and women with mild hypertension: effects on cardiovascular, metabolic, and hemodynamic functioning. Arch Intern Med. 2000;160:1947–1958. | Population > 50% hypertension or dyslipidemia
Bo S, Ciccone G, Baldi C et al. Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med. 2007;22:1695–1703. | Population > 50% hypertension or dyslipidemia
Bowen D, Ehret C, Pedersen M et al. Results of an adjunct dietary intervention program in the Women’s Health Initiative. Journal of the American Dietetic Association. 2002;102:1631–1637. | No relevant outcomes
Bowen DJ, Beresford SAA, Christensen CL, Kuniyuk AA, McLerran D, Feng Z, Hart A Jr, Tinker L, Campbell M, Satia J. Effects of a multilevel dietary intervention in religious organizations. Am.J.Health Promot. 24(1):15–22, 2009. | Setting not primary care or generalizable to primary care
Boyd NF, Cousins M, Beaton M et al. Clinical trial of low-fat, high-carbohydrate diet in subjects with mammographic dysplasia: report of early outcomes. J Natl Cancer Inst. 1988;80:1244–1248. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Boyd NF, Cousins M, Beaton M, Kriukov V, Lockwood G, Tritchler D. Quantitative changes in dietary fat intake and serum cholesterol in women: results from a randomized, controlled trial. Am J Clin Nutr. 1990;52:470–476. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Boyd NF, Martin LJ, Beaton M, Cousins M, Kriukov V. Long-term effects of participation in a randomized trial of a low-fat, high-carbohydrate diet. Cancer Epidemiol Biomarkers Prev. 1996;5:217–222. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Brekke HK, Sunesson A, Axelsen M, Lenner RA. Attitudes and barriers to dietary advice aimed at reducing risk of type 2 diabetes in first-degree relatives of patients with type 2 diabetes. Journal of Human Nutrition & Dietetics. 2004;17:513–521. | No relevant outcomes
British family heart study: its design and method, and prevalence of cardiovascular risk factors. Family heart study group. Br J Gen Pract. 1994;44:62–67. | Other quality issues
Bruckert E, Giral P, Paillard F et al. Effect of an educational program (PEGASE) on cardiovascular risk in hypercholesterolaemic patients. Cardiovascular Drugs & Therapy. 2008;22:495–505. | Population > 50% hypertension or dyslipidemia
Brug J, Glanz K, Van AP, Kok G, van Breukelen GJ. The impact of computer-tailored feedback and iterative feedback on fat, fruit, and vegetable intake. Health Educ Behav. 1998;25:517–531. | Less than 6 months of followup
Burke LE, Dunbar-Jacob J, Orchard TJ, Sereika SM. Improving adherence to a cholesterol-lowering diet: a behavioral intervention study. Patient Education & Counseling. 2005;57:134–142. | Population > 50% hypertension or dyslipidemia
Burke V, Beilin LJ, Cutt HE, Mansour J, Mori TA. Moderators and mediators of behaviour change in a lifestyle program for treated hypertensives: a randomized controlled trial (ADAPT). Health Education Research. 2008;23:583–591. | Population > 50% hypertension or dyslipidemia
Burke V, Giangiulio N, Gillam HF, Beilin LJ, Houghton S, Milligan RA. Health promotion in couples adapting to a shared lifestyle. Health Educ Res. 1999;14:269–288. | Less than 6 months of followup
Burke V, Giangiulio N, Gillam HF, Beilin LJ, Houghton S. Physical activity and nutrition programs for couples: a randomized controlled trial. Journal of Clinical Epidemiology. 2003;56:421–432. | High or differential attrition
Burke V, Mori TA, Giangiulio N et al. An innovative program for changing health behaviours. Asia Pac J Clin Nutr. 2002;11 Suppl 3:S586–S597. | High or differential attrition
Burr ML, Fehily AM. Fatty fish and heart disease: a randomized controlled trial. World Rev Nutr Diet. 1991;66:306–312. | Limited to children and adolescents, parents (if change intended for children), persons with any acute disease or symptomatic disease, persons with known coronary heart disease (or angina) or peripheral vascular disease or diabetes, pregnant women, institutionalized persons, or persons with SPMI or cognitive impairment
Caggiula AW, Christakis G, Farrand M et al. The multiple risk intervention trial (MRFIT). IV. Intervention on blood lipids. Prev Med. 1981;10:443–475. | Population > 50% hypertension or dyslipidemia
Caggiula AW, Watson JE, Kuller LH et al. Cholesterol-lowering intervention program. Effect of the step I diet in community office practices. Arch Intern Med. 1996;156:1205–1213. | Comparative-effectiveness
Chapman J, Armitage CJ, Norman P. Comparing implementation intention interventions in relation to young adults’ intake of fruit and vegetables. Psychology & Health 24(3):317–332, 2009. | Less than 6 months of followup
Clark M, Ghandour G, Miller NH, Taylor CB, Bandura A, DeBusk RF. Development and evaluation of a computer-based system for dietary management of hyperlipidemia. J Am Diet Assoc. 1997;97:146–150. | Not an allowable study design
Cook NR, Kumanyika SK, Cutler JA. Effect of change in sodium excretion on change in blood pressure corrected for measurement error. The Trials of Hypertension Prevention, Phase I. Am J Epidemiol. 1998;148:431–444. | No relevant outcomes
Cook NR, Obarzanek E, Cutler JA et al. Joint effects of sodium and potassium intake on subsequent cardiovascular disease: the Trials of Hypertension Prevention follow-up study. Arch Intern Med. 2009;169:32–40 | No relevant outcomes
Coulter A, Fowler G, Fuller A et al. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study. British Medical Journal. 1995;310:1099–1104. | Other quality issues
Crandall J, Schade D, Ma Y et al. The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. 2006;61:1075–1081. | Comparative-effectiveness
Cutler JA, Neaton JD, Hulley SB, Kuller L, Paul O, Stamler J. Coronary heart disease and all-causes mortality in the Multiple Risk Factor Intervention Trial: subgroup findings and comparisons with other trials. Prev Med. 1985;14:293–311. | Intervention involves supervised physical activity or medications
Davey SG, Bracha Y, Svendsen KH et al. Incidence of type 2 diabetes in the randomized multiple risk factor intervention trial. Ann Intern Med. 2005;142:313–322. | Population > 50% hypertension or dyslipidemia
Davis BR, Oberman A, Blaufox MD et al. Lack of effectiveness of a low-sodium/high-potassium diet in reducing antihypertensive medication requirements in overweight persons with mild hypertension. TAIM Research Group. Trial of Antihypertensive Interventions and Management. Am J Hypertens. 1994;7:926–932. | Population > 50% hypertension or dyslipidemia
de Vries, H., Kremers, S. P. J., Smeets, T., Brug, J., and Eijmael, K. The effectiveness of tailored feedback and action plans in an intervention addressing multiple health behaviors. Am J of Health Promot. 2008;22(6):417–425. | Comparative-effectiveness
Delahanty LM, Sonnenberg LM, Hayden D, Nathan DM. Clinical and cost outcomes of medical nutrition therapy for hypercholesterolemia: a controlled trial. Journal of the American Dietetic Association. 2001;101:1012–1023. | Population > 50% hypertension or dyslipidemia
Djuric Z, Vanloon G, Radakovich K, Dilaura NM, Heilbrun LK, Sen A. Design of a Mediterranean exchange list diet implemented by telephone counseling. Journal of the American Dietetic Association. 2008;108:2059–2065. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Dolecek TA, Milas NC, Van Horn LV et al. A long-term nutrition intervention experience: lipid responses and dietary adherence patterns in the Multiple Risk Factor Intervention Trial. J Am Diet Assoc. 1986;86:752–758. | Intervention involves supervised physical activity or medications
Dubbert PM, Cushman WC, Meydrech EF, Rowland AK, Maury P. Effects of dietary instruction and sodium excretion feedback in hypertension clinic patients. Behav Ther. 1995;26:721–732. | Population > 50% hypertension or dyslipidemia
Dutton GR, Napolitano MA, Whiteley JA, Marcus BH. Is physical activity a gateway behavior for diet? Findings from a physical activity trial. Prev Med. 2008;46:216–221. | Not one of specified interventions
Dzator JA, Hendrie D, Burke V et al. A randomized trial of interactive group sessions achieved greater improvements in nutrition and physical activity at a tiny increase in cost. Journal of Clinical Epidemiology. 2004;57:610–619. | High or differential attrition
Eakin E, Reeves M, Lawler S et al. Telephone counseling for physical activity and diet in primary care patients. Am J Prev Med. 2009;36:142–149. | Population > 50% hypertension or dyslipidemia
Effectiveness of health checks conducted by nurses in primary care: results of the OXCHECK study after one year. Imperial Cancer Research Fund OXCHECK Study Group. BMJ. 1994;308:308–312. | Other quality issues
Elder JP, Williams SJ, Drew JA, Wright BL, Boulan TE. Longitudinal effects of preventive services on health behaviors among an elderly cohort. Am J Prev Med. 1995;11:354–359. | High or differential attrition
Ellingsen I, Hjerkinn EM, Arnesen H, Seljeflot I, Hjermann I, Tonstad S. Follow-up of diet and cardiovascular risk factors 20 years after cessation of intervention in the Oslo Diet and Antismoking Study. European Journal of Clinical Nutrition. 2006;60:378–385. | Population > 50% hypertension or dyslipidemia
Ellingsen I, Hjermann I, Abdelnoor M, Hjerkinn EM, Tonstad S. Dietary and antismoking advice and ischemic heart disease mortality in men with normal or high fasting triacylglycerol concentrations: a 23-y follow-up study. The American journal of clinical nutrition. 2003;78:935–940. | Population > 50% hypertension or dyslipidemia
Ellsworth DL, O’Dowd SC, Salami B et al. Intensive lifestyle modification: impact on cardiovascular disease risk factors in subjects with and without clinical cardiovascular disease. Preventive Cardiology. 2004;7:168– 175. | Not an allowable study design
Elmer PJ, Obarzanek E, Vollmer WM et al. Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial (summary for patients in Ann Intern Med. 2006 Apr 4;144(7):I27); Ann Intern Med. 2006;144:485–495. | Comparative-effectiveness
Emmons, Karen M., Stoddard, Ann M., Fletcher, Robert, Gutheil, Caitlin, Suarez, Elizabeth Gonzalez, Lobb, Rebecca, Weeks, Jane, and Bigby, Judy Anne. Cancer Prevention Among Working Class, Multiethnic Adults: Results of the Healthy Directions--Health Centers Study. Am J Pub Health. 2005; 95(7):1200–1205. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Eriksson J, Lindstrom J, Valle T et al. Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42:793–801. | Intervention involves supervised physical activity or medications
Espeland MA, Whelton PK, Kostis JB et al. Predictors and mediators of successful long-term withdrawal from antihypertensive medications. TONE Cooperative Research Group. Trial of Nonpharmacologic Interventions in the Elderly. Arch Fam Med. 1999;8:228–236. | Population > 50% hypertension or dyslipidemia
Evans AT, Rogers LQ, Peden JG, Jr. et al. Teaching dietary counseling skills to residents: patient and physician outcomes. The CADRE Study Group. Am J Prev Med. 1996;12:259–265. | Population > 50% hypertension or dyslipidemia
Fagerberg B, Wikstrand J, Berglund G, Samuelsson O, Agewall S. Mortality rates in treated hypertensive men with additional risk factors are high but can be reduced: a randomized intervention study. Am J Hypertens. 1998;11:14–22. | Intervention involves supervised physical activity or medications
Ferrer RL, Mody-Bailey P, Jaen CR, Gott S, Araujo S. A medical assistant-based program to promote healthy behaviors in primary care. Ann Fam Med. 2009;7:504–512. | High or differential attrition
Gaston MH, Porter GK, Thomas VG. Prime Time Sister Circles: evaluating a gender-specific, culturally relevant health intervention to decrease major risk factors in mid-life African-American women. J Natl Med Assoc. 2007;99:428–438. | Setting not primary care or generalizable to primary care
Gorbach SL, Morrill-LaBrode A, Woods MN et al. Changes in food patterns during a low-fat dietary intervention in women. J Am Diet Assoc. 1990;90:802–809. | Population > 50% hypertension or dyslipidemia
Halbert JA, Silagy CA, Finucane PM, Withers RT, Hamdorf PA. Physical activity and cardiovascular risk factors: effect of advice from an exercise specialist in Australian general practice. Med J Aust. 2000;173:84–87. | No relevant outcomes
Harari D, Iliffe S, Kharicha K et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing. 2008;37:565–571. | Does not focus on counseling interventions
Harting J, Van AP, van LP et al. Effects of health counseling on behavioural risk factors in a high-risk cardiology outpatient population: a randomized clinical trial. European Journal of Cardiovascular Prevention & Rehabilitation. 2006;13:214–221. | Limited to children and adolescents, parents (if change intended for children), persons with any acute disease or symptomatic disease, persons with known coronary heart disease (or angina) or peripheral vascular disease or diabetes, pregnant women, institutionalized persons, or persons with SPMI or cognitive impairment
Havas S, Anliker J, Damron D, Langenberg P, Ballesteros M, Feldman R. Final results of the Maryland WIC 5-A-Day Promotion Program. Am J Public Health. 1998;88:1161–1167. | Not one of specified interventions
He J, Whelton PK, Appel LJ, Charleston J, Klag MJ. Long-term effects of weight loss and dietary sodium reduction on incidence of hypertension. Hypertension. 2000;35:544–549. | No relevant outcomes
Heller RF, Walker RJ, Boyle CA, O’Connell DL, Rusakaniko S, Dobson AJ. A randomised controlled trial of a dietary advice program for relatives of heart attack victims. Med J Aust. 1994;161:529–531. | High or differential attrition
Henderson MM, Kushi LH, Thompson DJ et al. Feasibility of a randomized trial of a low-fat diet for the prevention of breast cancer: dietary compliance in the Women’s Health Trial Vanguard Study. Prev Med. 1990;19:115–133. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Henkin Y, Shai I, Zuk R et al. Dietary treatment of hypercholesterolemia: do dietitians do it better? A randomized, controlled trial. Am J Med. 2000;109:549–555. | Comparative-effectiveness
Hernan WH, Brandle M, Zhang P et al. Costs associated with the primary prevention of type 2 diabetes mellitus in the diabetes prevention program. Diabetes Care. 2003;26:36–47. | Comparative-effectiveness
Hoffmeister H, Mensink GB, Stolzenberg H et al. Reduction of coronary heart disease risk factors in the German cardiovascular prevention study. Prev Med. 1996;25:135–145. | Not an allowable study design
Holme I, Hostmark AT, Anderssen SA. ApoB but not LDL-cholesterol is reduced by exercise training in overweight healthy men. Results from the 1-year randomized Oslo Diet and Exercise Study. Journal of Internal Medicine. 2007;262:235–243. | Population > 50% hypertension or dyslipidemia
Holtrop JS, Dosh SA, Torres T, Thum YM. The community health educator referral liaison (CHERL): a primary care practice role for promoting healthy behaviors. Am J Prev Med. 2008;35:Suppl-72. | Comparative-effectiveness
Hsieh YC, Hung CT, Lien LM, Bai CH, Chen WH, Yeh CY, Chen YH, Hsieh FI, Chiu HC, Chiou HY, Hsu CY. A significant decrease in blood pressure through a family-based nutrition health education programme among community residents in Taiwan. Public Health Nutrition 12 (4):570–577, 2009. | Quality- poor reporting
Huxley RR, Lean M, Crozier A, John JH, Neil HA, Oxford Fruit and Vegetable Study Group. Effect of dietary advice to increase fruit and vegetable consumption on plasma flavonol concentrations: results from a randomised controlled intervention trial. Journal of Epidemiology & Community Health. 2004;58:288–289. | No relevant outcomes
Hyman DJ, Herd JA, Ho KS, Dunn JK, Gregory KA. Maintenance of cholesterol reduction using automated telephone calls. Am J Prev Med. 1996;12:129–133. | Population > 50% hypertension or dyslipidemia
Hyman DJ, Ho KS, Dunn JK, Simons-Morton D. Dietary intervention for cholesterol reduction in public clinic patients. Am J Prev Med. 1998;15:139–145. | Population > 50% hypertension or dyslipidemia
Hyman DJ, Pavlik VN, Taylor WC, Goodrick GK, Moye L. Simultaneous vs sequential counseling for multiple behavior change. Arch Intern Med. 2007;167:1152–1158. | Population > 50% hypertension or dyslipidemia
Inoue S, Odagiri Y, Wakui S et al. Randomized controlled trial to evaluate the effect of a physical activity intervention program based on behavioral medicine. Zasshi/Tokyo Ika Daigaku. 2003;61:154–165. | Population > 50% hypertension or dyslipidemia
Insull W, Jr., Henderson MM, Prentice RL et al. Results of a randomized feasibility study of a low-fat diet. Arch Intern Med. 1990;150:421–427. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Ives DG, Kuller LH, Traven ND. Use and outcomes of a cholesterol-lowering intervention for rural elderly subjects. Am J Prev Med. 1993;9:274–281. | Population > 50% hypertension or dyslipidemia
Jacobs AD, Ammerman AS, Ennett ST et al. Effects of a tailored follow-up intervention on health behaviors, beliefs, and attitudes. Journal of Women’s Health. 2004;13:557–568. | Population > 50% hypertension or dyslipidemia
Jacobs DR, Jr., Sluik D, Rokling-Andersen MH, Anderssen SA, Drevon CA. Association of 1-y changes in diet pattern with cardiovascular disease risk factors and adipokines: results from the 1-y randomized Oslo Diet and Exercise Study. Am J Clin Nutr. 2009;89:509–517. | Population > 50% hypertension or dyslipidemia
Jalkanen L. The effect of a weight reduction program on cardiovascular risk factors among overweight hypertensives in primary health care. Scand J Soc Med. 1991;19:66–71. | Primary aim is weight loss
John JH, Yudkin PL, Neil HAW, Ziebland S. Does Stage of Change predict outcome in a primary care intervention to encourage an increase in fruit and vegetable consumption? Health Education Research. 2003;18:429–438. | No relevant outcomes
Johnston HJ, Jones M, Ridler-Dutton G, Spechler F, Stokes GS, Wyndham LE. Diet modification in lowering plasma cholesterol levels. A randomised trial of three types of intervention. Med J Aust. 1995;162:524–526. | Population > 50% hypertension or dyslipidemia
Jorgensen T, Borch-Johnsen K, Thomsen TF, Ibsen H, Glumer C, Pisinger C. A randomized non- pharmacological intervention study for prevention of ischaemic heart disease: baseline results Inter99. European Journal of Cardiovascular Prevention & Rehabilitation. 2003;10:377–386. | Population > 50% hypertension or dyslipidemia
Jula A, Ronnemaa T, Rastas M, Karvetti RL, Maki J. Long-term nopharmacological treatment for mild to moderate hypertension. J Intern Med. 1990;227:413–421. | Population > 50% hypertension or dyslipidemia
Jula AM, Karanko HM. Effects on left ventricular hypertrophy of long-term nonpharmacological treatment with sodium restriction in mild-to-moderate essential hypertension. Circulation. 1994;89:1023–1031. | Population > 50% hypertension or dyslipidemia
Kastarinen MJ, Puska PM, Korhonen MH et al. Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20:2505–2512. | Population > 50% hypertension or dyslipidemia
Kawano M, Shono N, Yoshimura T, Yamaguchi M, Hirano T, Hisatomi A. Improved cardio-respiratory fitness correlates with changes in the number and size of small dense LDL: randomized controlled trial with exercise training and dietary instruction. Internal Medicine. 2009;48:25–32. | Intervention involves supervised physical activity or medications
Keller S, Donner-Banzhoff N, Kaluza G, Baum E, Basler HD. Improving physician-delivered counseling in a primary care setting: lessons from a failed attempt. Educ Health (Abingdon ). 2000;13:387–397. | High or differential attrition
Ketola E, Makela M, Klockars M. Individualised multifactorial lifestyle intervention trial for high-risk cardiovascular patients in primary care. Br J Gen Pract. 2001;51:291–294. | Population > 50% hypertension or dyslipidemia
Keyserling TC, Ammerman AS, Davis CE, Mok MC, Garrett J, Simpson R, Jr. A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6:135–145. | Population > 50% hypertension or dyslipidemia
Kinzel LS, Averbach FM, Clark KS et al. A high carbohydrate, low fat, hypocaloric eating pattern using functional foods along with increased physical activity in postmenopausal women decreases cardiovascular risk factors. Journal of the American Dietetic Association. 2004;104:31. | Comparative-effectiveness
Kjelsberg MO, Cutler JA, Dolecek TA. Brief description of the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65:191S–195S. | Intervention involves supervised physical activity or medications
Klem ML, Viteri JE, Wing RR. Primary prevention of weight gain for women aged 25-34: the acceptability of treatment formats. Int J Obes Relat Metab Disord. 2000;24:219–225. | High or differential attrition
Knowler WC, Barrett-Connor E, Fowler SE et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. New England Journal of Medicine. 2002;346:393–403. | Comparative-effectiveness
Knutsen SF, Knutsen R. The Tromso Survey: the Family Intervention study--the effect of intervention on some coronary risk factors and dietary habits, a 6-year follow-up. Prev Med. 1991;20:197–212. | Population > 50% hypertension or dyslipidemia
Koopman H, Spreeuwenberg C, Westerman RF, Donker AJ. Dietary treatment of patients with mild to moderate hypertension in a general practice: a pilot intervention study (2). Beyond three months. J Hum Hypertens. 1990;4:372–374. | Population > 50% hypertension or dyslipidemia
Korhonen MH, Litmanen H, Rauramaa R, Vaisanen SB, Niskanen L, Uusitupa M. Adherence to the salt restriction diet among people with mildly elevated blood pressure. Eur J Clin Nutr. 1999;53:880–885. | Population > 50% hypertension or dyslipidemia
Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Research & Clinical Practice. 2005;67:152–162. | Comparative-effectiveness
Kreuter MW, Strecher VJ. Do tailored behavior change messages enhance the effectiveness of health risk appraisal? Results from a randomized trial. Health Educ Res. 1996;11:97–105. | Does not focus on counseling interventions
Kreuter MW, Sugg-Skinner C, Holt CL et al. Cultural tailoring for mammography and fruit and vegetable intake among low-income African-American women in urban public health centers. Prev Med. 2005;41:53–62. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Kristal AR, Shattuck AL, Patterson RE. Differences in fat-related dietary patterns between black, Hispanic and White women: results from the Women’s Health Trial Feasibility Study in Minority Populations. Public Health Nutr. 1999;2:253–262. | No relevant outcomes
Kristal AR, White E, Shattuck AL et al. Long-term maintenance of a low-fat diet: durability of fat-related dietary habits in the Women’s Health Trial. J Am Diet Assoc. 1992;92:553–559. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Kuller LH, Kinzel LS, Pettee KK et al. Lifestyle intervention and coronary heart disease risk factor changes over 18 months in postmenopausal women: the Women On the Move through Activity and Nutrition (WOMAN study) clinical trial. Journal of Women’s Health. 2006;15:962–974. | Comparative-effectiveness
Kulzer B, Hermanns N, Gorges D, Schwarz P, Haak T. Prevention of diabetes self-management program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32:1143–1146. | Primary aim is weight loss
Langford HG, Davis BR, Blaufox D et al. Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. The TAIM Research Group. Hypertension. 1991;17:210–217. | Population > 50% hypertension or dyslipidemia
Leduc, C. P., Cherniak, D., and Faucher, J. Effectiveness of a group dietary intervention on hypercholesterolemia: a randomized, controlled clinical trial. Atherosclerosis 1994;109(1–2):149. | Poor reporting
Liao D, Asberry PJ, Shofer JB et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. 2002;25:1504–1510. | Comparative-effectiveness
Lichtenstein AH, Ausman LM, Jalbert SM et al. Efficacy of a Therapeutic Lifestyle Change/Step 2 diet in moderately hypercholesterolemic middle-aged and elderly female and male subjects. Journal of Lipid Research. 2002;43:264–273. | Not one of specified interventions
Lin, P. H., Appel, L. J., Funk, K., Craddick, S., Chen, C., Elmer, P., McBurnie, M. A., and Champagne, C. The PREMIER intervention helps participants follow the Dietary Approaches to Stop Hypertension dietary pattern and the current Dietary Reference Intakes recommendations. Journal of the American Dietetic Association. 2007;107(9):1541–1551. | Comparative-effectiveness
Lindholm LH, Ekbom T, Dash C, Eriksson M, Tibblin G, Schersten B. The impact of health care advice given in primary care on cardiovascular risk. CELL Study Group. BMJ. 1995;310:1105–1109. | Population > 50% hypertension or dyslipidemia
Lindholm LH, Ekbom T, Dash C, Isacsson A, Schersten B. Changes in cardiovascular risk factors by combined pharmacological and nonpharmacological strategies: the main results of the CELL Study. J Intern Med. 1996;240:13–22. | Population > 50% hypertension or dyslipidemia
Lindsey, Lisa L. M. The influence of persuasive messages on attitude and subjective norm: A test of the theory of reasoned action. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2004;64(8-A):2705. | Does not focus on counseling interventions
Lindström J, Eriksson JG, Valle TT et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. Journal of the American Society of Nephrology. 2003;14:S108–S113. | Intervention involves supervised physical activity or medications
Lindstrom J, Louheranta A, Mannelin M et al. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26:3230–3236. | Intervention involves supervised physical activity or medications
Lyons GK, Woodruff SI, Candelaria JI, Rupp JW, Elder JP. Effect of a nutrition intervention on macronutrient intake in a low English-proficient Hispanic sample. Am J Health Promot. 1997;11:371–374. | Less than 6 months of followup
Marcus AC, Heimendinger J, Wolfe P et al. A randomized trial of a brief intervention to increase fruit and vegetable intake: a replication study among callers to the CIS. Prev Med. 2001;33:204–216. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Marcus AC, Heimendinger J, Wolfe P et al. Increasing fruit and vegetable consumption among callers to the CIS: results from a randomized trial. Prev Med. 1998;27:S16–S28. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Marcus AC, Morra M, Rimer BK et al. A feasibility test of a brief educational intervention to increase fruit and vegetable consumption among callers to the Cancer Information Service. Prev Med. 1998;27:250–261. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Maruthur NM, Wang NY, Appel LJ. Lifestyle interventions reduce coronary heart disease risk: results from the PREMIER Trial. Circulation. 2009;119:2026–2031. | Comparative-effectiveness
Maskarinec G, Chan CL, Meng L, Franke AA, Cooney RV. Exploring the feasibility and effects of a high- fruit and -vegetable diet in healthy women. Cancer Epidemiol Biomarkers Prev. 1999;8:919–924. | Comparative-effectiveness
Mayer JA, Jermanovich A, Wright BL, Elder JP, Drew JA, Williams SJ. Changes in health behaviors of older adults: the San Diego Medicare Preventive Health Project. Prev Med. 1994;23:127–133. | Does not focus on counseling interventions
Mayer-Davis EJ, Sparks KC, Hirst K et al. Dietary intake in the diabetes prevention program cohort: baseline and 1-year post randomization. Annals of Epidemiology. 2004;14:763–772. | Comparative-effectiveness
McGowan MP, Joffe A, Duggan AK, McCay PS. Intervention in hypercholesterolemic college students: a pilot study. J Adolesc Health. 1994;15:155–162. | Comparative-effectiveness
McKeown-Eyssen G.E., Bright-See E, Bruce WR et al. A randomized trial of a low fat high fibre diet in the recurrence of colorectal polyps. Toronto Polyp Prevention Group. J Clin Epidemiol. 1994;47:525–536. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Meland E, Laerum E, Ulvik RJ. Effectiveness of two preventive interventions for coronary heart disease in primary care. Scand J Prim Health Care. 1997;15:57–64. | Population > 50% hypertension or dyslipidemia
Melanson KJ, Dell’Olio J, Carpenter MR, Angelopoulos TJ. Changes in multiple health outcomes at 12 and 24 weeks resulting from 12 weeks of exercise counseling with or without dietary counseling in obese adults. Nutrition. 2004;20:849–856. | Primary aim is weight loss
Mensink M, Blaak EE, Corpeleijn E, Saris WH, de Bruin TW, Feskens EJ. Lifestyle intervention according to general recommendations improves glucose tolerance. Obesity Research. 2003;11:1588–1596. | Intervention involves supervised physical activity or medications
Mensink, M., Feskens, E. J. M., Saris, W. H. M., de Bruin, T. W. A., and Blaak, E. E. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): Preliminary results after one year. International Journal of Obesity. 2003; 27(3):377–384. | Intervention involves supervised physical activity or medications
Milkereit J, Graves JS. Follow-up dietary counseling benefits attainment of intake goals for total fat, saturated fat, and fiber. J Am Diet Assoc. 1992;92:603–605. | Population > 50% hypertension or dyslipidemia
Molitch ME, Fujimoto W, Hamman RF, Knowler WC, Diabetes-Prevention-Program-Research-Group. The diabetes prevention program and its global implications. Journal of the American Society of Nephrology. 2003;14:S103–S107. | Comparative-effectiveness
Moy TF, Yanek LR, Raquen~o-JV et al. Dietary counseling for high blood cholesterol in families at risk of coronary disease. Preventive Cardiology. 2001;4:158–164. | Population > 50% hypertension or dyslipidemia
Muhlhauser I, Sawicki PT, Didjurgeit U, Jorgens V, Trampisch HJ, Berger M. Evaluation of a structured treatment and teaching programme on hypertension in general practice. Clin Exp Hypertens. 1993;15:125–142. | Population > 50% hypertension or dyslipidemia
Multiple risk factor intervention trial. Risk factor changes and mortality results. Multiple Risk Factor Intervention Trial Research Group. JAMA. 1982;248:1465–1477. | Population > 50% hypertension or dyslipidemia
Naslund GK, Fredrikson M, Hellenius ML, de FU. Effect of diet and physical exercise intervention programmes on coronary heart disease risk in smoking and non-smoking men in Sweden. J Epidemiol Community Health. 1996;50:131–136. | No relevant outcomes
Neaton JD, Broste S, Cohen L, Fishman EL, Kjelsberg MO, Schoenberger J. The multiple risk factor intervention trial (MRFIT). VII. A comparison of risk factor changes between the two study groups. Prev Med. 1981;10:519–543. | Population > 50% hypertension or dyslipidemia
Neil HA, Roe L, Godlee RJ et al. Randomised trial of lipid lowering dietary advice in general practice: the effects on serum lipids, lipoproteins, and antioxidants. BMJ. 1995;310:569–573. | Population > 50% hypertension or dyslipidemia
Neville, Leonie M., O’Hara, Blythe, and Milat, Andrew J. Computer-tailored dietary behaviour change interventions: A systematic review. Health Education Research 24[4], 699–720. 2009. | Not one of the allowable study designs
Nichols, G. Testing a culturally consistent behavioral outcomes strategy for cardiovascular disease risk reduction and prevention in low income African American women. Unpublished doctoral dissertation, Univ of Maryland. 1995. | Less than 6 months of followup
Nilsson PM, Lindholm LH, Schersten BF. Life style changes improve insulin resistance in hyperinsulinaemic subjects: a one-year intervention study of hypertensives and normotensives in Dalby. J Hypertens. 1992;10:1071–1078. | Population > 50% hypertension or dyslipidemia
Nitzke S, Kritsch K, Boeckner L et al. A stage-tailored multi-modal intervention increases fruit and vegetable intakes of low-income young adults. Am J Health Promot. 2007;22:6–14. | High or differential attrition
Norris SL, Zhang X, Avenell A et al. Long-term effectiveness of weight-loss interventions in adults with pre- diabetes: a review. Am J Prev Med. 2005;28:126–139. | Not an allowable study design
O’Halloran, Peggy, Lazovich, DeAnn, Patterson, Ruth E., Harnack, Lisa, French, Simone, Curry, Sue J., and Beresford, Shirley A. A. Effect of health lifestyle pattern on dietary change. American Journal of Health Promotion 16[1], 27–33. 2001. | No relevant outcomes
Oberman A, Wassertheil-Smoller S, Langford HG et al. Pharmacologic and nutritional treatment of mild hypertension: changes in cardiovascular risk status. Ann Intern Med. 1990;112:89–95. | Population > 50% hypertension or dyslipidemia
Ockene IS, Hebert JR, Ockene JK et al. Effect of physician-delivered nutrition counseling training and an office-support program on saturated fat intake, weight, and serum lipid measurements in a hyperlipidemic population: Worcester Area Trial for Counseling in Hyperlipidemia (WATCH). Arch Intern Med. 1999;159:725–731. | Population > 50% hypertension or dyslipidemia
Ockene IS, Hebert JR, Ockene JK, Merriam PA, Hurley TG, Saperia GM. Effect of training and a structured office practice on physician-delivered nutrition counseling: the Worcester-Area Trial for Counseling in Hyperlipidemia (WATCH). Am J Prev Med. 1996;12:252–258. | Population > 50% hypertension or dyslipidemia
ODES Investigators. The Oslo Diet and Exercise Study (ODES): design and objectives. Control Clin Trials. 1993;14:229–243. | Population > 50% hypertension or dyslipidemia
Oenema A, Brug J, Lechner L. Web-based tailored nutrition education: results of a randomized controlled trial. Health Education Research. 2001;16:647–660. | Less than 6 months of followup
Papadaki A, Scott JA. Follow-up of a web-based tailored intervention promoting the Mediterranean diet in Scotland. Patient Education & Counseling. 2008;73:256–263. | Comparative-effectiveness
Park A, Nitzke S, Kritsch K, Kattelmann K, White A, Boeckner L, Lohse B, Hoerr S, Greene G, and Zhang Z. Internet-based interventions have potential to affect short-term mediators and indicators of dietary behavior of young adults. Journal of Nutrition Education and Behavior 40[5], 288–297. 2008. | Comparative-effectiveness
Pereira, R. F. Franz M. J. Prevention and Treatment of Cardiovascular Disease in People With Diabetes Through Lifestyle Modification: Current Evidence-Based Recommendations. Diabetes Spectr. 2008;21:189–193. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Perkins-Porras L, Cappuccio FP, Rink E, Hilton S, McKay C, Steptoe A. Does the effect of behavioral counseling on fruit and vegetable intake vary with stage of readiness to change? Prev Med. 2005;40:314– 320. | Comparative-effectiveness
Pierce JP, Faerber S, Wright FA et al. Feasibility of a randomized trial of a high-vegetable diet to prevent breast cancer recurrence. Nutr Cancer. 1997;28:282–288. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Pinto BM, Friedman R, Marcus BH, Kelley H, Tennstedt S, Gillman MW. Effects of a computer-based, telephone-counseling system on physical activity. Am J Prev Med. 2002;23:113–120. | No relevant outcomes
Ramachandran A, Snehalatha C, Mary S, Mukesh B, Bhaskar AD, Vijay V. The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006;49:289–297. | Not on list of countries with HDI > 0.90
Randomised controlled trial evaluating cardiovascular screening and intervention in general practice: principal results of British family heart study. Family Heart Study Group. BMJ. 1994;308:313–320. | Other quality issues
Rankinen T, Rauramaa R, Vaisanen SB, Halonen JP, Penttila IM. Blood coagulation and fibrinolytic factors are unchanged by aerobic exercise or fat modified diet. Randomized clinical trial in middle-aged men. Fibrinolysis. 1994;8:48–53. | Not one of specified interventions
Ratner R, Goldberg R, Haffner S et al. Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care. 2005;28:888–894. | Comparative-effectiveness
Ratner RE, Christophi CA, Metzger BE et al. Prevention of diabetes in women with a history of gestational diabetes: effects of metformin and lifestyle interventions. Journal of Clinical Endocrinology & Metabolism. 2008;93:4774–4779. | Comparative-effectiveness
Reseland JE, Anderssen SA, Solvoll K et al. Effect of long-term changes in diet and exercise on plasma leptin concentrations. Am J Clin Nutr. 2001;73:240–245. | Population > 50% hypertension or dyslipidemia
Ritenbaugh C, Patterson RE, Chlebowski RT et al. The Women’s Health Initiative Dietary Modification trial: overview and baseline characteristics of participants. Ann Epidemiol. 2003;13:Suppl-97. | No relevant outcomes
Roca-Cusachs A, Sort D, Altimira J et al. The impact of a patient education programme in the control of hypertension. J Hum Hypertens. 1991;5:437–441. | Population > 50% hypertension or dyslipidemia
Roumen C, Corpeleijn E, Feskens EJ, Mensink M, Saris WH, Blaak EE. Impact of 3-year lifestyle intervention on postprandial glucose metabolism: the SLIM study. Diabetic Medicine. 2008;25:597–605. | Intervention involves supervised physical activity or medications
Rydwik E, Lammes E, Frandin K, Akner G. Effects of a physical and nutritional intervention program for frail elderly people over age 75. A randomized controlled pilot treatment trial. Aging-Clinical & Experimental Research. 2008;20:159–170. | Does not focus on counseling interventions
Salkeld G, Phongsavan P, Oldenburg B et al. The cost-effectiveness of a cardiovascular risk reduction program in general practice. Health Policy. 1997;41:105–119. | Population > 50% hypertension or dyslipidemia
Sallinen J, Fogelholm M, Pakarinen A et al. Effects of strength training and nutritional counseling on metabolic health indicators in aging women. Canadian Journal of Applied Physiology. 2005;30:690–707. | Less than 6 months of followup
Sallis JF, Patrick K, Calfas KJ et al. A multi-media behavior change program for nutrition and physical activity in primary care: PACE+ for adults. Homeostasis. 1999;39:196–202. | Less than 6 months of followup
Shike M, Latkany L, Riedel E et al. Lack of effect of a low-fat, high-fruit, -vegetable, and -fiber diet on serum prostate-specific antigen of men without prostate cancer: results from a randomized trial. Journal of Clinical Oncology. 2002;20:3592–3598. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Stamler J, Briefel RR, Milas C, Grandits GA, Caggiula AW. Relation of changes in dietary lipids and weight, trial years 1–6, to changes in blood lipids in the special intervention and usual care groups in the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65:272S–288S. | Intervention involves supervised physical activity or medications
Staten, Lisa K., Gregory-Mercado, Karen Y., Ranger-Moore, James, Will, Julie C., Giuliano, Anna R., Ford, Earl S., and Marshall, James. Provider Counseling, Health Education, and Community Health Workers: The Arizona WISEWOMAN Project. Journal of Women’s Health 2004;13(5):547–556. | Comparative-effectiveness
Steptoe A, Perkins-Porras L, Hilton S, Rink E, Cappuccio FP. Quality of life and self-rated health in relation to changes in fruit and vegetable intake and in plasma vitamins C and E in a randomised trial of behavioural and nutritional education counselling. British Journal of Nutrition. 2004;92:177–184. | Comparative-effectiveness
Steptoe A, Perkins-Porras L, McKay C, Rink E, Hilton S, Cappuccio FP. Behavioural counselling to increase consumption of fruit and vegetables in low income adults: randomised trial. BMJ. 2003;326:855. | Comparative-effectiveness
Stevens VJ, Glasgow RE, Toobert DJ, Karanja N, Smith KS. Randomized trial of a brief dietary intervention to decrease consumption of fat and increase consumption of fruits and vegetables. Am J Health Promot. 2002;16:129–134. | Less than 6 months of followup
Stoddard AM, Palombo R, Troped PJ, Sorensen G, Will JC. Cardiovascular disease risk reduction: the Massachusetts WISEWOMAN project. Journal of women’s health. 2004;13:539–546. | Comparative-effectiveness
Strandberg TE, Salomaa VV, Naukkarinen VA, Vanhanen HT, Sarna SJ, Miettinen TA. Long-term mortality after 5-year multifactorial primary prevention of cardiovascular diseases in middle-aged men. JAMA. 1991;266:1225–1229. | Intervention involves supervised physical activity or medications
Strandberg TE, Salomaa VV, Vanhanen HT, Naukkarinen VA, Sarna SJ, Miettinen TA. Mortality in participants and non-participants of a multifactorial prevention study of cardiovascular diseases: a 28 year follow up of the Helsinki Businessmen Study. Br Heart J. 1995;74:449–454. | Intervention involves supervised physical activity or medications
Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24:619–624. | Limited to children and adolescents, parents (if change intended for children), persons with any acute disease or symptomatic disease, persons with known coronary heart disease (or angina) or peripheral vascular disease or diabetes, pregnant women, institutionalized persons, or persons with SPMI or cognitive impairment
Takahashi Y, Sasaki S, Okubo S, Hayashi M, Tsugane S. Blood pressure change in a free-living population-based dietary modification study in Japan. J Hypertens. 2006;24:451–458. | Other quality issues
The Diabetes Prevention Program. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22:623–634. | Comparative-effectiveness
The Diabetes Prevention Program: baseline characteristics of the randomized cohort. The Diabetes Prevention Program Research Group. Diabetes Care. 2000;23:1619–1629. | Comparative-effectiveness
The WISEWOMAN Workgroup. Cardiovascular disease prevention for women attending breast and cervical cancer screening programs: the WISEWOMAN projects. Prev Med. 1999;28:496–502. | Comparative-effectiveness
Toft U, Kristoffersen L, Ladelund S et al. The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake. The Inter99 study - a randomized controlled trial. International Journal of Behavioral Nutrition & Physical Activity. 2008;5:59. | Population > 50% hypertension or dyslipidemia
Toft U, Kristoffersen L, Ladelund S et al. The impact of a population-based multi-factorial lifestyle intervention on changes in long-term dietary habits The Inter99 study. Prev Med. 2008. | Population > 50% hypertension or dyslipidemia
Tomson Y, Johannesson M, Aberg H. The costs and effects of two different lipid intervention programmes in primary health care. J Intern Med. 1995;237:13–17. | Population > 50% hypertension or dyslipidemia
Tuomilehto J, Lindstrom J, Eriksson JG et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. New England Journal of Medicine. 2001;344:1343–1350. | Intervention involves supervised physical activity or medications
Uusitupa M, Lindi V, Louheranta A, Salopuro T, Lindstrom J, Tuomilehto J. Long-term improvement in insulin sensitivity by changing lifestyles of people with impaired glucose tolerance: 4-year results from the Finnish Diabetes Prevention Study. Diabetes. 2003;52:2532–2538. | Intervention involves supervised physical activity or medications
Uusitupa M, Louheranta A, Lindstrom J et al. The Finnish Diabetes Prevention Study. Br J Nutr. 2000;83 Suppl 1:S137–42.:S137–S142. | Intervention involves supervised physical activity or medications
van der Veen J, Bakx C, van den Hoogen H et al. Stage-matched nutrition guidance for patients at elevated risk for cardiovascular disease: a randomized intervention study in family practice. J Fam Pract. 2002;51:751–758. | Population > 50% hypertension or dyslipidemia
van Steenkiste B, van-der Weijden T, Stoffers HE, Kester AD, Timmermans DR, Grol R. Improving cardiovascular risk management: a randomized, controlled trial on the effect of a decision support tool for patients and physicians. European journal of cardiovascular prevention and rehabilitation: official journal of the European Society of Cardiology, Working Groups on Epidemiology & Prevention and Cardiac Rehabilitation and Exercise Physiology. 2007;14:44–50. | No relevant outcomes
Verheijden M, Bakx JC, Akkermans R et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. 2004;6:e44. | Population > 50% hypertension or dyslipidemia
Verheijden MW, van d, V, Bakx JC et al. Stage-matched nutrition guidance: stages of change and fat consumption in Dutch patients at elevated cardiovascular risk. J Nutr Educ Behav. 2004;36:228–237. | Population > 50% hypertension or dyslipidemia
Villareal DT, Miller BV, III, Banks M, Fontana L, Sinacore DR, Klein S. Effect of lifestyle intervention on metabolic coronary heart disease risk factors in obese older adults. Am J Clin Nutr. 2006;84:1317–1323. | Primary aim is weight loss
Walden CE, Retzlaff BM, Buck BL, McCann BS, Knopp RH. Lipoprotein lipid response to the National Cholesterol Education Program step II diet by hypercholesterolemic and combined hyperlipidemic women and men. Arterioscler Thromb Vasc Biol. 1997;17:375–382. | Population > 50% hypertension or dyslipidemia
Wassertheil-Smoller S, Oberman A, Blaufox MD, Davis B, Langford H. The Trial of Antihypertensive Interventions and Management (TAIM) Study. Final results with regard to blood pressure, cardiovascular risk, and quality of life. Am J Hypertens. 1992;5:37–44. | Population > 50% hypertension or dyslipidemia
Whelton PK, Kumanyika SK, Cook NR et al. Efficacy of nonpharmacologic interventions in adults with high- normal blood pressure: results from phase 1 of the Trials of Hypertension Prevention. Trials of Hypertension Prevention Collaborative Research Group. Am J Clin Nutr. 1997;65:652S–660S. | No relevant outcomes
Whelton PK, Appel LJ, Espeland MA et al. Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). TONE Collaborative Research Group. JAMA. 1998;279:839–846. | Population > 50% hypertension or dyslipidemia
White E, Shattuck AL, Kristal AR et al. Maintenance of a low-fat diet: follow-up of the Women’s Health Trial. Cancer Epidemiol Biomarkers Prev. 1992;1:315–323. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Wildman RP, Schott LL, Brockwell S, Kuller LH, Sutton-Tyrrell K. A dietary and exercise intervention slows menopause-associated progression of subclinical atherosclerosis as measured by intima-media thickness of the carotid arteries. Journal of the American College of Cardiology. 2004;44:579–585. | No relevant outcomes
Will JC, Massoudi B, Mokdad A et al. Reducing risk for cardiovascular disease in uninsured women: combined results from two WISEWOMAN projects. Journal of the American Medical Women’s Association. 2001;56:161–165. | Comparative-effectiveness
Wing RR, Venditti E, Jakicic JM, Polley BA, Lang W. Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21:350–359. | Primary aim is weight loss
Wolf RL, Lepore SJ, Vandergrift JL, Basch CE, Yaroch AL. Tailored telephone education to promote awareness and adoption of fruit and vegetable recommendations among urban and mostly immigrant black men: a randomized controlled trial. Prev Med. 2009;48:32–38. | Intervention meets criteria but specifically targets a non- cardiovascular-related condition
Wylie-Rosett J, Wassertheil-Smoller S, Blaufox MD et al. Trial of antihypertensive intervention and management: greater efficacy with weight reduction than with a sodium-potassium intervention. J Am Diet Assoc. 1993;93:408–415. | Population > 50% hypertension or dyslipidemia
Young DR, King AC, Sheehan M, Stefanick ML. Stage of motivational readiness: predictive ability for exercise behavior. American Journal of Health Behavior. 2002;26:331–341. | Population > 50% hypertension or dyslipidemia
Young DR, Vollmer WM, King AC et al. Can individuals meet multiple physical activity and dietary behavior goals? American Journal of Health Behavior. 2009;33:277–286. | Comparative-effectiveness

Appendix D Table 2 Healthful Diet Studies Excluded From the Review for Key Question 4

Reference | Reason for exclusion
Ferrer RL, Mody-Bailey P, Jaen CR, Gott S, Araujo S. A medical assistant- based program to promote healthy behaviors in primary care. Ann Fam Med. 2009;7:504–512. | High or differential attrition
Geleijnse JM, Witteman JC, Bak AA, den Breeijen JH, Grobbee DE. Long- term moderate sodium restriction does not adversely affect the serum HDL/total cholesterol ratio. J Hum Hypertens. 1995;9:975–979. | Population > 50% hypertension or dyslipidemia
Boyd NF, Greenberg C, Lockwood G et al. Effects at two years of a low-fat, high-carbohydrate diet on radiologic features of the breast: results from a randomized trial. Canadian Diet and Breast Cancer Prevention Study Group. J Natl Cancer Inst. 1997;89:488–496. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Hislop TG, Bajdik CD, Balneaves LG et al. Physical and emotional health effects and social consequences after participation in a low-fat, high- carbohydrate dietary trial for more than 5 years. Journal of Clinical Oncology. 2006;24:2311–2317. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition

Appendix D Table 3 Physical Activity Studies Excluded From the Review for Key Questions 1–3

Reference | Reason for exclusion
Albright, Cheryl, Pruitt, Leslie, Castro, Cynthia, Gonzalez, Alma, Woo, Sandi, and King, Abby C. Modifying physical activity in a multiethnic sample of low-income women: One-year results from the IMPACT (increasing motivation for physical ACTivity) project. Annals of Behavioral Medicine. 2005;30(3):191–200. | Comparative-effectiveness
Allison MJ, Keller C. Self-efficacy intervention effect on physical activity in older adults. Western Journal of Nursing Research. 2004;26:31–46. | Limited to children and adolescents, parents (if change intended for children), persons with any acute disease or symptomatic disease, persons with known coronary heart disease (or angina) or peripheral vascular disease or diabetes, pregnant women, institutionalized persons, or persons with SPMI or cognitive impairment
Amati, Francesca, Barthassat, Vincent, Miganne, Guy, Hausman, Isabelle, Monnin, Dominique, Constanza, Michael C., and Golay, Alain. Enhancing regular physical activity and relapse prevention through a 1-day therapeutic patient education workshop: A pilot study. Patient Educ Couns. 2007;68(1):70– 78. | Not an allowable study design
Anderson RT, King A, Stewart AL, Camacho F, Rejeski WJ. Physical activity counseling in primary care and patient well-being: Do patients benefit? Ann Behav Med. 2005;30:146–154. | Comparative-effectiveness
Anderssen S, Holme I, Urdal P, Hjermann I. Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4:343– 349. | Population > 50% hypertension or dyslipidemia
Anderssen SA, Carroll S, Urdal P, Holme I. Combined diet and exercise intervention reverses the metabolic syndrome in middle-aged males: results from the Oslo Diet and Exercise Study. Scandinavian Journal of Medicine & Science in Sports. 2007;17:687–695. | Intervention involves supervised physical activity or medications
Anderssen SA, Haaland A Hjerman I Urdal P Gjesdal K Holme I. Oslo diet and exercise study: a one year randomized intervention trial. Efect on Haemostatic variables and other coronary risk factors. Nutrition, Metabolism & Cardiovascular Diseases. 1995;5:189–200. | Intervention involves supervised physical activity or medications
Anderssen SA, Hjermann I, Urdal P, Torjesen PA, Holme I. Improved carbohydrate metabolism after physical training and dietary intervention in individuals with the “atherothrombogenic syndrome’. Oslo Diet and Exercise Study (ODES). A randomized trial. J Intern Med. 1996;240:203–209. | Population > 50% hypertension or dyslipidemia
Appel LJ, Champagne CM, Harsha DW et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289:2083–2093. | Comparative-effectiveness
Applegate WB, Miller ST, Elam JT et al. Nonpharmacologic intervention to reduce blood pressure in older patients with mild hypertension. Arch Intern Med. 1992;152:1162–1166. | Population > 50% hypertension or dyslipidemia
Armit CM, Brown WJ, Marshall AL et al. Randomized trial of three strategies to promote physical activity in general practice. Prev Med. 2009;48:156–163. | Comparative-effectiveness
Armit CM, Brown WJ, Ritchie CB, Trost SG. Promoting physical activity to older adults: a preliminary evaluation of three general practice-based strategies. Journal of Science & Medicine in Sport. 2005;8:446– 450. | Comparative-effectiveness
Asikainen TM, Miilunpalo S, Kukkonen-Harjula K et al. Walking trials in postmenopausal women: effect of low doses of exercise and exercise fractionization on coronary risk factors. Scandinavian Journal of Medicine & Science in Sports. 2003;13:284–292. | Intervention involves supervised physical activity or medications
Baker MK, Atlantis E, Fiatarone Singh MA. Multi-modal exercise programs for older adults. Age Ageing. 2007;36:375–381. | Not an allowable study design
Barclay C, Procter KL, Glendenning R, Marsh P, Freeman J, Mathers N. Can type 2 diabetes be prevented in UK general practice? A lifestyle-change feasibility study (ISAIAH). Br J Gen Pract. 2008;58:541–547. | Intervention involves supervised physical activity or medications
Bennett JA, Young HM, Nail LM, Winters-Stone K, Hanson G. A telephone-only motivational intervention to increase physical activity in rural adults: a randomized controlled trial. Nursing Research. 2008;57:24–32. | Comparative-effectiveness
Bergstrom I, Lombardo C, Brinck J. Physical training decreases waist circumference in postmenopausal borderline overweight women. Acta Obstetricia et Gynecologica Scandinavica. 2009;88:308–313. | Biased recruitment strategy or selection of patients not generalizable to primary care
Blue CL, Black DR. Synthesis of intervention research to modify physical activity and dietary behaviors. Res Theory Nurs Pract. 2005;19(1):25–61. | Not an allowable study design
Blumenthal JA, Sherwood A, Gullette EC et al. Exercise and weight loss reduce blood pressure in men and women with mild hypertension: effects on cardiovascular, metabolic, and hemodynamic functioning. Arch Intern Med. 2000;160:1947–1958. | Intervention involves supervised physical activity or medications
Bo S, Ciccone G, Baldi C et al. Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med. 2007;22:1695–1703. | Population > 50% hypertension or dyslipidemia
Bock BC, Marcus BH, Pinto BM, Forsyth LH. Maintenance of physical activity following an individualized motivationally tailored intervention. Ann Behav Med. 2001;23:79–87. | Comparative-effectiveness
Brawley LR, Rejeski W, Lutes LA. A group-mediated cognitive-behavioral intervention for increasing adherence to physical activity in older adults. Journal of Applied Biobehavioral Research. 2000;5:47–65. | Intervention involves supervised physical activity or medications
British family heart study: its design and method, and prevalence of cardiovascular risk factors. Family heart study group. Br J Gen Pract. 1994;44:62–67. | Other quality issues
Bull FC, Jamrozik K. Advice on exercise from a family physician can help sedentary patients to become active. Am J Prev Med. 1998;15:85–94. | High or differential attrition
Burke V, Beilin LJ, Cutt HE, Mansour J, Mori TA. Moderators and mediators of behaviour change in a lifestyle program for treated hypertensives: a randomized controlled trial (ADAPT). Health Education Research. 2008;23:583–591. | Population > 50% hypertension or dyslipidemia
Burke V, Giangiulio N, Gillam HF, Beilin LJ, Houghton S, Milligan RA. Health promotion in couples adapting to a shared lifestyle. Health Educ Res. 1999;14:269–288. | Less than 6 months of followup
Burke V, Giangiulio N, Gillam HF, Beilin LJ, Houghton S. Physical activity and nutrition programs for couples: a randomized controlled trial. Journal of Clinical Epidemiology. 2003;56:421–432. | High or differential attrition
Burke V, Mori TA, Giangiulio N et al. An innovative program for changing health behaviours. Asia Pac J Clin Nutr. 2002;11 Suppl 3:S586–S597. | High or differential attrition
Burton LC, Paglia MJ, German PS, Shapiro S, Damiano AM. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. The Medicare Preventive Services Research Team. Prev Med. 1995;24:492–497. | Other quality issues
Byfield, Cynthia Louise. Development and evaluation of a lifestyle physical activity intervention for obese sedentary women. Dissertation Abstracts International: Section B:The Sciences and Engineering. 2001;62(5-B):2280. | Comparative-effectiveness
Cardinal BJ, Sachs ML. Prospective analysis of stage-of-exercise movement following mail-delivered, self- instructional exercise packets. Am J Health Promot. 1995;9:430–432. | No relevant outcomes
Carlfjord S, Nilsen P, Leijon M, Andersson A, Johansson K, Bendtsen P. Computerized lifestyle intervention in routine primary health care: evaluation of usage on provider and responder levels. Patient Education & Counseling 75 (2):238–243, 2009. | No relevant outcomes
Carr LJ, Bartee RT, Dorozynski CM, Broomfield JF, Smith ML, Smith DT. Eight-month follow-up of physical activity and central adiposity: results from an Internet-delivered randomized control trial intervention. Journal of Physical Activity & Health 6 (4):444–455, 2009. | Less than 6 months of followup
Carroll R, Ali N, Azam N. Promoting physical activity in South Asian Muslim women through “exercise on prescription”. Health Technol Assess. 2002;6:1–101. | Not an allowable study design
Castro CM, King AC, Brassington GS. Telephone versus mail interventions for maintenance of physical activity in older adults. Health Psychology. 2001;20:438–444. | Comparative-effectiveness
Chen AH, Sallis JF, Castro CM et al. A home-based behavioral intervention to promote walking in sedentary ethnic minority women: project WALK. Womens Health. 1998;4:19–39. | High or differential attrition
Chen, AH-W. The effectiveness of a home-based intervention to promote walking in ethnic minority women. 1996. U California San Diego and San Diego State U. | High or differential attrition
Conn VS, Burks KJ, Minor MA, Mehr DR. Randomized trial of 2 interventions to increase older women’s exercise. Am J Health Behav. 2003;27:380–388. | Less than 6 months of followup
Corace, Kimberly M. Does reducing negative affect facilitate readiness to exercise? A stage-based, cognitive-behavioural intervention for individuals at risk for primary and secondary Coronary Heart Disease. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2008;69(6- B):3841. | Population > 50% hypertension or dyslipidemia
Costanzo C, Walker SN, Yates BC, McCabe B, Berg K. Physical activity counseling for older women. West J Nurs Res. 2006;28:786–801. | Less than 6 months of followup
Coulter A, Fowler G, Fuller A et al. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study. British Medical Journal. 1995;310:1099–1104. | Other quality issues
Crandall J, Schade D, Ma Y et al. The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. 2006;61:1075–1081. | Comparative-effectiveness
Cutler JA, Neaton JD, Hulley SB, Kuller L, Paul O, Stamler J. Coronary heart disease and all-causes mortality in the Multiple Risk Factor Intervention Trial: subgroup findings and comparisons with other trials. Prev Med. 1985;14:293–311. | Population > 50% hypertension or dyslipidemia
Davey SG, Bracha Y, Svendsen KH et al. Incidence of type 2 diabetes in the randomized multiple risk factor intervention trial. Ann Intern Med. 2005;142:313–322. | Population > 50% hypertension or dyslipidemia
Davidson LE, Hudson R, Kilpatrick K et al. Effects of exercise modality on insulin resistance and functional limitation in older adults: a randomized controlled trial. Arch Intern Med. 2009;169:122–131. | Intervention involves supervised physical activity or medications
de Vries, H., Kremers, S. P. J., Smeets, T., Brug, J., and Eijmael, K. The effectiveness of tailored feedback and action plans in an intervention addressing multiple health behaviors. American Journal of Health Promotion. 2008;22(6):417–425. | Comparative-effectiveness
Delahanty LM, Sonnenberg LM, Hayden D, Nathan DM. Clinical and cost outcomes of medical nutrition therapy for hypercholesterolemia: a controlled trial. Journal of the American Dietetic Association. 2001;101:1012–1023. | Not one of specified interventions
Deley G, Kervio G, Van HJ, Verges B, Grassi B, Casillas JM. Effects of a one-year exercise training program in adults over 70 years old: a study with a control group. Aging-Clinical & Experimental Research. 2007;19:310–315. | Intervention involves supervised physical activity or medications
Dolecek TA, Milas NC, Van Horn LV et al. A long-term nutrition intervention experience: lipid responses and dietary adherence patterns in the Multiple Risk Factor Intervention Trial. J Am Diet Assoc. 1986;86:752–758. | Population > 50% hypertension or dyslipidemia
Dubbert PM, Cooper KM, Kirchner KA, Meydrech EF, Bilbrew D. Effects of nurse counseling on walking for exercise in elderly primary care patients. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2002;57:M733–M740. | Comparative-effectiveness
Dubbert PM, Morey MC, Kirchner KA, Meydrech EF, Grothe K. Counseling for home-based walking and strength exercise in older primary care patients. Arch Intern Med. 2008;168:979–986. | Limited to children and adolescents, parents (if change intended for children), persons with any acute disease or symptomatic disease, persons with known coronary heart disease (or angina) or peripheral vascular disease or diabetes, pregnant women, institutionalized persons, or persons with SPMI or cognitive impairment
Dutton GR, Davis MP, Welsch MA, Brantley PJ. Promoting physical activity for low-income minority women in primary care. American Journal of Health Behavior. 2007;31:622–631. | Primary aim is weight loss
Dzator JA, Hendrie D, Burke V et al. A randomized trial of interactive group sessions achieved greater improvements in nutrition and physical activity at a tiny increase in cost. Journal of Clinical Epidemiology. 2004;57:610–619. | High or differential attrition
Eakin E, Reeves M, Lawler S et al. Telephone counseling for physical activity and diet in primary care patients. Am J Prev Med. 2009;36:142–149. | Population > 50% hypertension or dyslipidemia
Eakin EG, Brown WJ, Marshall AL, Mummery K, Larsen E. Physical activity promotion in primary care: bridging the gap between research and practice. Am J Prev Med. 2004;27:297–303. | No relevant outcomes
Eckstrom E, Hickam DH, Lessler DS, Buchner DM. Changing physician practice of physical activity counseling. J Gen Intern Med. 1999;14:376–378. | High or differential attrition
Effectiveness of health checks conducted by nurses in primary care: results of the OXCHECK study after one year. Imperial Cancer Research Fund OXCHECK Study Group. BMJ. 1994;308:308–312. | Other quality issues
Elder JP, Williams SJ, Drew JA, Wright BL, Boulan TE. Longitudinal effects of preventive services on health behaviors among an elderly cohort. Am J Prev Med. 1995;11:354–359. | High or differential attrition
Elley R, Kerse N, Arroll B, Swinburn B, Ashton T, Robinson E. Cost-effectiveness of physical activity counselling in general practice. New Zealand Medical Journal. 2004;117:U1216. | No relevant outcomes
Ellingsen I, Hjerkinn EM, Arnesen H, Seljeflot I, Hjermann I, Tonstad S. Follow-up of diet and cardiovascular risk factors 20 years after cessation of intervention in the Oslo Diet and Antismoking Study. European Journal of Clinical Nutrition. 2006;60:378–385. | No relevant outcomes
Ellingsen I, Hjermann I, Abdelnoor M, Hjerkinn EM, Tonstad S. Dietary and antismoking advice and ischemic heart disease mortality in men with normal or high fasting triacylglycerol concentrations: a 23-y follow-up study. The American journal of clinical nutrition. 2003;78:935–940. | Not one of specified interventions
Ellsworth DL, O’Dowd SC, Salami B et al. Intensive lifestyle modification: impact on cardiovascular disease risk factors in subjects with and without clinical cardiovascular disease. Preventive Cardiology. 2004;7:168– 175. | Not an allowable study design
Elmer PJ, Obarzanek E, Vollmer WM et al. Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Ann Intern Med. 2006;144:485–495. | Comparative-effectiveness
Emmons, Karen M., Stoddard, Ann M., Fletcher, Robert, Gutheil, Caitlin, Suarez, Elizabeth Gonzalez, Lobb, Rebecca, Weeks, Jane, and Bigby, Judy Anne. Cancer Prevention Among Working Class, Multiethnic Adults: Results of the Healthy Directions--Health Centers Study. American Journal of Public Health. 2005;95(7):1200–1205. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Engels HJ, Drouin J, Zhu W, Kazmierski JF. Effects of low-impact, moderate-intensity exercise training with and without wrist weights on functional capacities and mood states in older adults. Gerontology. 1998;44:239–244. | Intervention involves supervised physical activity or medications
Eriksson J, Lindstrom J, Valle T et al. Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42:793–801. | Intervention involves supervised physical activity or medications
Espeland MA, Whelton PK, Kostis JB et al. Predictors and mediators of successful long-term withdrawal from antihypertensive medications. TONE Cooperative Research Group. Trial of Nonpharmacologic Interventions in the Elderly. Arch Fam Med. 1999;8:228–236. | Population > 50% hypertension or dyslipidemia
Evans EM, Van Pelt RE, Binder EF, Williams DB, Ehsani AA, Kohrt WM. Effects of HRT and exercise training on insulin action, glucose tolerance, and body composition in older women. Journal of Applied Physiology. 2001;90:2033–2040. | Intervention involves supervised physical activity or medications
Fagerberg B, Wikstrand J, Berglund G, Samuelsson O, Agewall S. Mortality rates in treated hypertensive men with additional risk factors are high but can be reduced: a randomized intervention study. Am J Hypertens. 1998;11:14–22. | Population > 50% hypertension or dyslipidemia
Ferrer RL, Mody-Bailey P, Jaen CR, Gott S, Araujo S. A medical assistant-based program to promote healthy behaviors in primary care. Ann Fam Med. 2009;7:504–512. | High or differential attrition
Figueroa A, Going SB, Milliken LA et al. Effects of exercise training and hormone replacement therapy on lean and fat mass in postmenopausal women. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2003;58:266–270. | Intervention involves supervised physical activity or medications
Findorff MJ, Stock HH, Gross CR, Wyman JF. Does the Transtheoretical Model (TTM) explain exercise behavior in a community-based sample of older women? Journal of Aging & Health. 2007;19:985–1003 | Does not focus on counseling interventions
Frierson GM, Williams DM, Dunsiger S et al. Recruitment of a racially and ethnically diverse sample into a physical activity efficacy trial. Clinical Trials. 2008;5:504–516. | Comparative-effectiveness
Garcia A, King A. Predicting long-term adherence to aerobic exercise: a comparison of two models. J Sport Exerc Psychol. 1991;13:394–410. | Comparative-effectiveness
Gaston MH, Porter GK, Thomas VG. Prime Time Sister Circles: evaluating a gender-specific, culturally relevant health intervention to decrease major risk factors in mid-life African-American women. J Natl Med Assoc. 2007;99:428–438. | Setting not primary care or generalizable to primary care
Goodpaster BH, Chomentowski P, Ward BK et al. Effects of physical activity on strength and skeletal muscle fat infiltration in older adults: a randomized controlled trial. Journal of applied physiology (Bethesda, Md: 1985). 2008;105:1498–1503. | Intervention involves supervised physical activity or medications
Graham-Clarke P, Oldenburg B. The effectiveness of a general-practice-based physical activity intervention on patient physical activity status. Behavioral Change. 1994;11:132–144. | High or differential attrition
Greaves CJ, Middlebrooke A, O’Loughlin L et al. Motivational interviewing for modifying diabetes risk: a randomised controlled trial. Br J Gen Pract. 2008;58:535–540. | Primary aim is weight loss
Hamdorf PA, Penhall RK. Walking with its training effects on the fitness and activity patterns of 79–91 year old females. Aust N Z J Med. 1999;29:22–28. | Intervention involves supervised physical activity or medications
Hamdorf PA, Withers RT, Penhall RK, Haslam MV. Physical training effects on the fitness and habitual activity patterns of elderly women. Arch Phys Med Rehabil. 1992;73:603–608. | Intervention involves supervised physical activity or medications
Hamdorf PA, Withers RT, Penhall RK, Plummer JL. A follow-up study on the effects of training on the fitness and habitual activity patterns of 60- to 70-year-old women. Arch Phys Med Rehabil. 1993;74:473– 477. | Intervention involves supervised physical activity or medications
Harari D, Iliffe S, Kharicha K et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing. 2008;37:565–571. | Does not focus on counseling interventions
Hardman AE, Jones PR, Norgan NG, Hudson A. Brisk walking improves endurance fitness without changing body fatness in previously sedentary women. Eur J Appl Physiol Occup Physiol. 1992;65:354–359. | Outcome assessment unblinded
Harralson, TL, Emig JC, Polansky M, WalkerRE, Otero Cruz J, Garcia-Leeds C. Un corazon saludable: Factors influencing outcomes of an exercise program designed to impact cardiac and metabolic risks among urban Latinas. Journal of Community Health: The Publication for Health Promotion and Disease Prevention 32[6], 401–412. 2007. | Intervention involves supervised physical activity
Harrison RA, Roberts C, Elton PJ. Does primary care referral to an exercise programme increase physical activity one year later? A randomized controlled trial. Journal of Public Health. 2005;27:25–32. | Population > 50% hypertension or dyslipidemia
Harting J, Van AP, van LP et al. Effects of health counseling on behavioural risk factors in a high-risk cardiology outpatient population: a randomized clinical trial. European Journal of Cardiovascular Prevention & Rehabilitation. 2006;13:214–221. | Limited to children and adolescents, parents (if change intended for children), persons with any acute disease or symptomatic disease, persons with known coronary heart disease (or angina) or peripheral vascular disease or diabetes, pregnant women, institutionalized persons, or persons with SPMI or cognitive impairment
Havenar, Jacob. Adapted motivational interviewing for increasing physical activity: A 12 month clinical trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2007;68(4-B):2291. | Outcome assessment unblinded
He J, Whelton PK, Appel LJ, Charleston J, Klag MJ. Long-term effects of weight loss and dietary sodium reduction on incidence of hypertension. Hypertension. 2000;35:544–549. | No relevant outcomes
Hebert PR, Bolt RJ, Borhani NO et al. Design of a multicenter trial to evaluate long-term life-style intervention in adults with high-normal blood pressure levels. Trials of Hypertension Prevention (phase II). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5:130–139. | Not one of specified interventions
Hernan WH, Brandle M, Zhang P et al. Costs associated with the primary prevention of type 2 diabetes mellitus in the diabetes prevention program. Diabetes Care. 2003;26:36–47. | Comparative-effectiveness
Hillsdon M, Thorogood M, White I, Foster C. Advising people to take more exercise is ineffective: a randomized controlled trial of physical activity promotion in primary care. Int J Epidemiol. 2002;31:808–815. | High or differential attrition
Hoffmeister H, Mensink GB, Stolzenberg H et al. Reduction of coronary heart disease risk factors in the German cardiovascular prevention study. Prev Med. 1996;25:135–145. | Not an allowable study design
Holland SK, Greenberg J, Tidwell L, Malone J, Mullan J, Newcomer R. Community-based health coaching, exercise, and health service utilization. Journal of Aging & Health. 2005;17:697–716. | Limited to children and adolescents, parents (if change intended for children), persons with any acute disease or symptomatic disease, persons with known coronary heart disease (or angina) or peripheral vascular disease or diabetes, pregnant women, institutionalized persons, or persons with SPMI or cognitive impairment
Holme I, Hostmark AT, Anderssen SA. ApoB but not LDL-cholesterol is reduced by exercise training in overweight healthy men. Results from the 1-year randomized Oslo Diet and Exercise Study. Journal of Internal Medicine. 2007;262:235–243. | Population > 50% hypertension or dyslipidemia
Holtrop JS, Dosh SA, Torres T, Thum YM. The community health educator referral liaison (CHERL): a primary care practice role for promoting healthy behaviors. Am J Prev Med. 2008;35:Suppl-72. | Comparative-effectiveness
Hughes SL, Seymour RB, Campbell RT, Whitelaw N, Bazzarre T. Best-practice physical activity programs for older adults: findings from the national impact study. American Journal of Public Health. 2009;99:362–368. | Intervention involves supervised physical activity or medications
Hyman DJ, Herd JA, Ho KS, Dunn JK, Gregory KA. Maintenance of cholesterol reduction using automated telephone calls. Am J Prev Med. 1996;12:129–133. | Not one of specified interventions
Hyman DJ, Ho KS, Dunn JK, Simons-Morton D. Dietary intervention for cholesterol reduction in public clinic patients. Am J Prev Med. 1998;15:139–145. | Not one of specified interventions
Hyman DJ, Pavlik VN, Taylor WC, Goodrick GK, Moye L. Simultaneous vs sequential counseling for multiple behavior change. Arch Intern Med. 2007;167:1152–1158. | Population > 50% hypertension or dyslipidemia
Inoue S, Odagiri Y, Wakui S et al. Randomized controlled trial to evaluate the effect of a physical activity intervention program based on behavioral medicine. Zasshi/Tokyo Ika Daigaku. 2003;61:154–165. | Intervention involves supervised physical activity or medications
Irwin ML, Yasui Y, Ulrich CM et al. Effect of exercise on total and intra-abdominal body fat in postmenopausal women: a randomized controlled trial. JAMA. 2003;289:323–330. | Intervention involves supervised physical activity or medications
Isaacs AJ, Critchley JA, Tai SS et al. Exercise Evaluation Randomised Trial (EXERT): a randomised trial comparing GP referral for leisure centre-based exercise, community-based walking and advice only. Health Technol Assess. 2007;11:1–iv. | Intervention involves supervised physical activity or medications
Ives DG, Kuller LH, Traven ND. Use and outcomes of a cholesterol-lowering intervention for rural elderly subjects. Am J Prev Med. 1993;9:274–281. | Population > 50% hypertension or dyslipidemia
Jacobs AD, Ammerman AS, Ennett ST et al. Effects of a tailored follow-up intervention on health behaviors, beliefs, and attitudes. Journal of Women’s Health. 2004;13:557–568. | Population > 50% hypertension or dyslipidemia
Jacobs DR, Jr., Sluik D, Rokling-Andersen MH, Anderssen SA, Drevon CA. Association of 1-y changes in diet pattern with cardiovascular disease risk factors and adipokines: results from the 1-y randomized Oslo Diet and Exercise Study. Am J Clin Nutr. 2009;89:509–517. | Intervention involves supervised physical activity or medications
Jalkanen L. The effect of a weight reduction program on cardiovascular risk factors among overweight hypertensives in primary health care. Scand J Soc Med. 1991;19:66–71. | Primary aim is weight loss
Jarvis KL, Friedman RH, Heeren T, Cullinane PM. Older women and physical activity: using the telephone to walk. Womens Health Issues. 1997;7:24–29. | Less than 6 months of followup
Jenum AK, Lorentzen C, Anderssen SA et al. Promoting physical activity in a multi-ethnic district-methods and baseline results of a pseudo-experimental intervention study. European Journal of Cardiovascular Prevention & Rehabilitation. 2003;10:387–396. | No relevant outcomes
Jimmy G, Martin BW. Implementation and effectiveness of a primary care based physical activity counselling scheme. Patient Education & Counseling. 2005;56:323–331. | Comparative-effectiveness
Jorgensen T, Borch-Johnsen K, Thomsen TF, Ibsen H, Glumer C, Pisinger C. A randomized non-pharmacological intervention study for prevention of ischaemic heart disease: baseline results Inter99. European Journal of Cardiovascular Prevention & Rehabilitation. 2003;10:377–386. | Population > 50% hypertension or dyslipidemia
Jula A, Ronnemaa T, Rastas M, Karvetti RL, Maki J. Long-term nopharmacological treatment for mild to moderate hypertension. J Intern Med. 1990;227:413–421. | Population > 50% hypertension or dyslipidemia
Jula AM, Karanko HM. Effects on left ventricular hypertrophy of long-term nonpharmacological treatment with sodium restriction in mild-to-moderate essential hypertension. Circulation. 1994;89:1023–1031. | Population > 50% hypertension or dyslipidemia
Kastarinen MJ, Puska PM, Korhonen MH et al. Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20:2505–2512. | Population > 50% hypertension or dyslipidemia
Katzel LI, Bleecker ER, Colman EG, Rogus EM, Sorkin JD, Goldberg AP. Effects of weight loss vs aerobic exercise training on risk factors for coronary disease in healthy, obese, middle-aged and older men. A randomized controlled trial. JAMA. 1995;274:1915–1921. | Intervention involves supervised physical activity or medications
Kawano M, Shono N, Yoshimura T, Yamaguchi M, Hirano T, Hisatomi A. Improved cardio-respiratory fitness correlates with changes in the number and size of small dense LDL: randomized controlled trial with exercise training and dietary instruction. Internal Medicine. 2009;48:25–32. | Intervention involves supervised physical activity or medications
Keller S, Donner-Banzhoff N, Kaluza G, Baum E, Basler HD. Improving physician-delivered counseling in a primary care setting: lessons from a failed attempt. Educ Health (Abingdon ). 2000;13:387–397. | High or differential attrition
Kerse NM, Flicker L, Jolley D, Arroll B, Young D. Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme. BMJ. 1999;319:683–687. | Does not focus on counseling interventions
Ketola E, Makela M, Klockars M. Individualised multifactorial lifestyle intervention trial for high-risk cardiovascular patients in primary care. Br J Gen Pract. 2001;51:291–294. | Population > 50% hypertension or dyslipidemia
King AC, Sallis JF, Dunn AL et al. Overview of the Activity Counseling Trial (ACT) intervention for promoting physical activity in primary health care settings. Activity Counseling Trial Research Group. Med Sci Sports Exerc. 1998;30:1086–1096. | Comparative-effectiveness
King AC, Friedman R, Marcus B et al. Harnessing motivational forces in the promotion of physical activity: the Community Health Advice by Telephone (CHAT) project. Health Education Research. 2002;17:627–636. | No relevant outcomes
Kinzel LS, Averbach FM, Clark KS et al. A high carbohydrate, low fat, hypocaloric eating pattern using functional foods along with increased physical activity in postmenopausal women decreases cardiovascular risk factors. Journal of the American Dietetic Association. 2004;104:31. | Comparative-effectiveness
Kjelsberg MO, Cutler JA, Dolecek TA. Brief description of the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65:191S–195S. | Population > 50% hypertension or dyslipidemia
Klem ML, Viteri JE, Wing RR. Primary prevention of weight gain for women aged 25–34: the acceptability of treatment formats. Int J Obes Relat Metab Disord. 2000;24:219–225. | High or differential attrition
Knowler WC, Barrett-Connor E, Fowler SE et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. New England Journal of Medicine. 2002;346:393–403. | Comparative-effectiveness
Knutsen SF, Knutsen R. The Tromso Survey: the Family Intervention study--the effect of intervention on some coronary risk factors and dietary habits, a 6-year follow-up. Prev Med. 1991;20:197–212. | Not one of specified interventions
Korhonen MH, Litmanen H, Rauramaa R, Vaisanen SB, Niskanen L, Uusitupa M. Adherence to the salt restriction diet among people with mildly elevated blood pressure. Eur J Clin Nutr. 1999;53:880–885. | Not one of specified interventions
Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Research & Clinical Practice. 2005;67:152–162. | Comparative-effectiveness
Kreuter MW, Strecher VJ. Do tailored behavior change messages enhance the effectiveness of health risk appraisal? Results from a randomized trial. Health Educ Res. 1996;11:97–105. | Does not focus on counseling interventions
Kukkonen-Harjula KT, Borg PT, Nenonen AM, Fogelholm MG. Effects of a weight maintenance program with or without exercise on the metabolic syndrome: a randomized trial in obese men. Prev Med. 2005;41:784–790. | Primary aim is weight loss
Kuller LH, Kinzel LS, Pettee KK et al. Lifestyle intervention and coronary heart disease risk factor changes over 18 months in postmenopausal women: the Women On the Move through Activity and Nutrition (WOMAN study) clinical trial. Journal of Women’s Health. 2006;15:962–974. | Comparative-effectiveness
Kulzer B, Hermanns N, Gorges D, Schwarz P, Haak T. Prevention of diabetes self-management program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32:1143–1146. | Primary aim is weight loss
Lamb SE, Bartlett HP, Ashley A, Bird W. Can lay-led walking programmes increase physical activity in middle aged adults? A randomised controlled trial. Journal of Epidemiology & Community Health. 2002;56:246–252. | Comparative-effectiveness
Langford HG, Davis BR, Blaufox D et al. Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. The TAIM Research Group. Hypertension. 1991;17:210–217. | Intervention involves supervised physical activity or medications
Lee C, White SW. Controlled trial of a minimal-intervention exercise program for middle-aged working women. Psychology & Health. 1997;12:361–374. | Intervention involves supervised physical activity or medications
Leinonen R, Heikkinen E, Hirvensalo M et al. Customer-oriented counseling for physical activity in older people: study protocol and selected baseline results of a randomized-controlled trial (ISRCTN 07330512). Scandinavian Journal of Medicine & Science in Sports. 2007;17:156–164. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Leveille SG, Wagner EH, Davis C et al. Preventing disability and managing chronic illness in frail older adults: a randomized trial of a community-based partnership with primary care. J Am Geriatr Soc. 1998;46:1191–1198. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Liao D, Asberry PJ, Shofer JB et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. 2002;25:1504–1510. | Intervention involves supervised physical activity or medications
Life S, I, Pahor M, Blair SN et al. Effects of a physical activity intervention on measures of physical performance: Results of the lifestyle interventions and independence for Elders Pilot (LIFE-P) study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2006;61:1157–1165. | Intervention involves supervised physical activity or medications
Lin, P. H., Appel, L. J., Funk, K., Craddick, S., Chen, C., Elmer, P., McBurnie, M. A., and Champagne, C. The PREMIER intervention helps participants follow the Dietary Approaches to Stop Hypertension dietary pattern and the current Dietary Reference Intakes recommendations. Journal of the American Dietetic Association. 2007;107(9):1541–1551. | Comparative-effectiveness
Lindholm LH, Ekbom T, Dash C, Eriksson M, Tibblin G, Schersten B. The impact of health care advice given in primary care on cardiovascular risk. CELL Study Group. BMJ. 1995;310:1105–1109. | Population > 50% hypertension or dyslipidemia
Lindholm LH, Ekbom T, Dash C, Isacsson A, Schersten B. Changes in cardiovascular risk factors by combined pharmacological and nonpharmacological strategies: the main results of the CELL Study. J Intern Med. 1996;240:13–22. | Population > 50% hypertension or dyslipidemia
Lindström J, Eriksson JG, Valle TT et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. Journal of the American Society of Nephrology. 2003;14:S108–S113. | Intervention involves supervised physical activity or medications
Lindstrom J, Louheranta A, Mannelin M et al. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26:3230–3236. | Intervention involves supervised physical activity or medications
Little P, Dorward M, Gralton S et al. A randomised controlled trial of three pragmatic approaches to initiate increased physical activity in sedentary patients with risk factors for cardiovascular disease. Br J Gen Pract. 2004;54:189–195. | Population > 50% hypertension or dyslipidemia
Lombard DN, Lombard TN, Winett RA. Walking to meet health guidelines: the effect of prompting frequency and prompt structure. Health Psychol. 1995;14:164–170. | Comparative-effectiveness
Lowther M, Mutrie N, Scott EM. Promoting physical activity in a socially and economically deprived community: a 12 month randomized control trial of fitness assessment and exercise consultation. J Sports Sci. 2002;20:577–588. | High or differential attrition
Manty M, Heinonen A, Leinonen R et al. Long-term effect of physical activity counseling on mobility limitation among older people: a randomized controlled study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2009;64:83–89. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Marcus BH, Bock BC, Pinto BM, Forsyth LH, Roberts MB, Traficante RM. Efficacy of an individualized, motivationally-tailored physical activity intervention. Ann Behav Med. 1998;20:174–180. | Comparative-effectiveness
Marcus BH, Lewis BA, Williams DM et al. A comparison of Internet and print-based physical activity interventions. Arch Intern Med. 2007;167:944–949. | Comparative-effectiveness
Maruthur NM, Wang NY, Appel LJ. Lifestyle interventions reduce coronary heart disease risk: results from the PREMIER Trial. Circulation. 2009;119:2026–2031. | Comparative-effectiveness
Mayer JA, Jermanovich A, Wright BL, Elder JP, Drew JA, Williams SJ. Changes in health behaviors of older adults: the San Diego Medicare Preventive Health Project. Prev Med. 1994;23:127–133. | Does not focus on counseling interventions
Mayer-Davis EJ, Sparks KC, Hirst K et al. Dietary intake in the diabetes prevention program cohort: baseline and 1-year post randomization. Annals of Epidemiology. 2004;14:763–772. | Comparative-effectiveness
McAuley E, Jerome GJ, Elavsky S, Marquez DX, Ramsey SN. Predicting long-term maintenance of physical activity in older adults. Prev Med. 2003;37:110–118. | Comparative-effectiveness
McAuley E, Morris KS, Motl RW, Hu L, Konopack JF, Elavsky S. Long-term follow-up of physical activity behavior in older adults. Health Psychology. 2007;26:375–380. | Intervention involves supervised physical activity or medications
McGowan MP, Joffe A, Duggan AK, McCay PS. Intervention in hypercholesterolemic college students: a pilot study. J Adolesc Health. 1994;15:155–162. | Comparative-effectiveness
Meland E, Laerum E, Ulvik RJ. Effectiveness of two preventive interventions for coronary heart disease in primary care. Scand J Prim Health Care. 1997;15:57–64. | Population > 50% hypertension or dyslipidemia
Mensink M, Blaak EE, Corpeleijn E, Saris WH, de Bruin TW, Feskens EJ. Lifestyle intervention according to general recommendations improves glucose tolerance. Obesity Research. 2003;11:1588–1596. | Intervention involves supervised physical activity or medications
Mensink, M., Feskens, E. J. M., Saris, W. H. M., de Bruin, T. W. A., and Blaak, E. E. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): Preliminary results after one year. International Journal of Obesity. 2003;27(3):377–384. | Intervention involves supervised physical activity or medications
Michalowski J. The effects of a stage-matched intervention on physical activity and coronary heart disease risk factors in women West Lafayette, Indiana: Purdue University, 1999. | Less than 6 months of followup
Molitch ME, Fujimoto W, Hamman RF, Knowler WC, Diabetes-Prevention-Program-Research-Group. The diabetes prevention program and its global implications. Journal of the American Society of Nephrology. 2003;14:S103–S107. | Comparative-effectiveness
Morey MC, Sloane R, Pieper CF et al. Effect of physical activity guidelines on physical function in older adults. J Am Geriatr Soc. 2008;56:1873–1878. | Not an allowable study design
Morey, Miriam C., Dubbert, Patricia M., Doyle, Martha E., MacAller, Helga, Crowley, Gail M., Kuchibhatla, Maggie, Schenkman, Margaret, and Horner, Ronnie D. From Supervised to Unsupervised Exercise: Factors Associated With Exercise Adherence. Journal of Aging and Physical Activity. 2003;11(3):351–368. | Comparative-effectiveness
Muda SH, Kadir AA. The effectiveness of physical activity counseling in Primary Care Clinic University Science Malaysia Hospital. International Medical Journal. 2006;13:249–253. | Not on list of countries with HDI > 0.90
Munro JF, Nicholl JP, Brazier JE, Davey R, Cochrane T. Cost effectiveness of a community based exercise programme in over 65 year olds: cluster randomised trial. Journal of Epidemiology & Community Health. 2004;58:1004–1010. | Intervention involves supervised physical activity or medications
Napolitano MA, Papandonatos GD, Lewis BA et al. Mediators of physical activity behavior change: a multivariate approach. Health Psychology. 2008;27:409–418. | No relevant outcomes
Naylor PJ, Simmonds G, Riddoch C, Velleman G, Turton P. Comparison of stage-matched and unmatched interventions to promote exercise behaviour in the primary care setting. Health Educ Res. 1999;14:653–666. | High or differential attrition
Neville LM, O’Hara B, Milat A. Computer-tailored physical activity behavior change interventions targeting adults: a systematic review. International Journal of Behavioral Nutrition & Physical Activity. 2009;6:30. | Not an allowable study design
Newton RL, Jr., Perri MG. A randomized pilot trial of exercise promotion in sedentary African-American adults. Ethnicity & Disease. 2004;14:548–557. | High or differential attrition
Nichols, G. Testing a culturally consistent behavioral outcomes strategy for cardiovascular disease risk reduction and prevention in low income African American women. Unpublished doctoral dissertation, Univ of Maryland. 1995. | Less than 6 months of followup
Nies MA, Chruscial HL, Hepworth JT. An intervention to promote walking in sedentary women in the community. American Journal of Health Behavior. 2003;27:524–535. | Comparative-effectiveness
Nilsson PM, Lindholm LH, Schersten BF. Life style changes improve insulin resistance in hyperinsulinaemic subjects: a one-year intervention study of hypertensives and normotensives in Dalby. J Hypertens. 1992;10:1071–1078. | Population > 50% hypertension or dyslipidemia
No, authorship indicated. Promoting physical activity in an at-risk population. J Sport Exerc Psychol. 2008;30(3):434. | Not an allowable study design
Norris SL, Zhang X, Avenell A et al. Long-term effectiveness of weight-loss interventions in adults with pre-diabetes: a review. Am J Prev Med. 2005;28:126–139. | Not an allowable study design
ODES Investigators. The Oslo Diet and Exercise Study (ODES): design and objectives. Control Clin Trials. 1993;14:229–243. | Population > 50% hypertension or dyslipidemia
O’Halloran, Peggy, Lazovich, DeAnn, Patterson, Ruth E., Harnack, Lisa, French, Simone, Curry, Sue J., and Beresford, Shirley A. A. Effect of health lifestyle pattern on dietary change. Am J Health Promot. 2001;16(1):27–33. | Not one of specified interventions
Ohkubo T, Hozawa A, Nagatomi R et al. Effects of exercise training on home blood pressure values in older adults: a randomized controlled trial. J Hypertens. 2001;19:1045–1052. | Intervention involves supervised physical activity or medications
Oida Y, Kitabatake Y, Nishijima Y et al. Effects of a 5-year exercise-centered health-promoting programme on mortality and ADL impairment in the elderly. Age & Ageing. 2003;32:585–592. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Opdenacker J, Boen F, Coorevits N, Delecluse C. Effectiveness of a lifestyle intervention and a structured exercise intervention in older adults. Prev Med. 2008;46:518–524. | Intervention involves supervised physical activity or medications
Opdenacker J, Boen F, Vanden AY, De B, I. Effectiveness of a lifestyle physical activity intervention in a women’s organization. Journal of Women’s Health. 2008;17:413–421. | High or differential attrition
Pakkala I, Read S, Leinonen R, Hirvensalo M, Lintunen T, Rantanen T. The effects of physical activity counseling on mood among 75- to 81-year-old people: a randomized controlled trial. Prev Med. 2008;46:412–418. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Park SK, Park JH, Kwon YC, Kim HS, Yoon MS, Park HT. The effect of combined aerobic and resistance exercise training on abdominal fat in obese middle-aged women. Journal of Physiological Anthropology & Applied Human Science. 2003;22:129–135. | Intervention involves supervised physical activity or medications
Pekmezi D, Barbera B, Bodenlos JS, Jones GN, Brantley PJ. Promoting physical activity in low income African Americans: Six month results from Project LAPS. Ann Behav Med. 2008;35:S117. | High or differential attrition
Pereira MA, Kriska AM, Day RD, Cauley JA, LaPorte RE, Kuller LH. A randomized walking trial in postmenopausal women: effects on physical activity and health 10 years later. Arch Intern Med. 1998;158:1695–1701. | Intervention involves supervised physical activity or medications
Pereira, R. F. Franz M. J. Prevention and Treatment of Cardiovascular Disease in People With Diabetes Through Lifestyle Modification: Current Evidence-Based Recommendations. Diabetes Spectr. 2008;21:189–193. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Perkio-Makela M. Influence of exercise-focused group activities on the physical activity, functional capacity, and work ability of female farmers--a three-year follow-Up. Int J Occup Saf Ergon. 1999;5:381–394. | Intervention involves supervised physical activity or medications
Petrella RJ, Koval JJ, Cunningham DA, Paterson DH. Can primary care doctors prescribe exercise to improve fitness? The Step Test Exercise Prescription (STEP) project. Am J Prev Med. 2003;24:316–322. | Comparative-effectiveness
Pfeffer, Ines and Alfermann, Dorothee. Initiation of physical exercise: An intervention study based on the transtheoretical model. International Journal of Sport Psychology. 2008;39(1):41–58. | Comparative-effectiveness
Pinto BM, Lynn H, Marcus BH, DePue J, Goldstein MG. Physician-based activity counseling: intervention effects on mediators of motivational readiness for physical activity. Ann Behav Med. 2001;23:2–10. | No relevant outcomes
Pollock ML, Carroll JF, Graves JE et al. Injuries and adherence to walk/jog and resistance training programs in the elderly. Med Sci Sports Exerc. 1991;23:1194–1200. | Intervention involves supervised physical activity or medications
Potteiger JA, Jacobsen DJ, Donnelly JE, Hill JO, Midwest ET. Glucose and insulin responses following 16 months of exercise training in overweight adults: the Midwest Exercise Trial. Metabolism: Clinical & Experimental. 2003;52:1175–1181. | Intervention involves supervised physical activity or medications
Ramachandran A, Snehalatha C, Mary S, Mukesh B, Bhaskar AD, Vijay V. The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006;49:289–297. | Not on list of countries with HDI > 0.90
Randomised controlled trial evaluating cardiovascular screening and intervention in general practice: principal results of British family heart study. Family Heart Study Group. BMJ. 1994;308:313–320. | Other quality issues
Rankinen T, Rauramaa R, Vaisanen SB, Halonen JP, Penttila IM. Blood coagulation and fibrinolytic factors are unchanged by aerobic exercise or fat modified diet. Randomized clinical trial in middle-aged men. Fibrinolysis. 1994;8:48–53. | Comparative-effectiveness
Ratner R, Goldberg R, Haffner S et al. Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care. 2005;28:888–894. | Comparative-effectiveness
Ratner RE, Christophi CA, Metzger BE et al. Prevention of diabetes in women with a history of gestational diabetes: effects of metformin and lifestyle interventions. Journal of Clinical Endocrinology & Metabolism. 2008;93:4774–4779. | Comparative-effectiveness
Reed J, Malvern L, Muthukrishnan S, Hardy R, King L. An ecological approach with primary-care counseling to promote physical activity. Journal of Physical Activity & Health. 2008;5:169–183. | Less than 6 months of followup
Rejeski W, Brawley L. Shaping active lifestyles in older adults: a group-facilitated behavior change intervention. Ann Behav Med. 1997;19:s106. | Poor reporting
Reseland JE, Anderssen SA, Solvoll K et al. Effect of long-term changes in diet and exercise on plasma leptin concentrations. Am J Clin Nutr. 2001;73:240–245. | Intervention involves supervised physical activity or medications
Resnick B. Testing the effect of the WALC intervention on exercise adherence in older adults. Journal of Gerontological Nursing. 2002;28:40–49. | Setting not primary care or generalizable to primary care
Richardson, Amanda Hope. A comparison of physician based exercise counseling protocols: A pilot study. Does physical activity counseling provided by a physician in the form of verbal, written or combination delivery increase physical activity in a sedentary geriatric population? Dissertation Abstracts International: Section B: The Sciences and Engineering 68(8-B), 5180. 2008. | Less than 6 months of followup
Rose SB, Lawton BA, Elley CR, Dowell AC, Fenton AJ. The ‘Women’s Lifestyle Study’, 2-year randomized controlled trial of physical activity counselling in primary health care: rationale and study design. BMC Public Health. 2007;7:166. | No relevant outcomes
Roumen C, Corpeleijn E, Feskens EJ, Mensink M, Saris WH, Blaak EE. Impact of 3-year lifestyle intervention on postprandial glucose metabolism: the SLIM study. Diabetic Medicine. 2008;25:597–605. | Intervention involves supervised physical activity or medications
Roussel M, Garnier S, Lemoine S et al. Influence of a walking program on the metabolic risk profile of obese postmenopausal women. Menopause. 2009;16:566–575. | Intervention involves supervised physical activity or medications
Rydwik E, Lammes E, Frandin K, Akner G. Effects of a physical and nutritional intervention program for frail elderly people over age 75. A randomized controlled pilot treatment trial. Aging-Clinical & Experimental Research. 2008;20:159–170. | Biased recruitment strategy or selection of patients not generalizable to primary care
Salkeld G, Phongsavan P, Oldenburg B et al. The cost-effectiveness of a cardiovascular risk reduction program in general practice. Health Policy. 1997;41:105–119. | Population > 50% hypertension or dyslipidemia
Sallinen J, Fogelholm M, Pakarinen A et al. Effects of strength training and nutritional counseling on metabolic health indicators in aging women. Canadian Journal of Applied Physiology. 2005;30:690–707. | Less than 6 months of followup
Sallis JF, Patrick K, Calfas KJ et al. A multi-media behavior change program for nutrition and physical activity in primary care: PACE+ for adults. Homeostasis. 1999;39:196–202. | Less than 6 months of followup
Sevick MA, Napolitano MA, Papandonatos GD, Gordon AJ, Reiser LM, Marcus BH. Cost-effectiveness of alternative approaches for motivating activity in sedentary adults: results of Project STRIDE. Prev Med. 2007;45:54–61. | No relevant outcomes
Slootmaker SM, Chinapaw MJ, Schuit AJ, Seidell JC, van MW. Feasibility and effectiveness of online physical activity advice based on a personal activity monitor: randomized controlled trial. Journal of Medical Internet Research. 2009;11:e27. | Setting not primary care or generalizable to primary care
Smith BJ, Bauman AE, Bull FC, Booth ML, Harris MF. Promoting physical activity in general practice: a controlled trial of written advice and information materials. Br J Sports Med. 2000;34:262–267. | Other quality issues
Staffileno BA, Minnick A, Coke LA, Hollenberg SM. Blood pressure responses to lifestyle physical activity among young, hypertension-prone African-American women. Journal of Cardiovascular Nursing. 2007;22:107–117. | Less than 6 months of followup
Stamler J, Briefel RR, Milas C, Grandits GA, Caggiula AW. Relation of changes in dietary lipids and weight, trial years 1–6, to changes in blood lipids in the special intervention and usual care groups in the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65:272S–288S. | Population > 50% hypertension or dyslipidemia
Staten, Lisa K., Gregory-Mercado, Karen Y., Ranger-Moore, James, Will, Julie C., Giuliano, Anna R., Ford, Earl S., and Marshall, James. Provider Counseling, Health Education, and Community Health Workers: The Arizona WISEWOMAN Project. Journal of Women’s Health. 2004;13(5):547–556. | Comparative-effectiveness
Stefanick ML, Mackey S, Sheehan M, Ellsworth N, Haskell WL, Wood PD. Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339:12–20. | Intervention involves supervised physical activity or medications
Stevens W, Hillsdon M, Thorogood M, McArdle D. Cost-effectiveness of a primary care based physical activity intervention in 45–74 year old men and women: a randomised controlled trial. Br J Sports Med. 1998;32:236–241. | Poor reporting
Stoddard AM, Palombo R, Troped PJ, Sorensen G, Will JC. Cardiovascular disease risk reduction: the Massachusetts WISEWOMAN project. Journal of women’s health. 2004;13:539–546. | Comparative-effectiveness
Strandberg TE, Salomaa VV, Naukkarinen VA, Vanhanen HT, Sarna SJ, Miettinen TA. Long-term mortality after 5-year multifactorial primary prevention of cardiovascular diseases in middle-aged men. JAMA. 1991;266:1225–1229. | Population > 50% hypertension or dyslipidemia
Strandberg TE, Salomaa VV, Vanhanen HT, Naukkarinen VA, Sarna SJ, Miettinen TA. Mortality in participants and non-participants of a multifactorial prevention study of cardiovascular diseases: a 28 year follow up of the Helsinki Businessmen Study. Br Heart J. 1995;74:449–454. | Population > 50% hypertension or dyslipidemia
Sugiura H, Sugiura H, Kajima K, Mirbod SM, Iwata H, Matsuoka T. Effects of long-term moderate exercise and increase in number of daily steps on serum lipids in women: Randomised controlled trial. BMC Women’s Health. 2002;2:3. | Intervention involves supervised physical activity or medications
Taylor AH, Doust J, Webborn N. Randomised controlled trial to examine the effects of a GP exercise referral programme in Hailsham, East Sussex, on modifiable coronary heart disease risk factors. J Epidemiol Community Health. 1998;52:595–601. | High or differential attrition
Taylor AH, Fox KR. Effectiveness of a primary care exercise referral intervention for changing physical self-perceptions over 9 months. Health Psychology. 2005;24:11–21. | High or differential attrition
The Diabetes Prevention Program. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22:623–634. | Comparative-effectiveness
The Diabetes Prevention Program: baseline characteristics of the randomized cohort. The Diabetes Prevention Program Research Group. Diabetes Care. 2000;23:1619–1629. | Comparative-effectiveness
The WISEWOMAN Workgroup. Cardiovascular disease prevention for women attending breast and cervical cancer screening programs: the WISEWOMAN projects. Prev Med. 1999;28:496–502. | Comparative-effectiveness
Toft U, Kristoffersen L, Ladelund S et al. The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake. The Inter99 study - a randomized controlled trial. International Journal of Behavioral Nutrition & Physical Activity. 2008;5:59. | Population > 50% hypertension or dyslipidemia
Toft U, Kristoffersen L, Ladelund S et al. The impact of a population-based multi-factorial lifestyle intervention on changes in long-term dietary habits The Inter99 study. Prev Med. 2008. | Population > 50% hypertension or dyslipidemia
Tulloch H, Fortier M, Hogg W. Physical activity counseling in primary care: who has and who should be counseling? Patient Educ Couns. 2006;64(1–3):6–20. | Not an allowable study design
Tully MA, Cupples ME, Chan WS, McGlade K, Young IS. Brisk walking, fitness, and cardiovascular risk: a randomized controlled trial in primary care. Prev Med. 2005;41:622–628. | Less than 6 months of followup
Tuomilehto J, Lindstrom J, Eriksson JG et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. New England Journal of Medicine. 2001;344:1343–1350. | Intervention involves supervised physical activity or medications
van Steenkiste B, van-der Weijden T, Stoffers HE, Kester AD, Timmermans DR, Grol R. Improving cardiovascular risk management: a randomized, controlled trial on the effect of a decision support tool for patients and physicians. European journal of cardiovascular prevention and rehabilitation : official journal of the European Society of Cardiology, Working Groups on Epidemiology & Prevention and Cardiac Rehabilitation and Exercise Physiology. 2007;14:44–50. | Other quality issues
Vandelanotte C, Spathonis KM, Eakin EG, Owen N. Website-delivered physical activity interventions a review of the literature. Am J Prev Med. 2007;33:54–64. | Not an allowable study design
Veverka DV, Anderson J, Auld GW, Coulter GR, Kennedy C, Chapman PL. Use of the stages of change model in improving nutrition and exercise habits in enlisted Air Force men. Military Medicine. 2003;168:373–379. | Biased recruitment strategy or selection of patients not generalizable to primary care
Villareal DT, Miller BV, III, Banks M, Fontana L, Sinacore DR, Klein S. Effect of lifestyle intervention on metabolic coronary heart disease risk factors in obese older adults. Am J Clin Nutr. 2006;84:1317–1323. | Primary aim is weight loss
Wassertheil-Smoller S, Oberman A, Blaufox MD, Davis B, Langford H. The Trial of Antihypertensive Interventions and Management (TAIM) Study. Final results with regard to blood pressure, cardiovascular risk, and quality of life. Am J Hypertens. 1992;5:37–44. | Population > 50% hypertension or dyslipidemia
Whelton PK, Appel LJ, Espeland MA et al. Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). TONE Collaborative Research Group. JAMA. 1998;279:839–846. | Not one of specified interventions
Whitehead D, Bodenlos JS, Cowles ML, Jones GN, Brantley PJ. A stage-targeted physical activity intervention among a predominantly African-American low-income primary care population. Am J Health Promot. 2007;21:160–163. | High or differential attrition
Whiteley, Jessica Ann. An internet-based walking program for women. Dissertation Abstracts International: Section B: The Sciences and Engineering 64(6-B), 2946. 2003. | Less than 6 months of followup
Wilbur J, McDevitt JH, Wang E et al. Outcomes of a home-based walking program for African-American women. Am J Health Promot. 2008;22:307–317. | Comparative-effectiveness
Wilbur J, Miller AM, McDevitt J, Wang E, Miller J. Menopausal status, moderate-intensity walking, and symptoms in midlife women. Research & Theory for Nursing Practice. 2005;19:163–180. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Wildman RP, Schott LL, Brockwell S, Kuller LH, Sutton-Tyrrell K. A dietary and exercise intervention slows menopause-associated progression of subclinical atherosclerosis as measured by intima-media thickness of the carotid arteries. Journal of the American College of Cardiology. 2004;44:579–585. | No relevant outcomes
Will JC, Massoudi B, Mokdad A et al. Reducing risk for cardiovascular disease in uninsured women: combined results from two WISEWOMAN projects. Journal of the American Medical Women’s Association. 2001;56:161–165. | Comparative-effectiveness
Williams NH, Hendry M, France B, Lewis R, Wilkinson C. Effectiveness of exercise-referral schemes to promote physical activity in adults: systematic review. Br J Gen Pract. 2007;57:979–986. | Not an allowable study design
Williamson JD, Espeland M, Kritchevsky SB et al. Changes in cognitive function in a randomized trial of physical activity: results of the lifestyle interventions and independence for elders pilot study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2009;64:688–694. | Not one of specified interventions
Wing RR, Venditti E, Jakicic JM, Polley BA, Lang W. Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21:350–359. | Primary aim is weight loss
Woods C, Mutrie N, Scott M. Physical activity intervention: a transtheoretical model-based intervention designed to help sedentary young adults become active. Health Education Research. 2002;17:451–460. | No relevant outcomes
Writing Group for the Activity Counseling Trial Research Group. Effects of physical activity counseling in primary care: the Activity Counseling Trial: a randomized controlled trial. JAMA. 2001;286:677–687. | Comparative-effectiveness
Wylie-Rosett J, Wassertheil-Smoller S, Blaufox MD et al. Trial of antihypertensive intervention and management: greater efficacy with weight reduction than with a sodium-potassium intervention. J Am Diet Assoc. 1993;93:408–415. | Not one of specified interventions
Yates T, Davies M, Gorely T et al. Twelve-month follow-up from the PREPARE (Prediabetes Risk Education and Physical Activity Recommendation and Encouragement) programme study: a randomized controlled trial: A47 (P427). Diabetic Medicine. 2009;26:17. | No relevant outcomes
Young DR, King AC, Sheehan M, Stefanick ML. Stage of motivational readiness: predictive ability for exercise behavior. American Journal of Health Behavior. 2002;26:331–341. | Population > 50% hypertension or dyslipidemia

Appendix D Table 4 Physical Activity Studies Excluded From the Review for Key Question 4

Reference | Reason for exclusion
Boyd NF, Greenberg C, Lockwood G et al. Effects at two years of a low-fat, high-carbohydrate diet on radiologic features of the breast: results from a randomized trial. Canadian Diet and Breast Cancer Prevention Study Group. J Natl Cancer Inst. 1997;89:488–496. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Durakovic Z, Misigoj-Durakovic M, Medved R, Skavic J, Torovic N. Sudden death due to physical exercise in the elderly. Collegium Antropologicum. 2002;26:239–243. | Poor reporting
Durakovic Z, Misigoj-Durakovic M, Skavic J. Sudden death due to recreational exercise in physicians. Collegium Antropologicum. 2002;26:509–513. | Poor reporting
Ferrer RL, Mody-Bailey P, Jaen CR, Gott S, Araujo S. A medical assistant- based program to promote healthy behaviors in primary care. Ann Fam Med. 2009;7:504–512. | High or differential attrition
Geleijnse JM, Witteman JC, Bak AA, den Breeijen JH, Grobbee DE. Long- term moderate sodium restriction does not adversely affect the serum HDL/total cholesterol ratio. J Hum Hypertens. 1995;9:975–979. | Population > 50% hypertension or dyslipidemia
Goodrich DE, Larkin AR, Lowery JC, Holleman RG, Richardson CR. Adverse events among high-risk participants in a home-based walking study: a descriptive study. International Journal of Behavioral Nutrition & Physical Activity. 2007;4:20. | Intervention involves supervised physical activity or medications
Hislop TG, Bajdik CD, Balneaves LG et al. Physical and emotional health effects and social consequences after participation in a low-fat, high- carbohydrate dietary trial for more than 5 years. Journal of Clinical Oncology. 2006;24:2311–2317. | Intervention meets criteria but specifically targets a non-cardiovascular-related condition
Manninen P, Riihimaki H, Heliovaara M, Suomalainen O. Physical exercise and risk of severe knee osteoarthritis requiring arthroplasty. Rheumatology. 2001;40:432–437. | Not an allowable study design
Mozaffarian D, Furberg CD, Psaty BM, Siscovick D. Physical activity and incidence of atrial fibrillation in older adults: the cardiovascular health study. Circulation. 2008;118:800–807. | Does not focus on counseling interventions
Pollock ML, Carroll JF, Graves JE et al. Injuries and adherence to walk/jog and resistance training programs in the elderly. Med Sci Sports Exerc. 1991;23:1194–1200. | Intervention involves supervised physical activity or medications
Pons-Villanueva J, Segui-Gomez M, Martinez-Gonzalez MA. Risk of injury according to participation in specific physical activities: a 6-year follow-up of 14 356 participants of the SUN cohort. Int J Epidemiol. 2009; 1–8. | Not an allowable study design
Reddy PR, Reinier K, Singh T et al. Physical activity as a trigger of sudden cardiac arrest: the Oregon Sudden Unexpected Death Study. International Journal of Cardiology. 2009;131:345–349. | Does not focus on counseling interventions
Thompson PD, Funk EJ, Carleton RA, Sturner WQ. Incidence of death during jogging in Rhode Island from 1975 through 1980. JAMA. 1982;247:2535–2538. | Not an allowable study design
van Teeffelen WM, de Beus MF, Mosterd A et al. Risk factors for exercise-related acute cardiac events. A case-control study. Br J Sports Med. 2009;43:722–725. | Does not focus on counseling interventions

Appendix D Table 5 Combination Lifestyle Studies Excluded From the Review for Key Questions 1–3

Reference | Reason for exclusion
Block G, Sternfeld B, Block CH et al. Development of Alive! (A Lifestyle Intervention Via Email), and its effect on health-related quality of life, presenteeism, and other behavioral outcomes: randomized controlled trial. Journal of Medical Internet Research. 2008;10:e43. | High or differential attrition
Greene GW, Fey-Yensan N, Padula C, Rossi SR, Rossi JS, Clark PG. Change in fruit and vegetable intake over 24 months in older adults: results of the SENIOR project intervention. Gerontologist. 2008;48:378–387. | No relevant outcomes
Hilton S, Doherty S, Kendrick T, Kerry S, Rink E, Steptoe A. Promotion of healthy behaviour among adults at increased risk of coronary heart disease in general practice: methodology and baseline data from the Change of Heart study. Health Education Journal. 1999;58:3–16. | High or differential attrition
Jilcott SB, Keyserling TC, Samuel-Hodge CD et al. Linking clinical care to community resources for cardiovascular disease prevention: the North Carolina Enhanced WISEWOMAN project. Journal of Women's Health. 2006;15:569–583. | No relevant outcomes
Lombard CB, Deeks AA, Ball K, Jolley D, Teede HJ. Weight, physical activity and dietary behavior in young mothers: short term results of the HeLP-her cluster randomized controlled trial. Nutrition Journal. 2009;8:17. | Less than 6 months of followup
Merrill RM, Aldana SG, Ellrodt G, Orsi R, Grelle-Laramee J. Efficacy of the Berkshire Health System Cardiovascular Health Risk Reduction Program. Journal of Occupational & Environmental Medicine. 2009;51:1024–1031. | Not an allowable study design
Narayan KM, Hoskin M, Kozak D et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15:66–72. | Comparative-effectiveness
Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53:311–316. | High or differential attrition
Rosamond WD, Ammerman AS, Holliday JL et al. Cardiovascular disease risk factor intervention in low-income women: the North Carolina WISEWOMAN project. Prev Med. 2000;2000:370–379. | Population > 50% hypertension or dyslipidemia
Steptoe A, Doherty S, Rink E, Kerry S, Kendrick T, Hilton S. Behavioural counselling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial. BMJ. 1999;319:943–947. | High or differential attrition
Steptoe A, Kerry S, Rink E, Hilton S. The impact of behavioral counseling on stage of change in fat intake, physical activity, and cigarette smoking in adults at increased risk of coronary heart disease. Am J Public Health. 2001;91:265–269. | High or differential attrition
Sternfeld B, Block C, Quesenberry CP, Jr. et al. Improving diet and physical activity with ALIVE: a worksite randomized trial. Am J Prev Med. 2009;36:475–483. | High or differential attrition
Svetkey LP, Pollak KI, Yancy WS, Jr. et al. Hypertension improvement project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54:1226–1233. | Population > 50% hypertension or dyslipidemia
Tuomilehto J. Nonpharmacologic therapy and exercise in the prevention of type 2 diabetes. Diabetes Care. 2009;32:Suppl-93. | Not an allowable study design
Voils CI, Yancy WS, Jr., Kovac S et al. Study protocol: Couples Partnering for Lipid Enhancing Strategies (CouPLES) - a randomized, controlled trial. Trials [Electronic Resource]. 2009;10:10. | No relevant outcomes