# Evidence Tables

Appendix C Table 1 Physical Activity Counseling Evidence Table

Appendix C Table 2 Healthful Diet Counseling Evidence Table

Appendix C Table 3 Healthy Lifestyle Counseling Evidence Table

Appendix C Table 4 Evidence of Serious Harms Associated With Physical Activity Counseling: Case-Crossover Analyses of Exertion-Related Acute Cardiac Events

Author, year Country Quality | Subject Characteristics | Event N, Ascertainment | Results
Albert, 2000^133^ Finland Fair | Participants of Physicians’ Health Study (n=21,481) 100% men Mean age 60.5 10.7% diabetes 8.2% hyperlipidemia 32.5% hypertension 0% previous MI | N=122 sudden deaths from cardiac causes, 23 (18.8%) related to vigorous exertion Outcome from medical records with independent review and next of kin PA determined by self-report questionnaire, followup time NR | Incidence of sudden death associated with vigorous exertion: 1/1.42 million person-hours of exertion (n=12,481) RR of sudden death associated with vigorous exertion, by frequency of habitual exercise:
Albert, 2000^133^ Finland Fair | Participants of Physicians’ Health Study (n=21,481) 100% men Mean age 60.5 10.7% diabetes 8.2% hyperlipidemia 32.5% hypertension 0% previous MI | | [underlined: Habitual Exercise] | [underlined: RR (95% CI)]
Albert, 2000^133^ Finland Fair | Participants of Physicians’ Health Study (n=21,481) 100% men Mean age 60.5 10.7% diabetes 8.2% hyperlipidemia 32.5% hypertension 0% previous MI | | <1 times/week | 74.1 (22.0, 249)
Albert, 2000^133^ Finland Fair | Participants of Physicians’ Health Study (n=21,481) 100% men Mean age 60.5 10.7% diabetes 8.2% hyperlipidemia 32.5% hypertension 0% previous MI | | 1–4 times/week | 18.9 (10.2, 35.1)
Albert, 2000^133^ Finland Fair | Participants of Physicians’ Health Study (n=21,481) 100% men Mean age 60.5 10.7% diabetes 8.2% hyperlipidemia 32.5% hypertension 0% previous MI | | ≥5 times/week | 10.6 (4.5, 26.2)
Albert, 2000^133^ Finland Fair | Participants of Physicians’ Health Study (n=21,481) 100% men Mean age 60.5 10.7% diabetes 8.2% hyperlipidemia 32.5% hypertension 0% previous MI | | All | 16.9 (10.5, 27.0)
Giri 1999^134^ US Fair | Patients with MI treated with primary angioplasty in study hospital 57% men Mean age 60.8 18.1% diabetes 42.2% hyperlipidemia 44.8% hypertension 25.0% coronary artery disease | N=640 MIs, 64 (10%) related to vigorous exertion Outcome from medication records during hospitalization with independent review PA determined through structured interview in hospital | RR of MI associated with vigorous exertion, by habitual activity level:
Giri 1999^134^ US Fair | Patients with MI treated with primary angioplasty in study hospital 57% men Mean age 60.8 18.1% diabetes 42.2% hyperlipidemia 44.8% hypertension 25.0% coronary artery disease | N=640 MIs, 64 (10%) related to vigorous exertion Outcome from medication records during hospitalization with independent review PA determined through structured interview in hospital | [underlined: Habitual Activity] | [underlined: RR (95% CI)]
Giri 1999^134^ US Fair | Patients with MI treated with primary angioplasty in study hospital 57% men Mean age 60.8 18.1% diabetes 42.2% hyperlipidemia 44.8% hypertension 25.0% coronary artery disease | N=640 MIs, 64 (10%) related to vigorous exertion Outcome from medication records during hospitalization with independent review PA determined through structured interview in hospital | Very low | 30.5 (4.4, 209.9)
Giri 1999^134^ US Fair | Patients with MI treated with primary angioplasty in study hospital 57% men Mean age 60.8 18.1% diabetes 42.2% hyperlipidemia 44.8% hypertension 25.0% coronary artery disease | N=640 MIs, 64 (10%) related to vigorous exertion Outcome from medication records during hospitalization with independent review PA determined through structured interview in hospital | Low | 20.9 (3.1, 142.1)
Giri 1999^134^ US Fair | Patients with MI treated with primary angioplasty in study hospital 57% men Mean age 60.8 18.1% diabetes 42.2% hyperlipidemia 44.8% hypertension 25.0% coronary artery disease | N=640 MIs, 64 (10%) related to vigorous exertion Outcome from medication records during hospitalization with independent review PA determined through structured interview in hospital | Moderate | 2.9 (0.5, 15.9)
Giri 1999^134^ US Fair | Patients with MI treated with primary angioplasty in study hospital 57% men Mean age 60.8 18.1% diabetes 42.2% hyperlipidemia 44.8% hypertension 25.0% coronary artery disease | N=640 MIs, 64 (10%) related to vigorous exertion Outcome from medication records during hospitalization with independent review PA determined through structured interview in hospital | High | 1.2 (0.3, 5.2)
Giri 1999^134^ US Fair | Patients with MI treated with primary angioplasty in study hospital 57% men Mean age 60.8 18.1% diabetes 42.2% hyperlipidemia 44.8% hypertension 25.0% coronary artery disease | N=640 MIs, 64 (10%) related to vigorous exertion Outcome from medication records during hospitalization with independent review PA determined through structured interview in hospital | All | 10.1 (1.56, 65.6)
Hallqvist, 2000^135^ Sweden Fair | Survivors of an incident MI in a single county in Sweden 76.8% men Mean age 49 26.2% diabetes 35.4% hypertension 0% previous MI | N=660 MIs, 42 (6.4%) related to vigorous exertion Outcome from medical records and/or death certificates, plus structured interview in hospital or soon after discharge PA determined through structured interview in hospital or soon after discharge | RR of MI associated with vigorous exertion: 3.3 (2.4, 4.5) RR of MI associated with vigorous exertion, by habitual activity level, among those without premonitory symptoms (n=399, 27 with vigorous exertion):
Hallqvist, 2000^135^ Sweden Fair | Survivors of an incident MI in a single county in Sweden 76.8% men Mean age 49 26.2% diabetes 35.4% hypertension 0% previous MI | | [underlined: Habitual Activity] | [underlined: RR (95% CI)]
Hallqvist, 2000^135^ Sweden Fair | Survivors of an incident MI in a single county in Sweden 76.8% men Mean age 49 26.2% diabetes 35.4% hypertension 0% previous MI | | Very little | 54.7 (13.7, 218.4)
Hallqvist, 2000^135^ Sweden Fair | Survivors of an incident MI in a single county in Sweden 76.8% men Mean age 49 26.2% diabetes 35.4% hypertension 0% previous MI | | Sporadic Walks | 4.6 (1.7, 12.5)
Hallqvist, 2000^135^ Sweden Fair | Survivors of an incident MI in a single county in Sweden 76.8% men Mean age 49 26.2% diabetes 35.4% hypertension 0% previous MI | | Occasional | 2.3 (0.9, 6.0)
Hallqvist, 2000^135^ Sweden Fair | Survivors of an incident MI in a single county in Sweden 76.8% men Mean age 49 26.2% diabetes 35.4% hypertension 0% previous MI | | Regular | 12.1 (6.8, 21.4)
Mittleman, 1993^136^ US Fair | Patients from coronary care units 68% men Mean age 62 19% diabetes 44% hypertension 29% previous MI | N=1228 MIs, 54 (4.4%) related to vigorous exertion Outcome from medical records with independent review, plus structured interview in hospital or soon after discharge PA determined through structured interview in hospital or soon after discharge | RR of MI associated with vigorous exertion, by frequency of habitual exercise:
Mittleman, 1993^136^ US Fair | Patients from coronary care units 68% men Mean age 62 19% diabetes 44% hypertension 29% previous MI | | [underlined: Habitual Exercise] | [underlined: RR (95% CI)]
Mittleman, 1993^136^ US Fair | Patients from coronary care units 68% men Mean age 62 19% diabetes 44% hypertension 29% previous MI | | <1 times/week | 107 (67, 171)
Mittleman, 1993^136^ US Fair | Patients from coronary care units 68% men Mean age 62 19% diabetes 44% hypertension 29% previous MI | | 1–2 times/week | 19.4 (9.9, 38.1)
Mittleman, 1993^136^ US Fair | Patients from coronary care units 68% men Mean age 62 19% diabetes 44% hypertension 29% previous MI | | 3–4 times/week | 8.6 (3.6, 20.5)
Mittleman, 1993^136^ US Fair | Patients from coronary care units 68% men Mean age 62 19% diabetes 44% hypertension 29% previous MI | | ≥5 times/week | 2.4 (1.5, 3.7)
Mittleman, 1993^136^ US Fair | Patients from coronary care units 68% men Mean age 62 19% diabetes 44% hypertension 29% previous MI | | All | 5.9 (4.6, 7.7)
Siscovick, 1984^137^ US Fair | Married men with out-of-hospital incident cardiac arrest requiring EMS 100% men Mean age NR Risk factors NR 0% heart disease | N=133 MIs, 9 (6.8%) related to vigorous exertion Outcome from paramedics reports PA determined through structured interview with wives | RR of MI associated with vigorous exertion, by habitual minutes/week of activity:
Siscovick, 1984^137^ US Fair | Married men with out-of-hospital incident cardiac arrest requiring EMS 100% men Mean age NR Risk factors NR 0% heart disease | N=133 MIs, 9 (6.8%) related to vigorous exertion Outcome from paramedics reports PA determined through structured interview with wives | [underlined: Habitual Activity] | [underlined: RR (95% CI)]
Siscovick, 1984^137^ US Fair | Married men with out-of-hospital incident cardiac arrest requiring EMS 100% men Mean age NR Risk factors NR 0% heart disease | N=133 MIs, 9 (6.8%) related to vigorous exertion Outcome from paramedics reports PA determined through structured interview with wives | 0 | (no events during exertion)
Siscovick, 1984^137^ US Fair | Married men with out-of-hospital incident cardiac arrest requiring EMS 100% men Mean age NR Risk factors NR 0% heart disease | N=133 MIs, 9 (6.8%) related to vigorous exertion Outcome from paramedics reports PA determined through structured interview with wives | 1–19 | 56 (23, 131)
Siscovick, 1984^137^ US Fair | Married men with out-of-hospital incident cardiac arrest requiring EMS 100% men Mean age NR Risk factors NR 0% heart disease | N=133 MIs, 9 (6.8%) related to vigorous exertion Outcome from paramedics reports PA determined through structured interview with wives | 20–139 | 13 (5, 32)
Siscovick, 1984^137^ US Fair | Married men with out-of-hospital incident cardiac arrest requiring EMS 100% men Mean age NR Risk factors NR 0% heart disease | N=133 MIs, 9 (6.8%) related to vigorous exertion Outcome from paramedics reports PA determined through structured interview with wives | ≥140 | 5 (2, 14)
von Klot, 2008^138^ Germany Fair | Patients hospitalized by MI in any area hospital, 77% men Median age 61 26% diabetes 72% hypertension 15% previous MI | N=1301 MIs, 90(6.9%) related to vigorous exertion Outcome from medical records with independent review, plus structured interview in hospital or soon after discharge PA determined through structured interview in hospital or soon after discharge | RR of MI associated with vigorous exertion, by habitual minutes/week of activity of at least moderate-intensity):
von Klot, 2008^138^ Germany Fair | Patients hospitalized by MI in any area hospital, 77% men Median age 61 26% diabetes 72% hypertension 15% previous MI | | [underlined: Habitual Activity] | [underlined: RR (95% CI)]
von Klot, 2008^138^ Germany Fair | Patients hospitalized by MI in any area hospital, 77% men Median age 61 26% diabetes 72% hypertension 15% previous MI | | 0–59 | 26 (6.2, 113)
von Klot, 2008^138^ Germany Fair | Patients hospitalized by MI in any area hospital, 77% men Median age 61 26% diabetes 72% hypertension 15% previous MI | | 60–180 | 10 (4.3, 25)
von Klot, 2008^138^ Germany Fair | Patients hospitalized by MI in any area hospital, 77% men Median age 61 26% diabetes 72% hypertension 15% previous MI | | >180 | 1.2 (0.6, 2.4)
von Klot, 2008^138^ Germany Fair | Patients hospitalized by MI in any area hospital, 77% men Median age 61 26% diabetes 72% hypertension 15% previous MI | | All | 5.7 (3.6, 9.0)
Willich, 1993^139^ Germany Fair | Patients hospitalized by MI in any area hospital, 74.5% men Mean age 60.6 18.8% diabetes 49.4% hypertension 61.3% hyperlipidemia 18.3% previous MI | N=270 MIs, 44 (16.3%) related to vigorous exertion Outcome from medical records with independent review, plus structured interview in hospital or soon after discharge PA determined through structured interview in hospital or soon after discharge | RR of MI associated with vigorous exertion, by frequency of habitual exercise:
Willich, 1993^139^ Germany Fair | Patients hospitalized by MI in any area hospital, 74.5% men Mean age 60.6 18.8% diabetes 49.4% hypertension 61.3% hyperlipidemia 18.3% previous MI | | [underlined: Habitual Exercise] | [underlined: RR (95% CI)]
Willich, 1993^139^ Germany Fair | Patients hospitalized by MI in any area hospital, 74.5% men Mean age 60.6 18.8% diabetes 49.4% hypertension 61.3% hyperlipidemia 18.3% previous MI | | <4 times/week | 6.9 (4.1, 12.2)
Willich, 1993^139^ Germany Fair | Patients hospitalized by MI in any area hospital, 74.5% men Mean age 60.6 18.8% diabetes 49.4% hypertension 61.3% hyperlipidemia 18.3% previous MI | | ≥4 times/week | 1.3 (0.8, 2.2)
Willich, 1993^139^ Germany Fair | Patients hospitalized by MI in any area hospital, 74.5% men Mean age 60.6 18.8% diabetes 49.4% hypertension 61.3% hyperlipidemia 18.3% previous MI | | All | 2.1 (1.6, 3.1)

CI – confidence interval; MI – myocardial infarction; NR – not reported; RR – relative risk; US – United States