# Detailed Methdos

Appendix B Figure 1 PRISMA Flow Diagram

Appendix B Figure 1 is a flow chart that summarizes the search and selection of articles. There were 15,490 citations identified by searching MEDLINE, PsycInfo, and Cochrane databases. There were an additional 643 citations identified through other means (for example, suggestions from experts and reference lists from other publications). After removal of duplicates, 13,562 citations remained. Of these, 13,088 citations were excluded after abstract review. Reasons for exclusion included not relevant data (n=18), wrong setting (n=6), wrong population (n=100), no outcomes of interest (n=35), no interventions of interest (n=98), wrong study design (n=104), and poor study quality (n=46). (Note that 28 articles were excluded for different reasons in different areas and 7 were excluded for one area and included for another). The remaining 481 full-text articles were assessed for eligibility, and 109 of these articles were deemed eligible for inclusion. Of these 109 articles, 40 were included in the qualitative synthesis for healthful diet, 37 were included in the qualitative synthesis for physical activity, and 17 were included in the qualitative synthesis for combined lifestyle (8 articles were included in more than one area).

Appendix B Table 1 Review Inclusion and Exclusion Criteria

Condition Definition | Include | Healthy diet (HD) is one designed to improve or maintain optimal health, which includes:; - Appropriate calorie content; - Balance of fats (consumption of mono- and polyunsaturated fats, omega-3 fats, avoidance of excess saturated fat, avoidance of trans fat); - Fruits and vegetables; - Legumes; - Lean proteins; - Non- or low-fat dairy; - Balance of carbohydrates (consumption of whole grain and fiber, avoidance of excess refined carbohydrates, including excess sweetened beverages); - Balance of sodium (avoidance of excess sodium); Physical activity (PA) may involve either:; - Aerobic activities that involve repeated use of large muscles, such as walking, cycling, and swimming, OR; - Resistance training designed to improve physical strength
Condition Definition | Exclude | Aspects of a healthy diet that are out of scope include:; - Dietary calcium and other vitamin, micronutrient, and antioxidant supplementation; alcohol moderation; Aspects of physical activity that are out of scope include:; - Balance, flexibility, gait, and sedentary behaviors
Populations | Include | - Adults; - Unselected or low-risk patients similar to those seen in primary care (which may include some [<50% altogether] with cardiovascular disease [CVD], diabetes, hypertension, and/or hyperlipidemia) OR asymptomatic persons with increased CVD risk due to obesity; family history of CVD or a risk factor; or slightly elevated cholesterol, blood pressure, or glucose tolerance levels, but without a diagnosis of CVD, diabetes, hyperlipidemia, or hypertension
Populations | Exclude | Studies limited to:; - Children and adolescents; - Parents (if intended behavior change is directed toward children); - Persons with any acute disease; - Persons with symptomatic disease; - Persons with known coronary heart disease, diabetes (coronary heart disease equivalent), hypertension, or hyperipidemia; - Pregnant women; - Institutionalized persons; - Persons with severe and persistent mental illness; - Persons with cognitive impairment; HD only: persons requiring a specialized diet (e.g., kidney disease) PA only: persons with specific physical activity requirements or limitations for health reasons (e.g., cardiac or physiotherapeutic rehabilitation patients, physically disabled patients)
Settings | Include | Primary care (including obstetrics/gynecology, internal medicine, family practice, military health clinics) or otherwise generalizable to primary care; trials conducted in developed countries (Human Development Index >0.9) as defined by the United Nations (see below)
Settings | Exclude | Settings not generalizable to primary care (e.g., inpatient hospital units, emergency departments, nursing home and other institutionalized settings, school-based programs, occupational settings, and other community-based settings); dental clinics
Interventions | Include | Behaviorally-based counseling intervention on healthy diet and nutrition, physical activity, or both, including one or more of the following elements: assessment with feedback, advice, collaborative goal-setting, assistance, or arranging further contacts. Behaviorally-based counseling intervention targeting primary prevention of obesity, hypertension, hyperlipidemia, diabetes, or CVD. Either conducted in a primary care setting or judged to be feasible in primary care:; 1. Involve individual-level identification of being a patient or in need of intervention; 2. Usually involve primary care physicians, other physicians, nurses, nurse practitioners, physician assistants, or related clinical staff (e.g., health educators, other counselors), or the intervention will be seen as connected to the health care system by the participant; 3. Individual or small group format (15 persons or less, generally no more than 8 group sessions over 12 months); 4. Located anywhere, as long as linked to primary care OR may be conducted entirely online or through the mail without an explicit link to health care system.; OR must be primary care referable such that intervention needs to be conducted as part of a health care setting, or be available for referral in most communities. PA only: interventions evaluating referral by primary care provider (or health care system) to community exercise facilities or programs. (this addresses the question of whether patients would follow through on primary care referral)
Interventions | Exclude | - Non-counseling interventions (e.g., use of incentives, supervised exercise with the goal of assessing effects of exercise); - Interventions providing controlled diets; - Counseling interventions aimed at weight loss, falls prevention, depression, cognitive functioning, or disease prevention other than diabetes, hypertension, hyperlipidemia, or CVD; - Prenatal or postnatal dietary counseling; - Ccounseling interventions that are primarily community, nonreferral (e.g., occupational/worksite or school-based); or ocial marketing (e.g., media campaigns); - Policy (e.g., local or state public/health policy); - Interventions focused exclusively on reducing sedentary behavior
Comparisons | Include | Control arm with no intervention (e.g., waitlist control, usual care), minimal intervention (e.g., usual care limited to no more than 15 minutes of information), or attention control (e.g., similar format and intensity intervention on a different content area)
Comparisons | Exclude | Comparative effectiveness trials without a true control; PA only: studies in which the control group is instructed not to exercise
Outcomes | Include | KQ1: Distal health outcomes (i.e., morbidity related to CVD, diabetes, hypertension, hyperlipidemia, and mortality) KQ2: Intermediate health outcomes (i.e., blood pressure, hypertension, total cholesterol, LDL cholesterol or ratio of total/HDL cholesterol, serum fasting glucose or glucose tolerance, hemoglobin A1C, incidence of diabetes, weight, body mass index [BMI], overweight [BMI 25–29], obesity [BMI ≥ 30]) KQ3: Behavioral outcomes, self-reported or objective measures of overall endurance-related fitness, such as VO2max, walk time, or treadmill test KQ4: Adverse outcomes include any harms requiring medical attention (e.g., nutritional deficiencies, musculoskeletal injuries, cardiovascular events)
Outcomes | Exclude | Knowledge, attitudes, self-efficacy, functioning, quality of life PA only: studies limited to balance or flexibility outcomes, sedentary behavior Less than 6 months or 60% followup Excluded self-reported weight
Study Designs | Include | KQ1, 2, 3: systematic reviews, randomized controlled trials, controlled clinical trials KQ4: systematic reviews, randomized controlled trials, controlled clinical trials; for cardiovascular-related harms also include cohort, case-control, and case-crossover studies
Study Designs | Exclude | KQ1, 2, 3: any observational studies KQ4: ecological studies, case-series, case reports

Appendix B Table 2 Quality Rating Criteria

Design | U.S. Preventive Services Task Force quality rating criteria27 | National Institute for Health and Clinical Excellence methodology checklists28
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance; especially important for systematic reviews | - Study addresses an appropriate and clearly focused question; - Description of the methodology used is included; - Literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - Study addresses an appropriate and clearly focused question; - Cases and controls are taken from comparable populations; - Same exclusion criteria are used for both cases and controls; - Percentage of each group (cases and controls) that participated in the study is reported; - Comparison is made between participants and nonparticipants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - It is clearly established that controls are non-cases; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid, and reliable way; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided
Randomized controlled trials | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes are considered | - Study addresses an appropriate and clearly focused question; - Assignment of subjects to treatment groups is randomized; - Adequate concealment methods are used; - Subjects and investigators are kept blind about treatment allocation; - Treatment and control groups are similar at the start of the trial; - Only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid, and reliable way; - Percentage of the individuals or clusters recruited into each treatment arm of the study that dropped out before the study was completed are reported; - All subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - When the study is carried out at more than one site, results are comparable for all sites
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes are considered | - Study addresses an appropriate and clearly focused question; - Groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - Study indicates how many of the people asked to take part did so, in each of the groups being studied; - Likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - Percentage of individuals or clusters recruited into each arm of the study that dropped out before the study was completed are reported; - Comparison is made between full participants and those lost to followup, by exposure status; - Outcomes are clearly defined; - Assessment of outcome is made blind to exposure status; - When blinding is not possible, some recognition is made that knowledge of exposure status could have influenced the assessment of outcome; - Measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate results in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - Nature of the test being studied is clearly specified; - Test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - Test and gold standard are measured independently (blind) of each other; - Test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A prediagnosis is made and reported

## Hierarchy of research design

I Properly conducted randomized controlled trial
II-1 Well-designed controlled trial without randomization
II-2 Well-designed cohort or case-control analytic study
II-3 Multiple time series with or without the intervention; dramatic results from uncontrolled experiments
III Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees