# Abbreviations and Search Strategies

## Search Strategies

### Systematic Reviews

Databases: CDSR, DARE, PubMed, IOM, NICE, AHRQ, Clinical Evidence

Search Dates: 2001 to July 2008

Healthy diet counseling

1. diet[ti] OR dietary[ti]
2. “Food Habits”[Mesh] OR “Diet, Reducing”[Mesh] OR “Diet”[Mesh:NoExp] OR “Diet, Fat-Restricted”[Mesh]
3. “Fruit”[Mesh:NoExp] OR “Vegetables”[Mesh:NoExp]
4. “Dietary Fats”[Mesh:NoExp]
5. #1 OR #2 OR #3 OR #4
6. “Health Behavior”[Mesh:NoExp] OR “Health Promotion”[Mesh:NoExp] OR “Health Education”[Mesh:NoExp]
7. counsel*[tiab]
8. “Patient Education as Topic”[Mesh] OR “Counseling”[Mesh:NoExp] OR “Directive Counseling”[Mesh]
9. “Behavior Therapy”[Mesh:NoExp]
10. interventions[tiab] AND behavi*[tiab]
11. #6 OR #7 OR #8 OR #9 OR #10
12. #5 AND #11
13. “dietary education”[tiab]
14. “diet education”[tiab]
15. nutrition education”[tiab]
16. #12 OR #13 OR #14 OR #15
17. #16 AND systematic[sb]
18. diet[tiab] OR dietary[tiab]
19. counsel*[tiab] OR (behavi*[tiab] AND change*[tiab]) OR motivational*[tiab] OR (behavi*[tiab] AND interventions[tiab])
20. #18 AND #19
21. “diet interventions”[tiab]
22. “dietary interventions”[tiab]
23. “nutrition interventions”[tiab]
24. “obesity prevention interventions”[tiab]
25. #20 OR #21 OR #22 OR #23 OR #24
26. #25 AND systematic[sb]
27. #26 AND (in process [sb] OR publisher [sb] OR pubmednotmedline [sb])
28. #17 OR #27
29. #28 AND (Limits: Publication Date from 2001 to 2008, English)

Physical activity counseling

1. “physical activity”[ti]
2. “Exercise”[Mesh:NoExp] OR “Motor Activity”[Mesh:NoExp] OR “Physical Fitness”[Mesh]
3. #1 OR #2
4. (“Health Behavior”[Mesh:NoExp] OR “Health Promotion”[Mesh:NoExp]) OR “Health Education”[Mesh:NoExp]
5. (“Patient Education as Topic”[Mesh] OR “Counseling”[Mesh:NoExp]) OR “Directive Counseling”[Mesh]
6. counsel*[tiab]
7. “Behavior Therapy”[Mesh:NoExp]
8. interventions[tiab] AND behavi*[tiab]
9. #4 OR #5 OR #6 OR #7 OR #8
10. #3 AND #9
11. #10 AND systematic[sb]
12. “physical activity”[tiab] OR exercise[tiab]
13. counsel*[tiab] OR (behavi*[tiab] AND change*[tiab]) OR motivational*[tiab] OR (behavi*[tiab] AND interventions[tiab])
14. #12 AND #13
15. “physical activity interventions”[tiab]
16. “obesity prevention interventions”[tiab]
17. #14 OR #15 OR #16
18. #17 AND systematic[sb]
19. #18 AND (in process [sb] OR publisher [sb] OR pubmednotmedline [sb])
20. #11 OR #19
21. #20 AND (Limits: Publication Date from 2001 to 2008, English)

### Full Literature Search

Databases: MEDLINE, CCRCT, PsycINFO

Search Dates: 2001 through January 2010

1. Diet, Reducing
2. Diet, Fat-Restricted
3. Diet, Mediterranean
4. Diet, Sodium-Restricted
5. Diet, Carbohydrate-Restricted
6. Caloric Restriction
7. Fruit
8. Vegetables
9. Diet Therapy
10. Food Habits
11. Exercise
12. Exercise Therapy
13. Motor Activity
14. Physical Fitness
15. Walking
16. physical activit$.ti.
17. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16
18. Counseling
19. Directive Counseling
20. “Behavior-Therapy”
21. Cognitive Therapy
22. counsel?ing.ti,ab.
23. advice.ti,ab.
24. behavio?r$ change$.ti,ab.
25. behavio?r$ modification$.ti,ab.
26. “Referral and Consultation”
27. Persuasive Communication
28. Social Control, Informal
29. Risk Reduction Behavior
30. Life Style
31. Motivation
32. Social Support
33. Feedback, Psychological
34. Self Efficacy
35. Health Knowledge, Attitudes, Practice
36. Health Behavior
37. Health Education
38. Health Promotion
39. Patient Education as Topic
40. insulin.ti,ab,hw.
41. lipid$.ti,ab,hw.
42. cardiovascular.ti,ab,hw.
43. glucose.ti,ab,hw.
44. body mass index.ti,ab,hw.
45. bmi.ti,ab,hw.
46. coronary.ti,ab,hw.
47. Hemoglobin A, Glycosylated
48. hemoglobin a1c.ti,ab.
49. lipoprotein$.ti,ab,hw.
50. triglyceride$.ti,ab,hw.
51. hypertension.ti,ab,hw.
52. body weight.ti,ab,hw.
53. hyperlipidemia$.ti,ab,hw.
54. blood pressure.ti,ab,hw.
55. cholesterol$.ti,ab,hw.
56. diabet$.ti,ab,hw.
57. 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56
58. 17 and 57 (42846)
59. limit 58 to (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial)
60. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
61. Meta-Analysis as Topic
62. (control$ adj3 trial$).ti,ab.
63. random$.ti,ab.
64. clinical trial$.ti,ab.
65. 60 or 61 or 62 or 63 or 64
66. 58 and 65
67. 59 or 66
68. limit 67 to “all child (0 to 18 years)”
69. limit 67 to “all adult (19 plus years)”
70. 68 not 69
71. 67 not 70
72. limit 71 to animals
73. limit 71 to humans
74. 72 not 73
75. 71 not 74
76. limit 75 to english language
77. limit 76 to yr= “2001 – 2009”
78. (harm or harms or harmful or harmed).ti,ab.
79. (risky behavior$ or risky behaviour$).ti,ab.
80. (adverse effects or mortality).fs.
81. Mortality
82. Morbidity
83. death
84. Athletic injuries
85. Malnutrition
86. nutritional defici$.ti,ab.
87. (death or deaths).ti,ab.
88. fracture$.ti,ab,hw.
89. cardiovascular.ti,ab,hw.
90. 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89
91. 58 and 90
92. case-control studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/
93. case control$.ti,ab.
94. cohort.ti,ab.
95. longitudinal.ti,ab.
96. (follow-up or followup).ti,ab.
97. prospective$.ti,ab.
98. (comparison group$ or control group$).ti,ab.
99. observational.ti,ab.
100. retrospective studies
101. retrospective$.ti,ab.
102. database$.ti,ab.
103. nonrandomi$.ti,ab.
104. population$.ti,ab.
105. 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100 or 101 or 102 or 103 or 104
106. 91 and 105
107. limit 106 to “all child (0 to 18 years)”
108. limit 106 to “all adult (19 plus years)”
109. 107 not 108
110. 106 not 109
111. limit 110 to animals
112. limit 110 to humans
113. 111 not 112
114. 110 not 113
115. limit 114 to english language
116. limit 115 to yr= “2001 – 2010”
117. 77 or 116

Abbreviations
AARP: American Association of Retired Persons
ACSM: American College of Sports Medicine
AHA: American Health Association
AHSPAQ: Auckland Heart Study Physical Activity Questionnaire
BMI: Body Mass Index
CG: Control Group
CHAMPS: Community Healthy Activities Model Program for Seniors
CI: Confidence Interval
CONSORT: Consolidated Standards of Reporting Trials
DBP: Diastolic Blood Pressure
FAD: 5 A Day for Better Health Program
HDL: High-Density Lipoproteins
IG: Intervention Group
IPAQ: International Physical Activity Questionnaire
LDL: Low-Density Lipoproteins
MET: Metabolic Equivalent
MI: Motivational Interview
NCIF: National Cancer Institute Fruit and Vegetable Screener, All Day
NCIP: National Cancer Institute Fruit and Vegetable Screener, By Meal
NIA: National Institute on Aging
NR: Not Reported
NS: Not Significant
PAR: (Stanford 7-Day) Physical Activity Recall
PACE: Physician-Based Assessment and Counseling for Exercise
PASE: Physical Activity Scale for the Elderly
RCT: Randomized Controlled Trial
SD: Standard Deviation
SE: Standard Error
SBP: Systolic Blood Pressure
YPAS: Yale Physical Activity Survey