# Appendixes

Appendix A Abbreviations and Search Strategies

Appendix B Detailed Methdos

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Meta-Analysis Details

Appendix F Previous and Pending Studies

Appendix G Figures 1–16. Forest Plots of All Trials