# References

1 Jemal A, Siegel R, Ward E, Hao Y, Xu J, Thun MJ. Cancer statistics, 2009. CA Cancer J Clin. 2009;59:225-249. [pmid: 19474385].
2 Altekruse SF, Kosary CL, Krapcho M, Neyman N, Aminou R, Waldron W, Ruhl J, Howlader N, Tatalovich Z, Cho H, Mariotto A, Eisner MP, Lewis DR, Cronin K, Chen HS, Feuer EJ, Stinchcomb DG, Edwards BK, editors. SEER Cancer Statistics Review, 1975–2007. Bethesda, MD. National Cancer Institute. 2010. Accessed at: http://seer.cancer.gov/csr/1975_2007. 7 September 2010.
3 Kaufman DS, Shipley WU, Feldman AS. Bladder cancer. Lancet. 2009;374:239-249. [pmid: 19520422].
4 National Cancer Institute. Bladder Cancer Treatment (PDQ®) Summary: Health Professional Version. Bethesda, MD. National Cancer Institute. 2010. Accessed at http://www.cancer.gov/cancertopics/pdq/treatment/bladder. 7 September 2010.
5 Pashos CL, Botteman MF, Laskin BL, Redaelli A. Bladder cancer: epidemiology, diagnosis, and management. Cancer Pract. 2002;10(6):311-322. [pmid: 12406054].
6 American Cancer Society. Bladder Cancer: Detailed Guide. Atlanta. American Cancer Society. 2010. Accessed at http://www.cancer.org/Cancer/BladderCancer/DetailedGuide/index. 7 September 2010.
7 American Joint Committee on Cancer. What is Cancer Staging?. Chicago. American Joint Committee on Cancer. 2010. Accessed at http://www.cancerstaging.org/mission/whatis.html. 7 September 2010.
8 Epstein JI, Amin MB, Reuter VE, Mostofi FK. The World Health Organization/International Society of Urological Pathology consensus on classification of urothelial (transitional cell) neoplasms of the urinary bladder. Am J Surg Pathol. 1998;22:1435-1438. [pmid: 9850170].
9 Centers for Disease Control and Prevention and National Cancer Institute. United States Cancer Statistics 1999–2006. Cancer Incidence and Mortality Data. Atlanta. Centers for Disease Control and Prevention and National Cancer Institute. 2010. Accessed at http://apps.nccd.cdc.gov/uscs/. 7 September 2010.
10 Konety BR, Joyce GF, Wise F. Bladder and upper tract urothelial cancer. Litwin MS, Saigal CS, editors. Urologic Diseases in America. Bethesda, MD. National Institute of Diabetes and Digestive and Kidney Diseases. 2007.
11 Olfert SM, Felknor SA, Delclos GL. An updated review of the literature: risk factors for bladder cancer with focus on occupational exposures. South Med J. 2006;99:1256-1263. [pmid: 17195421].
12 Kiemeney LA. Hereditary bladder cancer. Scand J Urol Nephrol. 2008;42(Suppl 218):110-115. [pmid: 17853038].
13 Kirkali Z, Chan T, Manoharan M, et al. Bladder cancer: epidemiology, staging and grading, and diagnosis. Urology. 2005;66(6 Suppl 1):4-34. [pmid: 16399414].
14 Wu X, Ros MM, Gu J, Kiemeney LA. Epidemiology and genetic susceptibility to bladder cancer. BJU Int. 2008;102:1207-1215. [pmid: 19035883].
15 Madeb R, Golijanin D, Knopf J, Messing EM. Current state of screening for bladder cancer. Expert Rev Anticancer Ther. 2007;7(7):981-987. [pmid: 17627458].
16 Hall MC, Chang SS, Dalbagni G, et al. Guideline for the management of nonmuscle invasive bladder cancer (stages Ta, T1, and Tis): 2007 update. J Urol. 2007;178:2314-2330. [pmid: 17993339].
17 UK National Screening Committee. The UK National Screening Committee Policy on Bladder Cancer Screening in Adults. London. UK National Screening Committee. 2002. Accessed at http://www.screening.nhs.uk/bladdercancer. 7 September 2010.
18 Canadian Task Force on Preventive Health Care. Screening for Bladder Cancer. Ottowa, ON. Canadian Task Force on Preventive Health Care. 1994. Accessed at http://www.canadiantaskforce.ca/_archive/index.html. 7 September 2010.
19 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
20 Leeflang MMG, Deeks JJ, Gatsonis C, Bossuyt PM. Cochrane Diagnostic Test Accuracy Working Group. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149:889-897. [pmid: 19075208].
21 Friedman GD, Hiatt RA, Quesenberry CP Jr, Selby JV, Weiss NS. Problems in assessing screening experience in observational studies of screening efficacy: example of urinalysis screening for bladder cancer. J Med Screen. 1995;2(4):219-223. [pmid: 8719152].
22 Messing EM, Madeb R, Young T, et al. Long-term outcome of hematuria home screening for bladder cancer in men. Cancer. 2006;107(9):2173-2179. [pmid: 17029275].
23 Theriault G, Tremblay C, Armstrong B. Bladder cancer screening among primary aluminum production workers in Quebec. J Occup Med. 1990;32:869-872. [pmid: 2074510].
24 Messing EM, Young TB, Hunt VB, et al. Comparison of bladder cancer outcome in men undergoing hematuria home screening versus those with standard clinical presentations. Urology. 1995;45(3):387-396. [pmid: 7879333].
25 Hedelin H, Jonsson K, Salomonsson K, Boman H. Screening for bladder tumours in men aged 60–70 years with a bladder tumour marker (UBC) and dipstick-detected haematuria using both white-light and fluorescence cystoscopy. Scand J Urol Nephrol. 2006;40(1):26-30. [pmid: 16452052].
26 Whelan P, Britton JP, Dowell AC. Three-year follow-up of bladder tumours found on screening. Br J Urology. 1993;72:893-896.
27 Steiner H, Bergmeister M, Verdorfer I, et al. Early results of bladder-cancer screening in a high-risk population of heavy smokers. BJU Int. 2008;102(3):291-296. [pmid: 18336612].
28 Lotan Y, Elias K, Svatek RS, et al. Bladder cancer screening in a high risk asymptomatic population using a point of care urine based protein tumor marker. J Urol. 2009;182:52-58. [pmid: 19450825].
29 Marsh GM, Cassidy LD. The Drake Health Registry Study: findings from fifteen years of continuous bladder cancer screening. Am J Ind Med. 2003;43(2):142-148. [pmid: 12541268].
30 Lotan Y, Capitanio U, Shariat SF, Hutterer GC, Karakiewicz PI. Impact of clinical factors, including a point-of-care nuclear matrix protein-22 assay and cytology, on bladder cancer detection. Br J Urol. 2009;103:1368-1374.
31 Grossman HB, Messing E, Soloway M, et al. Detection of bladder cancer using a point-of-care proteomic assay. JAMA. 2005;293(7):810-816. [pmid: 15713770].
32 Ponsky LE, Sharma S, Pandrangi L, et al. Screening and monitoring for bladder cancer: refining the use of NMP22. J Urol. 2001;166(1):75-78. [pmid: 11435827].
33 Zippe C, Pandrangi L, Agarwal A. NMP22 is a sensitive, cost-effective test in patients at risk for bladder cancer. J Urol. 1999;161(1):62-65. [pmid: 10037369].
34 Britton JP, Dowell AC, Whelan P. Dipstick haematuria and bladder cancer in men over 60: results of a community study. BMJ. 1989;299(6706):1010-1012. [pmid: 2511941].
35 Collado A, Chechile GE, Salvador J, Vicente J. Early complications of endoscopic treatment for superficial bladder tumors. J Urol. 2000;164(5):1529-1532. [pmid: 11025697].
36 Aaronson DS, Walsh TJ, Smith JF, Davies BJ, Hsieh MH, Konety BR. Meta-analysis: does lidocaine gel before flexible cystoscopy provide pain relief?. BJU Int. 2009;104:506-510. [pmid: 19239453].
37 Burke DM, Shackley DC, O’Reilly PH. The community-based morbidity of flexible cystoscopy. BJU Int. 2002;89:347-349. [pmid: 11872022].
38 Stav K, Leibovici D, Goren E, et al. Adverse effects of cystoscopy and its impact on patients’ quality of life and sexual performance. Isr Med Assoc J. 2004;6:474-478. [pmid: 15326827].
39 Turan H, Balci U, Erdinc FS, Tulek N, Germiyanoglu C. Bacteriuria, pyuria and bacteremia frequency following outpatient cystoscopy. Int J Urol. 2006;13:25-28. [pmid: 16448428].
40 Herman MP, Svatek RS, Lotan Y, Karakiewizc PI, Shariat SF. Urine-based biomarkers for the early detection and surveillance of non-muscle invasive bladder cancer. Minerva Urol Nefrol. 2008;60:217-235. [pmid: 18923359].
41 Lam T, Nabi G. Potential of urinary biomarkers in early bladder cancer diagnosis. Expert Rev Anticancer Ther. 2007;7:1105-1115. [pmid: 18028019].
42 American Urological Association. Bladder Cancer: Guideline for the Management of Nonmuscle Invasive Bladder Cancer (Stages Ta, T1, and Tis): 2007 Update. Linthicum, MD. American Urological Association. 2007.
43 Greene FL, Page DL, Fleming ID, Fritz A, Balch CM, Haller DG. American Joint Committee on Cancer. AJCC Cancer Staging Manual. 6th ed. New York. Springer-Verlag. 2002.