# Discussion

## Summary of Review Findings

Table 3 summarizes the results of this evidence synthesis by Key Question. Bladder cancer is one of the 10 most frequently diagnosed cancers in the United States, but evidence on the natural history of asymptomatic bladder cancer is lacking, since tumors are typically treated following diagnosis.16 In addition, the variability in the natural history of bladder cancer with respect to risk of tumor progression from superficial to muscle invasive or metastatic bladder cancer and the relatively low incidence of bladder cancer mortality relative to the incidence of new cases present challenges in evaluating potential benefits and harms of screening.3, 16 Major gaps in the evidence make it impossible to reach any reliable conclusions about screening. We identified no high-quality randomized, controlled trials or controlled observational studies showing that bladder cancer screening is associated with improved clinical outcomes compared to no screening. The only controlled cohort studies on screening suggest that screening might result in a shift to earlier stage bladder cancer diagnoses or reduce the long-term risk of bladder cancer-related mortality, but the studies had serious methodological shortcomings, including selection of noncomparable control groups and failure to adjust for potential confounders.23, 24

Table 3 Summary of Evidence

Number of studies Overall quality rating | Limitations | Consistency | Primary care applicability | Summary of findings
KQ 1. Is there direct evidence that screening for bladder cancer reduces morbidity or mortality?
3 studies (4 publications) Overall quality rating: poor | 3 poor-quality observational studies; no inception cohort of similar unscreened subjects, historical control, or inaccurate ascertainment of exposures and symptoms | No important inconsistency | Low to moderate | No randomized, controlled trials of screening for bladder cancer were identified. 3 observational studies found screening for bladder cancer associated with decreased risk of bladder cancer mortality or lower stage at diagnosis (or trends toward decreased risks), but were difficult to interpret due to important methodological shortcomings.
KQ2. What are the accuracy and reliability of urinalysis for hematuria, urine cytology, and urine biomarkers for identification of bladder cancer?
No studies | All studies enrolled patients with previous bladder cancer or signs and symptoms of bladder cancer | No studies | No studies | No studies evaluated the sensitivity or specificity of diagnostic tests for bladder cancer in patients without previous bladder cancer or signs and symptoms associated with bladder cancer. 6 studies found a positive predictive value of <10% for screening in asymptomatic persons, including high-risk populations.^*^
KQ3. Does treatment of screen-detected bladder cancer reduce morbidity and mortality from this disease?
No studies | No studies met inclusion criteria | No studies | No studies | No evidence; no randomized, controlled trials or controlled observational studies were identified.
KQ4. What are the harms of screening for bladder cancer or treatment of screen-detected bladder cancer?
No studies | No studies met inclusion criteria | No studies | No studies | No randomized, controlled trials or controlled observational studies were identified. Harms of screening are likely to be related to the false-positive rate (see KQ2). One large uncontrolled observational study of transurethral resection of bladder tumor reported bleeding in 2.8% and perforation in 1.3%, with no associated mortality.

* These studies did not meet formal inclusion criteria because they provided incomplete diagnostic information.

Abbreviation: KQ = key question

In terms of indirect evidence, we could not estimate the effectiveness of treatments for screen-detected bladder cancer, as there are no studies comparing clinical outcomes associated with treatment versus no treatment. Evidence on the diagnostic accuracy of screening tests in asymptomatic patients with a prior history of bladder cancer is limited to studies reporting positive predictive values, without data on sensitivity or specificity. A number of recent studies have evaluated urine biomarkers, but their main focus has been on diagnostic accuracy for recurrent bladder cancer or in patients with gross hematuria or lower urinary tract symptoms, rather than in asymptomatic persons relevant for screening. In screening studies of asymptomatic persons, the positive predictive value is less than 10 percent, even in higher-risk populations, which could result in unnecessary procedures and associated harms, including bleeding and perforation.25, 27–29, 34 However, there are no reliable data to estimate the magnitude of harms associated with screening for bladder cancer compared to no screening or the magnitude of harms associated with treatment of screen-detected bladder cancer versus no treatment.

## Limitations

The major limitation of this review is the lack of evidence addressing any of the Key Questions.

## Emerging Issues/Next Steps

We identified no ongoing or planned trials of screening compared to no screening. A number of newer urinary biomarkers for bladder cancer are under investigation,40, 41 but have not been evaluated for their usefulness in screening.

## Future Research

Randomized trials or appropriately designed cohort studies that compare results of screening compared to no screening on clinical outcomes are needed to understand the effects of screening compared to no screening on clinical outcomes. Screening strategies to be evaluated could include testing all asymptomatic persons or targeted screening of high-risk groups based on smoking status, demographics, workplace exposures, or other factors, in order to help define optimal screening strategies. It would be appropriate to focus initial randomized trials on higher-risk groups, as the greater incidence of bladder cancer could result in a higher yield from screening and allow researchers to enroll smaller sample sizes. If randomized trials show benefit in high-risk groups, future trials could evaluate testing of all asymptomatic persons. In lieu of randomized trials, cohort studies could be helpful for understanding risks and benefits of screening, but to be more informative than currently available studies, they should be designed with appropriate attention to potential confounding and selection of appropriate control groups. If screening is shown to be effective, studies should evaluate the comparative diagnostic accuracy of urine tests for hematuria, urinary cytology, and urinary biomarkers in asymptomatic patients, in order to better inform the selection of screening tests. Randomized trials of treatment compared to no treatment for screen-detected or superficial bladder cancer could be difficult to implement, as TURBT has become the standard of care in any case where bladder cancer is either suspected or confirmed.42 Therefore, it may be more feasible—and provide more direct evidence—to focus future research efforts on trials of screening compared to no screening, rather than to attempt trials of treatment versus no treatment.

## Conclusions

Additional research is needed to determine whether screening of adults leads to better outcomes than no screening.