# Methods

## Key Questions and Analytic Framework

Using the methods of the USPSTF that are fully described in the Appendix and with the input of members of the USPSTF, we developed an analytic framework (Figure 1) and Key Questions to guide our literature search and review.

Figure 1 Analytic Framework and Key Questions

Key Question 1. Is there direct evidence that screening for bladder cancer reduces morbidity or mortality?

Key Question 2. What are the accuracy and reliability of urinalysis, urinary cytology, and other urinary biomarkers for identification of bladder cancer?

Key Question 3. Does treatment of screen-detected bladder cancer reduce morbidity and mortality from this disease?

Key Question 4. What are the harms of screening for bladder cancer and treatment of screen-detected bladder cancer?

Abbreviation: KQ = key question.

The Key Questions used to guide this evidence synthesis are:

1. Is there direct evidence that screening for bladder cancer reduces morbidity or mortality?
2. What are the accuracy and reliability of urinalysis for hematuria, urine cytology, and urine biomarkers for identification of bladder cancer?
3. Does treatment of screen-detected bladder cancer reduce morbidity and mortality from this disease?
4. What are the harms of screening for bladder cancer and treatment of screen-detected bladder cancer?

## Search Strategies

We searched Ovid MEDLINE from 2002 to December 2009, the Cochrane Database of Systematic Reviews and the Cochrane Central Register of Controlled Trials through the fourth quarter of 2009, and the CancerLit subsection of PubMed through March 2010 to identify relevant articles (Appendix 1). We identified additional studies from reference lists of relevant articles, including the previous USPSTF review.

## Study Selection

We selected studies pertaining to screening, diagnosis, and treatment of bladder cancer based on pre-defined inclusion and exclusion criteria (Appendix 2). Two reviewers evaluated each study at the title/abstract and full-text article stages to determine eligibility for inclusion. The flow of studies from initial identification of titles and abstracts to final inclusion or exclusion is diagrammed in Appendix 3. We defined the target population as asymptomatic persons older than 50 years of age. Our focus was studies performed in primary care settings, but we also included studies conducted in occupational settings. We excluded studies that enrolled patients with recurrent bladder cancer. We also excluded studies that enrolled patients with gross hematuria, dysuria, or other signs or symptoms associated with bladder cancer, as these were considered symptomatic and therefore outside the scope of screening. Studies that enrolled a mixed population of asymptomatic and symptomatic individuals were included if results were reported separately for asymptomatic patients without previous bladder cancer, or if >85 percent of enrollees satisfied these criteria. Outcomes of interest were morbidity and mortality and adverse events related to screening or treatment, and measures of diagnostic accuracy for screening tests.

We included randomized, controlled trials and controlled observational studies (cohort and case-control studies) that directly assessed effects of bladder cancer screening compared to not screening on morbidity, mortality, or harms. We also included studies that evaluated the diagnostic accuracy of urinalysis for hematuria, cytology, and urinary biomarkers compared to results of cystoscopy. For treatment, we focused on randomized, controlled trials and controlled observational studies comparing benefits and harms of TURBT and/or intravesical therapy compared to no treatment for screen-detected or superficial bladder cancer (the type most likely to be detected by screening and amenable to early treatment). We restricted our review to published studies available in the English language. Studies that were excluded after review of the full-text articles and reasons for exclusion are listed in Appendix 4.

## Data Abstraction and Quality Rating

We abstracted details about the patient population, study design, data analysis, follow-up, and results. One author abstracted data and another author verified data abstraction for accuracy. We used predefined criteria developed by the USPSTF to assess the risk of bias (quality) of studies (Appendix 5).19, 20 For randomized trials, we assessed methods of randomization, allocation concealment, and blinding; loss to follow-up; and use of intention-to-treat analysis. Two authors independently rated the internal validity of each study as “good,” “fair,” or “poor” based on the number and seriousness of methodological shortcomings. When data were available from diagnostic accuracy studies, we used the diagti procedure in Stata (Stata version 10, StataCorp, College Station, TX) to calculate sensitivities, specificities, and likelihood ratios. For all studies, we evaluated applicability to populations likely to be encountered in primary care screening settings, based on whether patients were recruited from primary care or community settings, the proportion of patients with signs or symptoms suggesting bladder cancer, occupational exposures, the stage of bladder cancer, and the proportion of patients with a previous bladder cancer diagnosis. Discrepancies in quality ratings were resolved by discussion and consensus.

## Data Synthesis

We assessed the overall strength of the body of evidence for each Key Question (“good,” “fair,” or “poor”), or part of a Key Question, using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.19 Because few studies met inclusion criteria, we did not quantitatively pool results.

## External Review

We distributed a draft of the report for review by external experts not affiliated with the USPSTF (Appendix 6), and revised the report based on their comments.