# Introduction

## Scope and Purpose

Bladder cancer is the fourth most commonly diagnosed cancer in men and the ninth most commonly diagnosed cancer in women in the United States.1 Screening could identify bladder cancer at earlier stages, when it may be more easily and effectively treated. The U.S. Preventive Services Task Force (USPSTF) last reviewed the evidence on bladder cancer screening in 2004. The USPSTF commissioned an update of the evidence review in 2009 in order to update its recommendation on screening. Bladder cancer remains an important public health problem, with no improvements in incidence or associated mortality since 1975.^2^ There is important uncertainty regarding bladder cancer screening, particularly in higher-risk patients. In addition, since the last USPSTF review, research on urinary biomarkers for diagnosis of bladder cancer has accumulated substantially. The purpose of this report is to systematically evaluate the current evidence on screening for bladder cancer.

## Condition Definition

In the United States, over 90 percent of bladder cancers are transitional cell carcinomas, 5 percent are squamous cell carcinomas, and less than 2 percent are adenocarcinomas.3–5 Bladder cancer is typically staged according to the American Joint Committee on Cancer Tumor Node Metastases (TNM) criteria, in which the tumor stage (T) is based on the extent of penetration or invasion into the bladder wall and adjacent structures (Table 1).6, 7 Superficial bladder cancers, or those that have not invaded the bladder smooth muscle, include stages Ta (noninvasive papillary carcinoma), Tis (carcinoma in situ), and T1 (tumor has invaded the subepithelial connective tissue) tumors. Tumors stage 2 and higher are muscle invasive. The likelihood of progression to invasive cancer is associated with the presence of more poorly differentiated cells and other histopathologic features. According to a 1998 World Health Organization and International Society of Urological Pathology consensus statement, transitional cell carcinomas are classified histopathologically into one of four categories: papilloma, papillary urothelial neoplasm of low malignant potential, low grade carcinoma, and high grade carcinoma.8

Table 1 Bladder Cancer Tumor Staging

TX | Primary tumor cannot be assessed
Ta | Noninvasive papillary carcinoma
Tis | Carcinoma in situ
T1 | Tumor invades lamina propria
T2 | Tumor invades muscularis propria
| T2a: Invades superficial muscularis propria (inner half)
| T2b: Invades deep muscularis propria (outer half)
T3 | Tumor invades perivesical tissue/fat
| T3a: Invades perivesical tissue/fat microscopically
| T3b: Invades perivesical tissue/fat macroscopically (extravesical mass)
T4 | Tumor invades prostate, uterus, vagina, pelvic wall, or abdominal wall
| T4a: Invades adjacent organs (uterus, ovaries, prostate stoma)
| T4b: Invades pelvic wall and/or abdominal wall

Sources: American Urological Association, 2007^42^ and Greene et al, 2002^43^

## Prevalence and Burden of Disease

The incidence of bladder cancer in the United States in 2005 was approximately 21 per 100,000 persons, or 0.02 percent.9 The American Cancer Society estimates that 70,980 new cases of bladder cancer will be diagnosed in the United States during 2009 (about 52,810 men and 18,170 women), and about 14,330 people will die of the disease (about 10,180 men and 4,150 women).1 By comparison, it is estimated that there will be 219,440 new cases of lung cancer and 159,390 deaths (88,900 in men and 70,490 in women), 146,970 new cases of colorectal cancer and 49,920 deaths (25,240 in men and 24,680 in women), 42,470 new cases of pancreatic cancer and 35,240 deaths (18,030 in men and 17,210 in women), 192,280 new cases of prostate cancer and 27,360 prostate cancer deaths, 192,370 new cases of breast cancer and 40,170 breast cancer deaths, 42,160 new cases of uterine cancer and 7,780 uterine cancer deaths, and 11,270 new cases of cervical cancer and 4,070 cervical cancer deaths. Bladder cancer occurs primarily in men older than 60 years of age and roughly twice as frequently in white compared to black men.9

## Etiology and Natural History

Bladder cancer is a heterogeneous condition. Approximately 75 percent of newly diagnosed transitional cell carcinomas present as superficial tumors which can be treated with local (bladder-sparing) resection and intravesical therapy.3 About 25 percent of newly diagnosed bladder cancer presents as invasive tumor.10 Once bladder cancer invades muscle, it can quickly progress and metastasize, is associated with a poor prognosis, and its treatment may involve removal of the bladder or systemic chemotherapy. As many as 50–70 percent of superficial tumors will recur after initial treatment, with a 10–20 percent risk of progression to invasive tumor.3 A major challenge for screening is to accurately identify tumors that are still superficial, yet at high risk for progression, in order to initiate interventions at a more treatable stage. Factors that influence risk of progression include the tumor stage and grade; the number, size, and appearance of lesions; the response to initial treatment; and other factors.

## Risk Factors

Cigarette smokers are 2 to 4 times more likely to develop bladder cancer than nonsmokers.11 Occupational exposures to carcinogens, particularly in the rubber, chemical, and leather industries, are also associated with increased risk for bladder cancer. For example, β-napthylamine (BNA), one of the best established carcinogens, is associated with a 200-fold increased risk of bladder cancer.11 Other risk factors for bladder cancer include male sex, older age, white race, infections caused by certain bladder parasites, and having a family or prior personal history of bladder cancer.11–14

## Rationale for Screening/Screening Strategies

The rationale for screening is that screening could identify high-grade superficial bladder cancer at earlier asymptomatic stages, when there is a greater chance of cure with bladder-sparing therapies.15 Circumstances that would favor screening include the presence of a prolonged asymptomatic phase in which superficial bladder cancers at high risk for progression can be detected, availability of accurate screening tests, and availability of effective and safe treatments for bladder cancers detected by screening.

## Interventions/Treatment

Once bladder cancer has been diagnosed, a number of factors affect prognosis and treatment options. These include the stage of the cancer (superficial versus invasive), tumor grade, whether the tumor is recurrent, the patient’s age and general health, and other factors. The main treatment for superficial bladder cancer is local (bladder-sparing) resection (transurethral resection of bladder tumor or TURBT), often with adjuvant radiation therapy, intravesical chemotherapy, immunotherapy, or photodynamic therapy.16 For invasive bladder cancer that is surgically resectable, the main treatment is radical cystectomy, often with adjuvant or neoadjuvant systemic chemotherapy.

## Current Clinical Practice

Screening tests that are feasible for primary care include the urine dipstick or microscopic urinalysis to detect hematuria (blood in the urine) and urine cytology to detect abnormal or cancerous cells in the urine. Urine biomarkers for bladder cancer, such as the nuclear matrix protein-22 (NMP22) complement factor H-related protein, would also be feasible for screening, but have not yet been widely adopted in primary care. One factor that could affect how urine biomarkers are used for screening is their cost, which varies substantially for different tests. Screening strategies could include testing all asymptomatic persons or targeted screening of high-risk groups based on smoking status, demographics, workplace exposures, or other factors. Patients with a positive screening test in primary care settings are referred to a urologist for further evaluation, which typically includes cystoscopy (with biopsy if a bladder tumor is found), and may include imaging and other studies.

## Recommendations of Other Groups

No organization recommends routine screening for bladder cancer in asymptomatic older adults, including the American Cancer Society, the United Kingdom National Screening Committee, and the Canadian Task Force on Preventive Health Care.6, 17, 18

## Previous USPSTF Recommendation

In 2004, the USPSTF recommended against routine screening for bladder cancer in adults (D recommendation). The USPSTF found fair evidence that screening can detect bladder cancer in asymptomatic individuals, but concluded that the potential benefit of screening would be small at best because many of the cancers detected by screening have a low tendency to progress to invasive disease, there is a relatively low overall prevalence of asymptomatic bladder cancer that would eventually lead to important clinical consequences, and because of insufficient evidence that early treatment of bladder cancer detected through screening improves long-term health outcomes. The potential harms of screening were assessed as at least small, based on the low positive predictive value of screening tests (resulting in many false-positive test results), which could lead to unnecessary invasive procedures (such as cystoscopies and biopsies) or other tests. As a result, the USPSTF concluded that the potential harms of screening for bladder cancer outweigh potential benefits.