# Expert Reviewers of the Draft Report

Sam Chang, MD

Associate Professor, Vanderbilt University Medical Center

Robert R. German, DrPH, MPH

Associate Director for Science, Centers for Disease Control and Prevention

Linda Kinsinger, MD

Chief Consultant, Preventive Medicine, Veterans Health Administration, National Center for Health Promotion and Disease

Barnett Kramer, MD, MP

Director, National Institutes of Health, Office of Medical Applications of Research

Yair Lotan, MD

Associate Professor, University of Texas Southwestern Medical Center at Dallas, Department of Urology

Edward Messing, MD, FACS

Professor of Urology, University of Rochester Medical Center