# Inclusion and Exclusion Criteria

## Settings

### Include

Studies of screening performed in settings generalizable to primary care

Studies of diagnostic accuracy performed in specialty settings, if the screening test is generalizable to primary care

### Exclude

Specialty settings and countries with populations not similar to the United States

## Populations

### Include

Adults, ages 50 and older

### Exclude

Prior bladder cancer

Gross hematuria

Urinary symptoms

## Screening Tests

### Include

Screening tests used or available in primary care settings (urine dipstick or urinalysis for microscopic hematuria, urine cytology, and urine biomarkers for bladder cancer)

### Exclude

Cystoscopy (except as gold standard examination)

## Interventions

### Include

Surgery

Radiation therapy

Chemotherapy

Biologic therapy (biotherapy, immunotherapy)

Photodynamic therapy

## Outcomes

### Include

Morbidity

Mortality

Health-related quality of life

## Study Types

### Include

Randomized, control trials of screening vs. no screening or treatment vs. no treatment

Cohort and case-control studies of screening vs. no screening or treatment vs. no treatment

High-quality systematic reviews

Studies of diagnostic accuracy in which the screening test is compared against a reference standard (cystoscopy)

### Exclude

Case series

Non-systematic reviews