# Search Strategies

## Overall

Database: CancerLit Subsection of PubMed
Search Strategy:
1 | bladder cancer.mp. or Urinary Bladder Neoplasms/
2 | mass screening.mp. or Mass Screening/
3 | 1 and 2
4 | limit 3 to cancer
5 | from 4 keep 1–182

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
Search Strategy:
1 | (bladder adj2 (cancer$ or malign$ or tumor$ or neoplas$ or carcino$ or adenocarcino$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 | screen$.mp.
3 | (routine$ adj3 (test$ or detect$ or find$ or diagno$)).mp.
4 | 2 or 3
5 | 1 and 4
6 | (mortal$ or death$ or fatal$ or dead).mp.
7 | morbid$.mp.
8 | 6 or 7
9 | 8 and 1
10 | (accura$ or inaccura$ or reliab$ or unreliab$ or incorrect$ or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11 | (diagnos$ adj3 (mistak$ or error$ or erroneous$ or wrong$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12 | (differential$ adj2 diagnos$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13 | 10 or 11 or 12
14 | 1 and 13
15 | ((gene or genet$ or DNA) adj2 (test or tests or testing or tested)).mp.
16 | biomarker$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
17 | 15 or 16
18 | 17 and 1
19 | ((early or earli$ or time$) adj5 (detect$ or diagnos$ or discover$)).mp.
20 | 1 and 19
21 | 14 or 18 or 9 or 20 or 5
22 | from 21 keep 1–143

Database: EBM Reviews - Cochrane Database of Systematic Reviews
Search Strategy:
1 | (bladder adj2 (cancer$ or malign$ or tumor$ or neoplas$ or carcino$ or adenocarcino$)).mp. [mp=title, abstract, full text, keywords, caption text]
2 | screen$.mp.
3 | (routine$ adj3 (test$ or detect$ or find$ or diagno$)).mp.
4 | 2 or 3
5 | 1 and 4
6 | (mortal$ or death$ or fatal$ or dead).mp.
7 | morbid$.mp.
8 | 6 or 7
9 | 8 and 1
10 | (accura$ or inaccura$ or reliab$ or unreliab$ or incorrect$ or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, abstract, full text, keywords, caption text]
11 | (diagnos$ adj3 (mistak$ or error$ or erroneous$ or wrong$)).mp. [mp=title, abstract, full text, keywords, caption text]
12 | (differential$ adj2 diagnos$).mp. [mp=title, abstract, full text, keywords, caption text]
13 | 10 or 11 or 12
14 | 1 and 13
15 | ((gene or genet$ or DNA) adj2 (test or tests or testing or tested)).mp.
16 | biomarker$.mp. [mp=title, abstract, full text, keywords, caption text]
17 | 15 or 16
18 | 17 and 1
19 | ((early or earli$ or time$) adj5 (detect$ or diagnos$ or discover$)).mp.
20 | 1 and 19
21 | 14 or 18 or 9 or 20 or 5
22 | from 21 keep 1–39

## Screening

Database: Ovid MEDLINE
Search Strategy:
1 | exp Urinary Bladder Neoplasms/
2 | exp Mass Screening/
3 | 1 and 2
4 | exp Urinary Bladder Neoplasms/pa, ri, us, di, ra, pc
5 | screen$.mp.
6 | 4 and 5
7 | 6 or 3
8 | exp Vital Statistics/
9 | 8 and 7
10 | morbid$.mp.
11 | (mortal$ or death$ or fatal$ or dead).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
12 | mo.fs.
13 | 11 or 10 or 12
14 | 7 and 13
15 | 9 or 14
16 | (200$ not (2000$ or 2001$)).ed.
17 | 16 and 15
18 | from 17 keep 1–48

## Diagnostic Accuracy

Database: Ovid MEDLINE
Search Strategy:
1 | exp Urinary Bladder Neoplasms/
2 | exp Urinary Bladder Neoplasms/di
3 | exp Urinary Bladder Neoplasms/ge
4 | exp "Sensitivity and Specificity"/
5 | 3 or 2
6 | 4 and 5
7 | (accura$ or inaccura$ or reliab$ or unreliab$ or incorrect$ or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 | 5 and 7
9 | exp Diagnostic Errors/
10 | 9 and 5
11 | exp Diagnosis, Differential/
12 | 11 and 5
13 | exp biomarkers/
14 | 5 and 13
15 | exp mass screening/or screen$.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
16 | (routine$ adj3 (test$ or detect$ or find$ or diagno$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
17 | 15 or 16
18 | 6 or 8 or 10 or 12 or 14
19 | 17 and 18
20 | (200$ not (2000$ or 2001$)).ed.
21 | 19 and 20
22 | from 21 keep 1–115

## Treatment

Database: Ovid MEDLINE
Search Strategy:
1 | exp Urinary Bladder Neoplasms/th, rt, dh, su, dt [Therapy, Radiotherapy, Diet Therapy, Surgery, Drug Therapy]
2 | ((early or earli$) adj5 (detect$ or diagnos$ or discover$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
3 | 1 and 2
4 | exp Time/
5 | 4 and 1
6 | exp Prognosis/
7 | exp "Outcome Assessment (Health Care)"/
8 | 6 or 7
9 | 8 and 5
10 | exp neoplasm staging/
11 | 1 and 4 and 10
12 | exp Vital Statistics/
13 | morbid$.mp.
14 | (mortal$ or death$ or fatal$ or dead).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
15 | mo.fs.
16 | 13 or 15 or 12 or 14
17 | 16 and 5
18 | 9 or 11 or 17
19 | 3 or 18
20 | from 19 keep 1–421