# Appendixes

Appendix 1 Search Strategies

Appendix 2 Inclusion and Exclusion Criteria

Appendix 3 Literature Flow Diagram

Appendix 4 Excluded Studies

Appendix 5 U.S. Preventive Services Task Force Quality Rating Criteria

Appendix 6 Expert Reviewers of the Draft Report