# References

1 Nelson HD, Helfand M, Woolf SH, Allan JD. Screening for postmenopausal osteoporosis: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137(6):529-541. [pmid: 12230356].
2 Nelson HD, Helfand M. Screening for Postmenopausal Osteoporosis Systematic Evidence Review No 17 (Prepared by the Oregon Evidence-based Practice Center for the Agency for Healthcare Research and Quality). Rockville, MD. Agency for Healthcare Research and Quality. 2002.
3 U.sS. Preventive Services Task Force. Screening for osteoporosis in postmenopausal women: recommendations and rationale. Ann Intern Med. 2002;137(6):526-528. [pmid: 12230355].
4 U.S. Preventive Services Task Force. Screening for Osteoporosis in Postmenopausal Women. Rockville, MD. Agency for Healthcare Research and Policy. 2002.
5 Agency for Healthcare Research and Quality. The Guide to Clinical Preventive Services 2008: Recommendations of the U.S. Preventive Services Task Force. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
6 U.S. Department of Health and Human Services. Bone Health and Osteoporosis: A Report of the Surgeon General. Rockville, MD. U.S. Department of Health and Human Services. 2004.
7 Kanis JA. Assessment of fracture risk and its application to screening for post-menopausal osteoporosis. Osteoporos Int. 1994;4:368-381. [pmid: 7696835].
8 Looker AC, Orwoll ES, Johnston CC Jr, et al. Prevalence of low femoral bone density in older U.S. adults from NHANES III. J Bone Miner Res. 1997;12:1761-1768. [pmid: 9383679].
9 George A, Tracy JK, Meyer WA, et al. Racial differences in bone mineral density in older men. J Bone Miner Res. 2003;18(12):2238-2244. [pmid: 14672360].
10 Nelson DA, Jacobsen G, Barondess DA, Parfitt AM. Ethnic differences in regional bone density, hip axis length, and lifestyle variables among healthy black and white men. J Bone Miner Res. 1995;10(5):782-787. [pmid: 7639113].
11 Melton L Jr, Kan SH, Frye MA, Wahner HW, O’Fallon WM, Riggs BL. Epidemiology of vertebral fractures in women. Am J Epidemiol. 1989;129(5):1000-1011. [pmid: 2784934].
12 Heaney RP. Bone mass, bone loss and osteoporosis prophylaxis. Ann Intern Med. 1998;128:313-314. [pmid: 9471936].
13 Cauley JA, Thompson DE, Ensrud KC, Scott JC, Black D. Risk of mortality following clinical fractures. Osteoporos Int. 2000;11(7):556-561. [pmid: 11069188].
14 Center JR, Nguyen TV, Schneider D, Sambrook PN, Eisman JA. Mortality after all major types of osteoporotic fracture in men and women: an observational study. Lancet. 1999;353(9156):878-882. [pmid: 10093980].
15 Leibson CL, Tosteson AN, Gabriel SE, Ransom JE, Melton LJ. Mortality, disability, and nursing home use for persons with and without hip fracture: a population-based study. J Am Geriatr Soc. 2002;50(10):1644-1650. [pmid: 12366617].
16 Bliuc D, Nguyen ND, Milch VE, Nguyen TV, Eisman JA, Center JR. Mortality risk associated with low-trauma osteoporotic fracture and subsequent fracture in men and women. JAMA. 2009;301(5):513-521. [pmid: 19190316].
17 Ebeling PR. Clinical practice. Osteoporosis in men. New Engl J Med. 2008;358(14):1474-1482. [pmid: 18385499].
18 Cummings SR, Nevitt MC, Browner WS, Stone K, Fox KM, Ensrud KE. Risk factors for hip fracture in white women. Study of Osteoporotic Fractures Research Group. New Engl J Med. 1995;332(12):767-773. [pmid: 7862179].
19 Marshall D, Johnell O, Wedel H. Meta-analysis of how well measures of bone mineral density predict occurrence of osteoporotic fractures. BMJ. 1996;312(7041):1254-1259. [pmid: 8634613].
20 Cummings SR, Black DM, Nevitt MC, Browner W. Bone density at various sites for prediction of hip fractures. Lancet. 1993;341:72-75. [pmid: 8093403].
21 Melton LJ III, Atkinson EJ, O’Fallon WM, Wahner HW, Riggs BL. Long-term fracture prediction by bone mineral assessed at different skeletal sites. J Bone Miner Res. 1993;8:1227-1233. [pmid: 8256660].
22 Kuroda T, Miyakawa N, Miyazaki T, Shiraki M. [A-TOP Research Group/JOINT Program]. Nippon Rinsho. 2009;67(5):1017-1021. [pmid: 19432126].
23 Bone HG, Bolognese MA, Yuen CK, et al. Effects of denosumab on bone mineral density and bone turnover in postmenopausal women. J Clin Endocrinol Metab. 2008;93(6):2149-2157. [pmid: 18381571].
24 Lewiecki EM, Miller PD, McClung MR, et al. Two-year treatment with denosumab (AMG 162) in a randomized phase 2 study of postmenopausal women with low BMD. J Bone Miner Res. 2007;22(12):1832-1841. [pmid: 17708711].
25 McClung MR, Lewiecki EM, Cohen SB, et al. Denosumab in postmenopausal women with low bone mineral density. New Engl J Med. 2006;354(8):821-831. [pmid: 16495394].
26 Cummings SR, McClung MR, Christiansen C, et al. A Phase III Study of the Effects of Denosumab on Vertebral, Nonvertebral, and Hip Fracture in Women with Osteoporosis: Results from the FREEDOM Trial. Washington, DC. Abstracts of the 30th Annual Meeting of the American Society for Bone and Mineral Research. 2008.
27 Raisz LG. Pathogenesis of osteoporosis: concepts, conflicts, and prospects. J Clin Invest. 2005;115(12):3318-3325. [pmid: 16322775].
28 Goldring SR, Goldring MB. Eating bone or adding it: the WNT pathway decides. Nat Med. 2007;13(2):133-134. [pmid: 17290270].
29 McClung MR, Bone H, Cosman F, et al. A randomized, double-blind, placebo-controlled study of odanacatib (MK-822) in the treatment of postmenopausal women with low bone mineral density: 24-month results. Washington, DC. Abstracts of the 30th Annual Meeting of the American Society for Bone and Mineral Research. 2008.
30 Kiebzak GM, Beinart GA, Perser K, Ambrose CG, Siff SJ, Heggeness MH. Undertreatment of osteoporosis in men with hip fracture. Arch Intern Med. 2002;162:2217-2222. [pmid: 12390065].
31 Wilkins CH, Goldfeder JS. Osteoporosis screening is unjustifiably low in older African-American women. J Natl Med Assoc. 2004;96(4):461-467. [pmid: 15101666].
32 Morris CA, Cabral D, Cheng H, et al. Patterns of bone mineral density testing: Current guidelines, testing rates, and interventions. J Gen Intern Med. 2004;19(7):783-790. [pmid: 15209594].
33 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
34 Guirguis-Blake J, Calonge N, Miller T, et al. Current processes of the U.S. Preventive Services Task Force: refining evidence-based recommendation development. Ann Intern Med. 2007;147(2):117-122. [pmid: 17576998].
35 U.S Preventive Services Task Force Procedure Manual. Rockville, MD. Agency for Healthcare Research and Quality. 2008. Available at http:\\www.ahrq.gov/clinic/uspstf08/methods/procmanual.pdf. Accessed June 21, 201.
36 Web of Science. New York, NY. Thompson Reuters. 2010. Available at http://thomsonreuters.com/products_services/science/science_products/a-z/web_of_science. Accessed June 21, 2010.
37 Kado DM, Browner WS, Palermo L, Nevitt MC, Genant HK, Cummings SR. Vertebral fractures and mortality in older women: a prospective study. Arch Intern Med. 1999;159(11):1215-1220. [pmid: 10371229].
38 Bone HG, Downs RW Jr, Tucci JR, et al. Dose-response relationships for alendronate treatment in osteoporotic elderly women. J Clin Endocrinol Metab. 1997;82(1):265-274. [pmid: 8989272].
39 Greenspan SL, Schneider DL, McClung MR, et al. Alendronate improves bone mineral density in elderly women with osteoporosis residing in long-term care facilities. Ann Intern Med. 2002;136:742-746. [pmid: 12020142].
40 Ishida Y, Kawai S. Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: the Yamaguchi Osteoporosis Prevention Study. Am J Med. 2004;117(8):549-555. [pmid: 15465502].
41 McClung MR, Geusens P, Miller PD, et al. Effect of risedronate on the risk of hip fracture in elderly women. N Engl J Med. 2001;344(5):333-340. [pmid: 11172164].
42 Bradburn MJ, Deeks JJ, Berlin JA, Localio AR. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Statist Med. 2007;26:53-77.
43 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Statist Med. 2004;23:1351-1375.
44 Rucker G, Schwarzer G, Carpenter J, Olkin I. Why add anything to nothing? The arcsine difference as a measure of treatment effect in meta-analysis with zero cells. Statist Med. 2009;28:721-738.
45 Fogelman I, Ribot C, Smith R, Ethgen D, Sod E, Reginster JY. Risedronate reverses bone loss in postmenopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. J Clin Endocrinol Metab. 2000;85:1895-1900. [pmid: 10843171].
46 Greenspan SL, Parker RA, Ferguson L, Rosen HN, Maitland-Ramsey L, Karpf DB. Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: a randomized clinical trial. J Bone Miner Res. 1998;13:1431-1438. [pmid: 9738515].
47 Liberman UA, Weiss SR, Broll J, et al. Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis. N Engl J Med. 1995;333:1437-1443. [pmid: 7477143].
48 Montessori ML, Scheele WH, Netelenbos JC, Kerkhoff JF, Bakker K. The use of etidronate and calcium versus calcium alone in the treatment of postmenopausal osteopenia: results of three years of treatment. Osteoporos Int. 1997;7(1):52-58. [pmid: 9102064].
49 Melton LJ III, Chrischilles EA, Cooper C, Lane AW, Riggs BL. Perspective. How many women have osteoporosis?. J Bone Miner Res. 1992;7:1005-1010. [pmid: 1414493].
50 Cummings SR, Black DM, Thompson DE, et al. Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA. 1998;280(24):2077-2082. [pmid: 9875874].
51 FRAX. WHO Fracture Risk Assessment Tool Sheffield, United Kingdom: World Health Organization Collaborating Centre for Metabolic Bone Diseases. 2009. Available at www.shef.ac.uk/FRAX/. Accessed June 21, 2009.
52 Adler RA, Tran MT, Petkov VI. Performance of the osteoporosis self-assessment screening tool for osteoporosis in American men. Mayo Clin Proc. 2003;78(6):723-727. [pmid: 12934782].
53 Ben Sedrine W, Devogelaer JP, Kaufman JM, et al. Evaluation of the simple calculated osteoporosis risk estimation (SCORE) in a sample of white women from Belgium. Bone. 2001;29(4):374-380. [pmid: 11595621].
54 Brenneman S, LaCroix AZ, Buist DS, Chen YT, Abbott T. Evaluation of decision rules to identify postmenopausal women for intervention related to osteoporosis. Dis Manag. 2003;6(3):159-168. [pmid: 14570384].
55 Cadarette SM, Jaglal SB, Kreiger N, McIsaac WJ, Darlington GA, Tu JV. Development and validation of the Osteoporosis Risk Assessment Instrument to facilitate selection of women for bone densitometry. CMAJ. 2000;162(9):1289-1294. [pmid: 10813010].
56 Cadarette SM, Jaglal SB, Murray TM, et al. Evaluation of decision rules for referring women for bone densitometry by dual-energy x-ray absorptiometry. JAMA. 2001;286(1):57-63. [pmid: 11434827].
57 Cadarette S, McIsaac W, Hawker G, et al. The validity of decision rules for selecting women with primary osteoporosis for bone mineral density testing. Osteoporos Int. 2004;15(5):361-366. [pmid: 14730421].
58 Carranza-Lira S, Rosas M, Murillo A, Martinez N, Santos J. Osteoporosis in postmenopausal women (Mexico City), I. Int J Fertil Womens Med. 2002;47(1):22-25. [pmid: 11900271].
59 Carranza-Lira S, Rosas M, Murillo A, Martinez N, Santos J. Osteoporosis in postmenopausal women (Mexico City), II. Int J Fertil Womens Med. 2002;47(1):26-31. [pmid: 11900272].
60 Cass AR, Shepherd AJ, Carlson CA. Osteoporosis risk assessment and ethnicity: validation and comparison of 2 clinical risk stratification instruments. J Gen Intern Med. 2006;21:630-635. [pmid: 16808748].
61 Cook RB, Collins D, Tucker J, Zioupos P. Comparison of questionnaire and quantitative ultrasound techniques as screening tools for DXA. Osteoporos Int. 2005;16(12):1565-1575. [pmid: 15883661].
62 D’Amelio P, Tamone C, Pluviano F, Di Stefano M, Isaia G. Effects of lifestyle and risk factors on bone mineral density in a cohort of Italian women: suggestion for a new decision rule. Calcif Tissue Int. 2005;77(2):72-78. [pmid: 16059776].
63 Devlin H, Allen PD, Graham J, et al. Automated osteoporosis risk assessment by dentists: a new pathway to diagnosis. Bone. 2007;40(4):835-842. [pmid: 17188590].
64 Geusens P, Hochberg MC, van der Voort DJ, et al. Performance of risk indices for identifying low bone density in postmenopausal women. Mayo Clin Proc. 2002;77(7):629-637. [pmid: 12108600].
65 Gnudi S, Sitta E. Clinical risk factor evaluation to defer postmenopausal women from bone mineral density measurement: an Italian study. J Clin Densitom. 2005;8(2):199-205. [pmid: 15908708].
66 Gourlay ML, Miller WC, Richy F, Garrett JM, Hanson LC, Reginster JY. Performance of osteoporosis risk assessment tools in postmenopausal women aged 45–64 years. Osteoporos Int. 2005;16(8):921-927. [pmid: 16028108].
67 Harrison EJ, Adams JE. Application of a triage approach to peripheral bone densitometry reduces the requirement for central DXA but is not cost effective. Calcif Tissue Int. 2006;79(4):199-206. [pmid: 16969598].
68 Lindh C, Horner K, Jonasson G, et al. The use of visual assessment of dental radiographs for identifying women at risk of having osteoporosis: the OSTEODENT project. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2008;106(2):285-293. [pmid: 18299223].
69 Lynn HS, Woo J, Leung PC, et al. An evaluation of osteoporosis screening tools for the Osteoporotic Fractures in Men (MrOS) Study. Osteoporos Int. 2008;19(7):1087-1092. [pmid: 18239959].
70 Martinez-Aguila D, Gomez-Vaquero C, Rozadilla A, Romera M, Narvaez J, Nolla JM. Decision rules for selecting women for bone mineral density testing: application in postmenopausal women referred to a bone densitometry unit. J Rheumatol. 2007;34(6):1307-1312. [pmid: 17552058].
71 Masoni A, Morosano M, Pezzotto SM, et al. Construction of two instruments for the presumptive detection of postmenopausal women with low spinal bone mass by means of clinical risk factors. Maturitas. 2005;51(3):314-324. [pmid: 15978976].
72 Mauck KF, Cuddihy MT, Atkinson EJ, Melton LJ III. Use of clinical prediction rules in detecting osteoporosis in a population-based sample of postmenopausal women. Arch Intern Med. 2005;165(5):530-536. [pmid: 15767529].
73 Minnock E, Cook R, Collins D, Tucker J, Zioupos P. Using risk factors and quantitative ultrasound to identify postmenopausal Caucasian women at risk of osteoporosis. J Clin Densitom. 2008;11(4):485-493. [pmid: 18539491].
74 Nguyen TV, Center JR, Pocock NA, Eisman JA. Limited utility of clinical indices for the prediction of symptomatic fracture risk in postmenopausal women. Osteoporos Int. 2004;15(1):49-55. [pmid: 14593453].
75 Reginster JY, Sedrein WB, Viethel P, Micheletti MC, Chevallier T, Audran M. Validation of OSIRIS, a prescreening tool for the identification of women with an increased risk of osteoporosis. Gynecol Endocrinol. 2004;18:3-8. [pmid: 15106358].
76 Richy F, Deceulaer F, Ethgen O, Bruyere O, Reginster JY. Development and validation of the ORACLE score to predict risk of osteoporosis. Mayo Clin Proc. 2004;79(11):1402-1408. [pmid: 15544019].
77 Rud B, Jensen JE, Mosekilde L, Nielsen SP, Hilden J, Abrahamsen B. Performance of four clinical screening tools to select peri- and early postmenopausal women for dual X-ray absorptiometry. Osteoporos Int. 2005;16(7):764-772. [pmid: 15986263].
78 Russell AS, Morrison RT. An assessment of the new SCORE index as a predictor of osteoporosis in women. Scand J Rheumatol. 2001;30(1):35-39. [pmid: 11252690].
79 Salaffi F, Silveri F, Stancati A, Grassi W. Development and validation of the osteoporosis prescreening risk assessment (OPERA) tool to facilitate identification of women likely to have low bone density. Clin Rheumatol. 2005;24(3):203-211. [pmid: 15549501].
80 Sedrine WB, Chevallier T, Zegels B, et al. Development and assessment of the Osteoporosis Index of Risk (OSIRIS) to facilitate selection of women for bone densitometry. Gynecol Endocrinol. 2002;16(3):245-250. [pmid: 12192897].
81 Shepherd AJ, Cass AR, Carlson CA, Ray L. Development and internal validation of the male osteoporosis risk estimation score. Ann Fam Med. 2007;5(6):540-546. [pmid: 18025492].
82 Sinnott B, Kukreja S, Barengolts E. Utility of screening tools for the prediction of low bone mass in African American men. Osteoporosis Int. 2006;17:684-692.
83 Smeltzer SC, Zimmerman VL. Usefulness of the SCORE index as a predictor of osteoporosis in women with disabilities. Orthop Nurs. 2005;24(1):33-39. [pmid: 15722972].
84 Timmer MH, Samson MM, Monninkhof EM, De Ree B, Verhaar HJ. Predicting osteoporosis in patients with a low-energy fracture. Arch Gerontol Geriatr. 2009;49(1):e32-35. [pmid: 18835048].
85 Wallace LS, Ballard JE, Holiday D, Turner LW, Keenum AJ, Pearman CM. Evaluation of decision rules for identifying low bone density in postmenopausal African-American women. J Natl Med Assoc. 2004;96(3):290-296. [pmid: 15040510].
86 Wildner M, Peters A, Raghuvanshi VS, Hohnloser J, Siebert U. Superiority of age and weight as variables in predicting osteoporosis in postmenopausal white women. Osteoporos Int. 2003;14(11):950-956. [pmid: 13680102].
87 Ahmed LA, Schirmer H, Fonnebo V, Joakimsen RM, Berntsen GK. Validation of the Cummings’ risk score; how well does it identify women with high risk of hip fracture: the Tromso Study. Eur J Epidemiol. 2006;21(11):815-822. [pmid: 17119878].
88 Black DM, Steinbuch M, Palermo L, et al. An assessment tool for predicting fracture risk in postmenopausal women. Osteoporos Int. 2001;12(7):519-528. [pmid: 11527048].
89 Carroll J, Testa MA, Erat K, LeBoff MS, Fuleihan G el-H. Modeling fracture risk using bone density, age, and years since menopause. Am J Prev Med. 1997;13(6):447-452. [pmid: 9415791].
90 Colon-Emeric CS, Pieper CF, Artz MB. Can historical and functional risk factors be used to predict fractures in community-dwelling older adults? Development and validation of a clinical tool. Osteoporos Int. 2002;13(12):955-961. [pmid: 12459938].
91 Crabtree NJ, Kroger H, Martin A, et al. Improving risk assessment: hip geometry, bone mineral distribution and bone strength in hip fracture cases and controls. Osteoporos Int. 2002;13(1):48-54. [pmid: 11883408].
92 Dargent-Molina P, Douchin MN, Cormier C, Meunier PJ, Breart G. EPIDOS Study Group. Use of clinical risk factors in elderly women with low bone mineral density to identify women at higher risk of hip fracture: the EPIDOS prospective study. Osteoporos Int. 2002;13(7):593-599. [pmid: 12111021].
93 Dargent-Molina P, Piault S, Breart G. EPIDOS Study Group. A comparison of different screening strategies to identify elderly women at high risk of hip fracture: results from the EPIDOS Prospective Study. Osteoporos Int. 2003;14(12):969-977. [pmid: 14520511].
94 De Laet C, Oden A, Johansson H, Johnell O, Jonsson B, Kanis JA. The impact of the use of multiple risk indicators for fracture on case-finding strategies: a mathematical approach. Osteoporos Int. 2005;16(3):313-318. [pmid: 15241584].
95 Diez-Perez A, Gonzalez-Macias J, Marin F, et al. Prediction of absolute risk of non-spinal fractures using clinical risk factors and heel quantitative ultrasound. Osteoporos Int. 2007;18(5):629-639. [pmid: 17235664].
96 Donaldson MG, Palermo L, Schousboe JT, Ensrud KE, Hochberg MC, Cummings SR. FRAX and risk of vertebral fractures: the Fracture Intervention Trial. J Bone Miner Res. 2009;24:1793-1799. [pmid: 19419318].
97 Durosier C, Hans D, Krieg MA, Schott AM. Defining risk thresholds for a 10-year probability of hip fracture model that combines clinical risk factors and quantitative ultrasound: results using the EPISEM cohort. J Clin Densitom. 2008;11(3):397-403. [pmid: 18456531].
98 Ensrud KE, Lui L, Taylor BC, et al. A comparison of prediction models for fractures in older women. Arch Intern Med. 2009;169(22):2087-2094. [pmid: 20008691].
99 Ettinger B, Hillier TA, Pressman A, Che M, Hanley DA. Simple computer model for calculating and reporting 5-year osteoporotic fracture risk in postmenopausal women. J Womens Health (Larchmt). 2005;14(2):159-171. [pmid: 15775734].
100 Girman CJ, Chandler JM, Zimmerman SI, et al. Prediction of fracture in nursing home residents. J Am Geriatr Soc. 2002;50(8):1341-1347. [pmid: 12164989].
101 Hans D, Durosier C, Kanis JA, Johansson H, Schott-Pethelaz AM, Krieg MA. Assessment of the 10-year probability of osteoporotic hip fracture combining clinical risk factors and heel bone ultrasound: the EPISEM prospective cohort of 12,958 elderly women. J Bone Miner Res. 2008;23(7):1045-1051. [pmid: 18302507].
102 Henry MJ, Pasco JA, Sanders KM, Kotowicz MA, Nicholson GC. Application of epidemiology to change health policy: defining age-related thresholds of bone mineral density for primary prevention of fracture. J Clin Densitom. 2008;11(4):494-497. [pmid: 18619881].
103 Hippisley-Cox J, Coupland C. Predicting risk of osteoporotic fracture in men and women in England and Wales: prospective derivation and validation of QFractureScores. BMJ. 2009;339:b4229. [pmid: 19926696].
104 Kanis JA, Oden A, Johnell O, et al. The use of clinical risk factors enhances the performance of BMD in the prediction of hip and osteoporotic fractures in men and women. Osteoporos Int. 2007;18(8):1033-1046. [pmid: 17323110].
105 Leslie WD, Metge C, Ward L. Contribution of clinical risk factors to bone density-based absolute fracture risk assessment in postmenopausal women. Osteoporos Int. 2003;14(4):334-338. [pmid: 12730741].
106 Leslie WD, Tsang JF, Lix LM. Manitoba Bone Density Program. Simplified system for absolute fracture risk assessment: clinical validation in Canadian women. J Bone Miner Res. 2009;24(2):353-360. [pmid: 19514851].
107 McGrother CW, Donaldson MM, Clayton D, Abrams KR, Clarke M. Evaluation of a hip fracture risk score for assessing elderly women: the Melton Osteoporotic Fracture (MOF) Study. Osteoporos Int. 2002;13(1):89-96. [pmid: 11883411].
108 Miller PD, Barlas S, Brenneman SK, et al. An approach to identifying osteopenic women at increased short-term risk of fracture. Arch Intern Med. 2004;164(10):1113-1120. [pmid: 15159269].
109 Nguyen ND, Frost SA, Center JR, Eisman JA, Nguyen TV. Development of a nomogram for individualizing hip fracture risk in men and women. Osteoporos Int. 2007;18(8):1109-1117. [pmid: 17370100].
110 Pluijm SM, Koes B, de Laet C, et al. A simple risk score for the assessment of absolute fracture risk in general practice based on two longitudinal studies. J Bone Miner Res. 2009;24(5):768-774. [pmid: 19113932].
111 Richards JB, Leslie WD, Joseph L, et al. Changes to osteoporosis prevalence according to method of risk assessment. J Bone Miner Res. 2007;22(2):228-234. [pmid: 17129177].
112 Robbins J, Aragaki AK, Kooperberg C, et al. Factors associated with 5-year risk of hip fracture in postmenopausal women. JAMA. 2007;298(20):2389-2398. [pmid: 18042916].
113 Sandhu SK, Nguyen ND, Center JR, Pocock NA, Eisman JA, Nguyen TV. Prognosis of fracture: evaluation of predictive accuracy of the FRAX algorithm and Garvan nomogram. Osteoporos Int. 2010;21:863-871. [pmid: 19633880].
114 Vogt TM, Ross PD, Palermo L, et al. Vertebral fracture prevalence among women screened for the Fracture Intervention Trial and a simple clinical tool to screen for undiagnosed vertebral fractures. Mayo Clin Proc. 2000;75(9):888-896. [pmid: 10994823].
115 Wei GS, Jackson JL. Postmenopausal bone density referral decision rules: correlation with clinical fractures. Mil Med. 2004;169(12):1000-1004. [pmid: 15646195].
116 Richards JS, Amdur RL, Kerr GS. Osteoporosis risk factor assessment increases the appropriate use of dual energy X-ray absorptiometry in men and reduces ethnic disparity. J Clin Rheumatol. 2008;14(1):1-5. [pmid: 18431089].
117 LaCroix AZ, Buist DS, Brenneman SK, Abbott TA. Evaluation of three population-based strategies for fracture prevention: results of the Osteoporosis Population-Based Risk Assessment (OPRA) Trial. Med Care. 2005;43(3):293-302. [pmid: 15725986].
118 Rud B, Hilden J, Hyldstrup L, Hrobjartsson A. Performance of the Osteoporosis Self-Assessment Tool in ruling out low bone mineral density in postmenopausal women: a systematic review. Osteoporos Int. 2007;18(9):1177-1187. [pmid: 17361324].
119 Mossman EA, DeFrancisco T, Strot S, et al. OST versus weight alone in groups defined by clinical guidelines. J Clin Densitom. 2004;7:234.
120 Gambacciani M, Genazzani AR. Osteoporosis screening: comparison of the heel ultrasound measurement to calculated risk assessment tools. Osteoporos Int. 2004;15(Suppl 1):S36.
121 Kanis JA. World Health Organization Scientific Group. Assessment of osteoporosis at the primary health care level Technical Report Sheffield, United Kingdom: World Health Organization Collaborating Centre for Metabolic Bone Diseases. 2008.
122 Hillier TA, Cauley JA, Rizzo JH, et al. World Health Organization (WHO). Absolute Fracture Models in Older Women: How Does Prediction Vary for Incident Hip and Non-spine Fractures Across T-scores?. Washington, DC. Abstracts of the 30th Annual Meeting of the American Society for Bone and Mineral Research. 2008.
123 Schuit SC, van der Klift M, Weel AE, et al. Fracture incidence and association with bone mineral density in elderly men and women: the Rotterdam Study. Bone. 2004;34(1):195-202. [pmid: 14751578].
124 Van der Klift M, De Laet CE, McCloskey EV, Hofman A, Pols H. The incidence of vertebral fractures in men and women: the Rotterdam Study. J Bone Miner Res. 2002;17(6):1051-1056. [pmid: 12054160].
125 Cummings SR, Cawthon PM, Ensrud KE, et al. BMD and risk of hip and nonvertebral fractures in older men: a prospective study and comparison with older women. J Bone Miner Res. 2006;21(10):1550-1556. [pmid: 16995809].
126 Mulleman D, Legroux-Gerot I, Duquesnoy B, Marchandise X, Delcambre B, Cortet B. Quantitative ultrasound of bone in male osteoporosis. Osteoporos Int. 2002;13(5):388-393. [pmid: 12086349].
127 Gonnelli S, Cepollaro C, Gennari L, et al. Quantitative ultrasound and dual-energy X-ray absorptiometry in the prediction of fragility fracture in men. Osteoporos Int. 2005;16(8):963-968. [pmid: 15599495].
128 Bauer DC, Ewing SK, Cauley JA, et al. Quantitative ultrasound predicts hip and non-spine fracture in men: the MrOS Study. Osteoporos Int. 2007;18(6):771-777. [pmid: 17273893].
129 Hans D, Dargent-Molina T, Schott AM, Sebert JL, Cormier C, Kotzki P. Ultrasonographic heel measurements to predict hip fracture in elderly women: the EPIDOS prospective study. Lancet. 1996;348:511-514. [pmid: 8757153].
130 Bauer DC, Gluer CC, Cauley JA, et al. Broadband ultrasound attenuation predicts fractures strongly and independently of densitometry in older women: a prospective study. Arch Intern Med. 1997;157(6):629-634. [pmid: 9080917].
131 Khaw KT, Reeve J, Luben R, et al. Prediction of total and hip fracture risk in men and women by quantitative ultrasound of the calcaneus: EPIC-Norfolk prospective population study. Lancet. 2004;363(9404):197-202. [pmid: 14738792].
132 Alexandersen P, de Terlizzi F, Tanko LB, Bagger YZ, Christiansen C. Comparison of quantitative ultrasound of the phalanges with conventional bone densitometry in healthy postmenopausal women. Osteoporos Int. 2005;16(9):1071-1078. [pmid: 15719153].
133 Gluer CC, Barkmann R. Quantitative ultrasound: use in the detection of fractures and in the assessment of bone composition. Curr Osteoporos Rep. 2003;1(3):98-104. [pmid: 16036071].
134 Stewart A, Kumar V, Reid DM. Long-term fracture prediction by DXA and QUS: a 10-year prospective study. J Bone Miner Res. 2006;21(3):413-418. [pmid: 16491289].
135 Frediani B, Acciai C, Falsetti P, et al. Calcaneus ultrasonometry and dual-energy X-ray absorptiometry for the evaluation of vertebral fracture risk. Calcif Tissue Int. 2006;79(4):223-229. [pmid: 16969597].
136 Varenna M, Sinigaglia L, Adami S, et al. Association of quantitative heel ultrasound with history of osteoporotic fractures in elderly men: the ESOPO study. Osteoporos Int. 2005;16(12):1749-1754. [pmid: 15976988].
137 Nayak S, Olkin I, Liu H, et al. Meta-analysis: accuracy of quantitative ultrasound for identifying patients with osteoporosis. Ann Intern Med. 2006;144(11):832-841. [pmid: 16754925].
138 Hillier TA, Stone KL, Bauer DC, et al. Evaluating the value of repeat bone mineral density measurement and prediction of fractures in older women: the study of osteoporotic fractures. Arch Intern Med. 2007;167(2):155-160. [pmid: 17242316].
139 Ascott-Evans B, Guanabens N, Kivinen S, et al. Alendronate prevents loss of bone density associated with discontinuation of hormone replacement therapy. Arch Intern Med. 2003;163(7):789-794. [pmid: 12695269].
140 Chesnut CH III, McClung M, Ensrud K, Bell NH, Genant HK, Harris S. Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling. Am J Med. 1995;99:144-152. [pmid: 7625419].
141 Dursun N, Dursun E, Yalcin S. Comparison of alendronate, calcitonin and calcium treatments in postmenopausal osteoporosis. Int J Clin Pract. 2001;55(8):505-509. [pmid: 11695068].
142 Hosking D, Chilvers C, Christiansen C, et al. Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. New Engl J Med. 1998;338(8):485-492. [pmid: 9443925].
143 Pols H, Felsenberg D, Hanley D, et al. Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT Study. Osteoporos Int. 1999;9:461-468. [pmid: 10550467].
144 Herd R, Balena R, Blake G, Ryan P, Fogelman I. The prevention of early postmenopausal bone loss by cyclical etidronate therapy: a 2-year, double-blind, placebo-controlled study. Am J Med. 1997;103:92-99. [pmid: 9274891].
145 Meunier P, Confavreux E, Tupinon C, Hardouin C, Delmas P, Balena R. Prevention of early postmenopausal bone loss with cyclical etidronate therapy (a double-blind, placebo-controlled study and 1-year follow-up). J Clin Endocrinol Metab. 1997;82(9):2784-2791. [pmid: 9284696].
146 Pouilles J, Tremollieres F, Roux C, et al. Effects of cyclical etidronate therapy on bone loss in early postmenopausal women who are not undergoing hormonal replacement therapy. Osteoporos Int. 1997;7:213-218. [pmid: 9205633].
147 Hooper MJ, Ebeling PR, Roberts AP, et al. Risedronate prevents bone loss in early postmenopausal women: a prospective , randomized, placebo-controlled trial. Climacteric. 2005;8:251-262. [pmid: 16390757].
148 Mortensen L, Charles P, Bekker PJ, Degennaro J, Johnston CC Jr. Risedronate increases bone mass in an early postmenopausal population: two years of treatment plus one year of follow-up. J Clin Endocrinol Metab. 1998;83(2):396-402. [pmid: 9467547].
149 Valimaki M, Farrerons-Minguella J, Halse J, et al. Effects of risedronate 5 mg/d on bone mineral density and bone turnover markers in late-postmenopausal women with osteopenia: a multinational, 24-month, randomized, double-blind, placebo-controlled, parallel-group, phase III trial. Clin Ther. 2007;29(9):1937-1949. [pmid: 18035193].
150 Reid IR, Brown JP, Burckhardt P, et al. Intravenous zoledronic acid in postmenopausal women with low bone mineral density. N Engl J Med. 2002;346(9):653-661. [pmid: 11870242].
151 Greenspan SL, Bone HG, Ettinger MP, et al. Effect of recombinant human parathyroid hormone (1–84) on vertebral fracture and bone mineral density in postmenopausal women with osteoporosis: a randomized trial. Ann Intern Med. 2007;146(5):326-339. [pmid: 17339618].
152 Delmas PD, Ensrud KE, Adachi JD, et al. Efficacy of raloxifene on vertebral fracture risk reduction in postmenopausal women with osteoporosis: four-year results from a randomized clinical trial. J Clin Endocrinol Metab. 2002;87(8):3609-3617. [pmid: 12161484].
153 Ettinger B, Black DM, Mitlak BH, et al. Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. JAMA. 1999;282(7):637-645. [pmid: 10517716].
154 Barrett-Connor E, Mosca L, Collins P, et al. Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. New Engl J Med. 2006;355(2):125-137. [pmid: 16837676].
155 Nelson HD, Fu R, Humphrey L, Smith ME, Griffin J, Nygren P. Comparative Effectiveness of Medications to Reduce Risk of Primary Breast Cancer in Women. Comparative Effectiveness Review No. 17. (Prepared by Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-1). Rockville, MD. Agency for Healthcare Research and Quality. 2009.
156 Nelson HD, Fu R, Griffin JC, Nygren P, Smith ME, Humphrey LL. Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann Intern Med. 2009;151(10):703-715. [pmid: 19920271].
157 Cauley JA, Robbins J, Chen Z, et al. Effects of estrogen plus progestin on risk of fracture and bone mineral density: the Women’s Health Initiative randomized trial. JAMA. 2003;290(13):1729-1738. [pmid: 14519707].
158 Anderson GL, Limacher M, Assaf AR, et al. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women’s Health Initiative randomized controlled trial. JAMA. 2004;291(14):1701-1712. [pmid: 15082697].
159 Orwoll E, Scheele WH, Paul S, et al. The effect of teriparatide (human parathyroid hormone I-34) therapy on bone mineral density in postmenopausal men with osteoporosis. J Bone Miner Res. 2003;18:9-17. [pmid: 12510800].
160 Kaufman JM, Orwoll E, Goemaere S, et al. Teriparatide effects on vertebral fractures and bone mineral density in men with osteoporosis: treatment and discontinuation of therapy. Osteoporos Int. 2005;16(5):510-516. [pmid: 15322742].
161 Wells GA, Cranney A, Peterson J, et al. Risedronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008;4:4.
162 Wells GA, Cranney A, Peterson J, et al. Alendronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008;4:4.
163 Wells GA, Cranney A, Peterson J, et al. Etidronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008;4:4.
164 Sawka A, Papaioannou A, Adachi JD, Gafni A, Hanley DA, Thabane L. Does alendronate reduce the risk of fracture in men? a meta-analysis incorporating prior knowledge of anti-fracture efficacy in women. BMC Musculoskelet Disord. 2005;6:39-46. [pmid: 16008835].
165 Orwoll E, Ettinger M, Weiss S, et al. Alendronate for the treatment of osteoporosis in men. N Engl J Med. 2000;343(9):604-610. [pmid: 10979796].
166 Ringe JD, Dorst A, Faber H, Ibach K. Alendronate treatment of established primary osteoporosis in men: 3-year results of a prospective, comparative, two-arm study. Rheumatol Int. 2004;24(2):110-113. [pmid: 13680141].
167 Chesnut C, Ettinger M, Miller P, et al. Ibandronate produces significant, similar antifracture efficacy in North American and European women: new clinical findings from BONE. Curr Med Res Opin. 2005;21(3):391-401. [pmid: 15811208].
168 Recker R, Stakkestad JA, Chesnut CH, et al. Insufficiently dosed intravenous ibandronate injections are associated with suboptimal antifracture efficacy in postmenopausal osteoporosis. Bone. 2004;34(5):890-899. [pmid: 15121021].
169 Delmas PD, Adami S, Strugala C, et al. Intravenous ibandronate injections in postmenopausal women with osteoporosis: one-year results from the Dosing IntraVenous Administration study. Arthritis Rheum. 2006;54:1838-1846. [pmid: 16729277].
170 Eisman JA, Garcia-Hernandez PA, Ortiz-Luna G, et al. Intermittent intravenous ibandronate injections are an effective treatment option in postmenopausal osteoporosis: 2-year results from DIVA. Osteoporos Int. 2006;17:S212.
171 Miller PD, McClung MR, Macovei L, et al. Monthly oral ibandronate therapy in postmenopausal osteoporosis: 1-year results from the MOBILE study. J Bone Miner Res. 2005;20:1315-1322. [pmid: 16007327].
172 Reginster JY, Adami S, Lakatos P, et al. Efficacy and tolerability of once-monthly oral ibandronate in postmenopausal osteoporosis: 2-year results from the MOBILE study. Ann Rheum Dis. 2006;65:654-661. [pmid: 16339289].
173 Harris ST, Blumentals WA, Miller PD. Ibandronate and the risk of nonvertebral and clinical fractures in women with postmenopausal osteoporosis: results of a meta-analysis of phase III studies. Curr Med Res Opin. 2008;24(1):237-245. [pmid: 18047776].
174 Black D, Delmas P, Eastell R, et al. Once-yearly zoledronic acid for treatment of postmenopausal osteoporosis. New Engl J Med. 2007;356(18):1809-1822. [pmid: 17476007].
175 Lyles KW, Colon-Emeric CS, Magaziner JS, et al. Zoledronic acid and clinical fractures and mortality after hip fracture. N Engl J Med. 2007;357(18):1799-1809. [pmid: 17878149].
176 Cranney A, Tugwell P, Zytaruk N, et al. Meta-analyses of therapies for postmenopausal osteoporosis, VI: meta-analysis of calcitonin for the treatment of postmenopausal osteoporosis. Endocr Rev. 2002;23(4):540-551. [pmid: 12202469].
177 Chesnut CH, Silverman S, Andriano K, et al. A randomized trial of nasal spray salmon calcitonin in postmenopausal women with established osteoporosis: the Prevent Recurrence of Osteoporotic Fractures Study. Am J Med. 2000;109(4):267-276. [pmid: 10996576].
178 Hizmetli S, Elden H, Kaptanoglu E, Nacitarhan V, Kocagli S. The effect of different doses of calcitonin on bone mineral density and fracture risk in postmenopausal women. Int J Clin Pract. 1996;52:453-455. [pmid: 10622084].
179 Overgaard K, Hansen MA, Jensen SB, Christiansen C. Effect of salcalcitonin given intranasally on bone mass and fracture rates in established osteoporosis: a dose-response study. BMJ. 1992;305:556-561. [pmid: 1393035].
180 Gennari C, Chierichetti SM, Bigazzi S, et al. Comparative effects on bone mineral content of calcium plus salmon calcitonin given in two different regimens in postmenopausal osteoporosis. Curr Ther Res. 1985;38:455-462.
181 Rico H, Revilla M, Hernandez E, Villa LF, Alverex de Buergo M. Total and regional bone mineral content and fracture rate in postmenopausal osteoporosis treated with salmon calcitonin: a prospective study. Calcif Tissue Int. 1995;56:181-185. [pmid: 7750020].
182 Greenspan DL, Bone H, Marriott TB, et al. Preventing the first vertebral fracture in postmenopausal women with low bone mass using PTH (I-84): results from the TOP study. J Bone Miner Res. 2005;20:S56.
183 Kurland ES, Cosman F, McMahon DJ, et al. Parathyroid hormone as therapy for idiopathic osteoporosis in men: effects on bone mineral density and bone markers. J Clin Endocrinol Metab. 2000;85:3069-3076. [pmid: 10999788].
184 Neer RM, Arnaud CD, Zanchetta J, et al. Effect of parathyroid hormone (I-34) on fractures and bone mineral density in postmenopausal women with osteoporosis. N Engl J Med. 2001;344:1434-1441. [pmid: 11346808].
185 Vestergaard P, Jorgensen NR, Mosekilde L, Schwarz P. Effects of parathyroid hormone alone or in combination with antiresorptive therapy on bone mineral density and fracture risk: a meta-analysis. Osteoporos Int. 2007;18(1):45-57. [pmid: 16951908].
186 Tracz MJ, Sideras K, Bolona ER, et al. Testosterone use in men and its effects on bone health: a systematic review and meta-analysis of randomized placebo-controlled trials. J Clin Endocrinol Metab. 2006;91(6):2011-2016. [pmid: 16720668].
187 MacLean C, Newberry S, Maglione M, et al. Systematic review: Comparative effectiveness of treatments to prevent fractures in men and women with low bone density or osteoporosis. Ann Intern Med. 2008;148(3):197-213. [pmid: 18087050].
188 Cadarette SM, Katz JN, Brookhart MA, Sturmer T, Stedman MR, Solomon DH. Relative effectiveness of osteoporosis drugs for preventing nonvertebral fracture. Ann Intern Med. 2008;148(9):637-646. [pmid: 18458276].
189 Heckbert SR, Li G, Cummings SR, Smith NL, Psaty BM. Use of alendronate and risk of incident atrial fibrillation in women. Arch Intern Med. 2008;168(8):826-831. [pmid: 18443257].
190 Karam R, Camm J, Mcclung M. Yearly zoledronic acid in postmenopausal osteoporosis. New Engl J Med. 2007;357(7):712. [pmid: 17703529].
191 Sorensen HT, Christensen S, Mehnert F, et al. Use of bisphosphonates among women and risk of atrial fibrillation and flutter: population based case-control study. BMJ. 2008;336(7648):813-816. [pmid: 18334527].
192 U.S. Food and Drug Administration. Update of Safety Review Follow-up to the October 1, 2007 Early Communication About the Ongoing Safety Review of Bisphosphonates. Rockville, MD. U.S. Food and Drug Administration. 2008.
193 Office of Drug Safety. ODS Postmarketing Safety Review. Rockville, MD. U.S. Food and Drug Administration. 2004. Available at www.fda.gov/ohrms/dockets/ac/05/briefing/2005-4095B2_03_04-FDA-TAB3.pdf. Accessed June 21, 2010.
194 Chesnut IC, Skag A, Christiansen C, et al. Effects of oral ibandronate administered daily or intermittently on fracture risk in postmenopausal osteoporosis. J Bone Miner Res. 2004;19(8):1241-1249. [pmid: 15231010].
195 McClung M, Wasnich RD, Recker R, et al. Oral daily ibandronate prevents bone loss in early postmenopausal women without osteoporosis. J Bone Miner Res. 2004;19(1):11-18. [pmid: 14753731].
196 de Groen PC, Lubbe DF, Hirsch LJ, et al. Esophagitis associated with the use of alendronate. N Engl J Med. 1996;335:1016-1021. [pmid: 8793925].
197 van Staa T, Abenhaim L, Cooper C. Upper gastrointestinal adverse events and cyclical etidronate. Am J Med. 1997;103(6):462-467. [pmid: 9428828].
198 Cryer B, Bauer DC. Oral bisphosphonates and upper gastrointestinal tract problems: what is the evidence?. Mayo Clin Proc. 2002;77:1031-1043. [pmid: 12374247].
199 Wysowski DK. Reports of esophageal cancer with oral bisphosphonate use. N Engl J Med. 2009;360:889-890.
200 Cummings S, Schwartz A, Black D. Alendronate and atrial fibrillation. New Engl J Med. 2007;356(18):1895-1896. [pmid: 17476024].
201 Shiraki M, Fukunaga M, Kushida K, et al. A double-blind dose-ranging study of risedronate in Japanese patients with osteoporosis (a study by the Risedronate Late Phase II Research Group). Osteoporos Int. 2003;14:225-234. [pmid: 12730746].
202 Goh SK, Yang KY, Koh JS, et al. Subtrochanteric insufficiency fractures in patients on alendronate therapy. J Bone Joint Surg (Br). 2007;89B:349-353. [pmid: 17356148].
203 Lenart BA, Lorich DG, Lane JM. Atypical fractures of the femoral diaphysis in postmenopausal women taking alendronate. N Engl J Med. 2008;358:1304-1306. [pmid: 18354114].
204 Odvina CV, Zerwekh JE, Rao S, Maalouf N, Gottschalk FA, Pak CY. Severely suppressed bone turnover: a potential complication of alendronate therapy. J Clin Endrocrinol Metab. 2005;90:1294-1301.
205 Grbic J, Landesberg R, Lin SQ, et al. Incidence of osteonecrosis of the jaw in health outcomes and reduced incidence with zoledronic acid once yearly pivotal fracture trial. J Am Dent Assoc. 2008;139(1):32-40. [pmid: 18167382].
206 Writing Group for the Women’s Health Initiative Investigators. Risks and benefits of estrogen plus progestin in healthy postmenopausal women. JAMA. 2002;288:321-333. [pmid: 12117397].
207 Chlebowski RT, Hendrix SL, Langer RD, et al. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative Randomized Trial. JAMA. 2003;289(24):3243-3253. [pmid: 12824205].
208 Manson JE, Hsia J, Johnson KC, et al. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003;349(6):523-534. [pmid: 12904517].
209 Rossouw JE, Prentice RL, Manson JE, et al. Postmenopausal hormone therapy and risk of cardiovascular disease by age and years since menopause. JAMA. 2007;297(13):1465-1477. [pmid: 17405972].
210 Stefanick ML, Anderson GL, Margolis KL, et al. Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA. 2006;295(14):1647-1657. [pmid: 16609086].
211 Hsia J, Criqui MH, Herrington DM, et al. Conjugated equine estrogens and peripheral arterial disease risk: the Women’s Health Initiative. Am Heart J. 2006;152(1):170-176. [pmid: 16824852].
212 Cushman M, Kuller LH, Prentice R, et al. Estrogen plus progestin and risk of venous thrombosis. JAMA. 2004;292(13):1573-1580. [pmid: 15467059].
213 Curb JD, Prentice RL, Bray PF, et al. Venous thrombosis and conjugated equine estrogen in women without a uterus. Arch Intern Med. 2006;166(7):772-780. [pmid: 16606815].
214 Wassertheil-Smoller S, Hendrix SL, Limacher M, et al. Effect of estrogen plus progestin on stroke in postmenopausal women: the Women’s Health Initiative, a randomized trial. JAMA. 2003;289(20):2673-2684. [pmid: 12771114].
215 Anderson GL, Judd HL, Kaunitz AM, et al. Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women’s Health Initiative randomized trial. JAMA. 2003;290(13):1739-1748. [pmid: 14519708].
216 Black DM, Kelly MP, Genant HK, et al. Bisphosphonates and fractures of the subtrochanteric or diaphyseal femur. N Engl J Med. 2010;362(19):1761-1771. [pmid: 20335571].
217 Kern LM, Powe NR, Levine MA, et al. Association between screening for osteoporosis and the incidence of hip fracture. Ann Intern Med. 2005;142(3):173-181. [pmid: 15684205].
218 Buist DSM, LaCroix AZ, Brenneman SK, Abbott T. A population-based osteoporosis screening program: who does not participate, and what are the consequences?. J Am Geriatr Soc. 2004;52(7):1130-1137. [pmid: 15209651].
219 Buist DS, LaCroix AZ, Manfredonia D, Abbott T. Identifying postmenopausal women at high risk of fracture in populations: a comparison of three strategies. J Am Geriatr Soc. 2002;50(6):1031-1038. [pmid: 12110062].
220 Barr RJ, Stewart A, Torgerson DJ, Seymour DG, Reid DM. Screening elderly women for risk of future fractures: participation rates and impact on incidence of falls and fractures. Calcif Tissue Int. 2005;76(4):243-248. [pmid: 15812582].
221 Lafata JE, Kolk D, Peterson EL, et al. Improving osteoporosis screening: results from a randomized cluster trial. J Gen Intern Med. 2007;22(3):346-351. [pmid: 17356966].
222 Hodgson SF, Watts NB, Bilezikian JP, et al. American Association of Clinical Endocrinologists Medical Guidelines for Clinical Practice for the Prevention and Treatment of Postmenopausal Osteoporosis: 2001 edition, with selected updates for 2003. Endocr Pract. 2003;9(6):544-564. [pmid: 14715483].
223 American Academy of Family Physicians. Recommendations for Clinical preventive Services: screening for osteoporosis in postmenopausal women. Leawood, KS. American Academy of Family Physicians. 2002. Available at www.aafp.org/online/en/home/clinical/exam/k-o.html. Accessed June 21, 2010.
224 Qaseem A, Snow V, Shekelle P, Hopkins R, Forciea M, Owens D. Screening for osteoporosis in men: a clinical practice guideline from the American College of Physicians. Ann Intern Med. 2008;148:680-684. [pmid: 18458281].
225 International Society for Clinical Densitometry. Official Positions of the International Society of Clinical Densitometry. West Hartford, CT. International Society for Clinical Densitometry. 2007. Available at www.iscd.org/Visitors/pdfs/ISCD2007OfficialPositions-Adult.pdf. Accessed June 21, 2010.
226 National Institutes of Health. Osteoporosis prevention, diagnosis, and therapy. NIH Consens Statement. 2000;17(1):1-36.
227 National Osteoporosis Foundation. Clinician’s Guide to Prevention and Treatment of Osteoporosis. Washington, DC. National Osteoporosis Foundation. 2008. Available at www.nof.org/professionals/NOF_Clinicians_Guide.pdf. Accessed June 21, 2010.
228 Royal College of Physicians. Osteoporosis: Clinical Guidelines for Prevention and Treatment. London. Royal College of Physicians. 2000. Available at www.rcplondon.ac.uk/pubs/wp/wp_osteo_update.htm. Accessed June 21, 2010.
229 United Kingdom National Screening Committee. National Screening Committee Policy: Osteoporosis Screening. London. National Screening Committee. 2006. Available at www.library.nhs.uk/screening/viewResource.aspx?catID=5534&resID=61088. Accessed June 21, 2010.
230 WHO Scientific Group on the Assessment of Osteoporosis at Primary Health Care Level. Summary Meeting Report. Geneva. World Health Organization. 2007. Available at www.who.int/chp/topics/Osteoporosis.pdf. Accessed June 21,2010.
231 Glüer MG, Minne HW, Glüer CC, et al. Prospective identification of postmenopausal osteoporotic women at high vertebral fracture risk by radiography, bone densitometry, quantitative ultrasound, and laboratory findings. J Clin Densitom. 2005;8(4):386-395. [pmid: 16311422].
232 Cummings SR. Prevention of hip fractures in older women: a population-based perspective. Osteoporos Int. 1998;8(Suppl 1):S8-S12. [pmid: 9682790].
233 Siris ES, Harris ST, Eastell R, et al. Skeletal effects of raloxifene after 8 years: results from the Continuing Outcomes Relevant to Evista (CORE) Study. J Bone Miner Res. 2005;20(9):1514-1524. [pmid: 16059623].
234 Ensrud KE, Stock JL, Barrett-Connor E, et al. Effects of raloxifene on fracture risk in postmenopausal women: the Raloxifene Use for the Heart Trial. J Bone Miner Res. 2008;23(1):112-120. [pmid: 17892376].
235 Chlebowski RT, Wactawski-Wende J, Ritenbaugh C, et al. Estrogen plus progestin and colorectal cancer in postmenopausal women. N Engl J Med. 2004;350:991-1004. [pmid: 14999111].
236 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. Institute for Health and Clinical Excellence. 2006.
237 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271-1278. [pmid: 1834807].
238 Greenfield DM, Walters SJ, Coleman RE, et al. Prevalence and consequences of androgen deficiency in young male cancer survivors in a controlled cross-sectional study. J Clin Endocrinol Metab. 2007;92(9):3476-3482. [pmid: 17579201].
239 Black DM, Cummings SR, Karpf DB, et al. Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Lancet. 1996;348(9041):1535-1541. [pmid: 8950879].
240 Lyritis GP, Tsakalakos N, Paspati I, Skarantavos G, Galanos A, Androulakis C. The effect of a modified etidronate cyclical regimen on postmenopausal osteoporosis: a 4-year study. Clin Rheumatol. 1997;16(4):354-360. [pmid: 9259248].
241 Pacifici R, McMurtry C, Vered I, Rupich R, Avioli L. Coherence therapy does not prevent axial bone loss in osteoporotic women: a preliminary comparative study. J Clin Endocrinol Metab. 1988;66(4):747-753. [pmid: 3126214].
242 Shiota E, Tsuchiya K, Yamaoka K, Kawano O. Effect of intermittent cyclical treatment with etidronate disodium (HEBP) and calcium plus alphacalcidol in postmenopausal osteoporosis. J Orthop Sci. 2001;6:133-136. [pmid: 11484098].
243 Storm T, Thamsborg G, TS. Effect of intermittent cyclical etidronate therapy on bone mass and fracture rate in women with postmenopausal osteoporosis. New Engl J Med. 1990;322(18):1265-1271. [pmid: 2109197].
244 Watts N, Harris S, Harry M, et al. Intermittent cyclical etidronate treatment of postmenopausal osteoporosis. N Engl J Med. 1990;323(2):73-79. [pmid: 2113611].
245 Wimalawansa SJ. A 4-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med. 1998;104:219-226. [pmid: 9552083].
246 Clemmesen B, Ravn P, Zegels B, Taquet AN, Christiansen C, Reginster JY. A 2-year phase II study with 1-year of follow-up of risedronate (NE-58095) in postmenopausal osteoporosis. Osteoporos Int. 1997;7:488-495. [pmid: 9425508].
247 Harris ST, Watts NB, Genant HK. Vertebral Efficacy with Risedronate Therapy (VERT) Study Group. Effects of risedronate treatment on vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: a randomized controlled trial. JAMA. 1999;282(14):1344-1352. [pmid: 10527181].
248 Reginster JY, Minne HW, Sorensen OH, et al. Randomized trial of the effects of risedronate on vertebral fractures in women with established postmenopausal osteoporosis. Osteoporos Int. 2000;11(1):83-91. [pmid: 10663363].