# Discussion

## Summary of Review Findings

Table 10 summarizes the evidence reviewed for this update, and an outcomes table providing an illustration of the clinical application of the evidence is described in Table 11 and Figure 2 and Figure 3. No RCTs evaluated the overarching questions of the effectiveness and harms of screening for osteoporosis in reducing fractures and fracture-related outcomes for postmenopausal women and men. Therefore, no direct evidence that screening improves outcomes is available. Support for population screening would be based on evidence that individual risk for fracture can be estimated and fractures can be significantly reduced for those at risk.

Figure 2 Number of Women Needed to Screen to Prevent One Fracture in 5 Years

This figure is a graph depicting the number of women who need to undergo screening to prevent one osteoporosis-related fracture in 5 years. The horizontal axis represents the woman’s age in years. There are five categories: women ages 55 to 59; women ages 60 to 64; women ages 65 to 69; women ages 70 to 74; and women ages 75 to 79. The vertical axis represents the number of women needed to screen, and it ranges from 0 to 1,800 in increments of 200. The data points connected by the dotted line correspond to the number of women who need to be screened to prevent one case of hip fracture. The line begins with about 1,700 women needing to be screened between the ages of 55 and 59 and gradually decreases to about 300 women needing to be screened after the age of 75. The data points connected by the dashed line correspond to the number of women who need to be screened to prevent one case of vertebral fracture. The line begins with about 700 women needing to be screened between the ages of 55 and 59 and gradually decreases to about 100 women needing to be screened after the age of 75. The data points connected by the solid line correspond to the number of women who need to be screened to prevent one case of clinical fracture. The line begins with about 300 women needing to be screened between the ages of 55 and 59 and gradually decreases to about 50 women needing to be screened after the age of 75.

Figure 3 10-year Risks for Major Osteoporotic and Hip Fractures for Women from the FRAX Calculator

Abbreviations: BMI = body mass index; FRAX = online risk calculator (http://www.shef.ac.uk/FRAX/).

*Normal BMI=25.0 kg/m^2^ based on average height 163 cm (64 in.), weight 66.5 kg (147 lbs). Low BMI=22.1 kg/m 2 based on average height (163 cm (64 in.), weight 56.7 kg (125 lbs).

†Daily alcohol use of 3 or more units/day (approximately 3 oz.).

This figure depicts a woman’s risk of having a major osteoporotic or hip fracture in the next 10 years, based on her age and risk factors. The risk is calculated using FRAX, the World Health Organization’s risk assessment tool for osteoporosis. The results are grouped on the basis of the number and type of risk factors present. The first category includes women who have none or one risk factor for osteoporotic fracture. For women who have no risk factors, the 10-year risk of osteoporotic fracture is 3.7 at age 50; 5.7 at age 55; 7.6 at age 60; 9.3 at age 65; 12.0 at age 70; 15.0 at age 75; 20.0 at age 80; 23.0 at age 85; and 20.0 at age 90. For women who have a low body mass index (BMI) (normal BMI is defined as 25.0 kg/m2, based on an average height of 163 cm [64 in] and weight of 66.5 kg [147 lbs]; low BMI is defined as 22.1 kg/m2, based on an average height of 163 cm [64 in] and weight of 56.7 kg [125 lbs]), the 10-year risk of osteoporotic fracture is 3.8 at age 50; 5.9 at age 55; 7.9 at age 60; 9.8 at age 65; 12.0 at age 70; 16.0 at age 75; 22.0 at age 80; 24.0 at age 85; and 21.0 at age 90. For women who have a parental history of hip fracture, the 10-year risk of osteoporotic fracture is 7.3 at age 50; 11.0 at age 55; 15.0 at age 60; 18.0 at age 65; 18.0 at age 70; 25.0 at age 75; 34.0 at age 80; 39.0 at age 85; and 35.0 at age 90. For women who smoke, the 10-year risk of osteoporotic fracture is 3.9 at age 50; 6.0 at age 55; 8.1 at age 60; 10.0 at age 65; 13.0 at age 70; 16.0 at age 75; 22.0 at age 80; 25.0 at age 85; and 21.0 at age 90. For women who consume three or more units of alcohol (approximately 3 oz) per day, the 10-year risk of osteoporotic fracture is 4.4 at age 50; 6.9 at age 55; 9.1 at age 60; 11.0 at age 65; 14.0 at age 70; 19.0 at age 75; 25.0 at age 80; 28.0 at age 85; and 25.0 at age 90. The second category includes women who have none or one risk factor for hip fracture. For women who have no risk factors, the 10-year risk of hip fracture is 0.2 at age 50; 0.4 at age 55; 0.7 at age 60; 1.2 at age 65; 2.4 at age 70; 4.6 at age 75; 7.6 at age 80; 9.4 at age 85; and 8.7 at age 90. For women who have a low BMI, the 10-year risk of hip fracture is 0.3 at age 50; 0.6 at age 55; 1.0 at age 60; 1.9 at age 65; 3.6 at age 70; 6.8 at age 75; 11.0 at age 80; 13.0 at age 85; and 12.0 at age 90. For women who have a parental history of hip fracture, the 10-year risk of hip fracture is 0.3 at age 50; 0.5 at age 55; 0.9 at age 60; 1.6 at age 65; 5.0 at age 70; 15.0 at age 75; 24.0 at age 80; 29.0 at age 85; and 26.0 at age 90. For women who smoke, the 10-year risk of hip fracture is 0.3 at age 50; 0.5 at age 55; 1.0 at age 60; 1.8 at age 65; 3.5 at age 70; 6.5 at age 75; 11.0 at age 80; 13.0 at age 85; and 11.0 at age 90. For women who consume three or more units of alcohol per day, the 10-year risk of hip fracture is 0.3 at age 50; 0.5 at age 55; 1.0 at age 60; 1.9 at age 65; 3.6 at age 70; 6.9 at age 75; 11.0 at age 80; 14.0 at age 85; and 13.0 at age 90. The third category includes women who have more than one risk factor for osteoporotic or hip fracture. For women who have a low BMI and a parental history of hip fracture, the 10-year risk of fracture is 7.4/0.4 at age 50; 11.0/0.7 at age 55; and 15.0/1.4 at age 60. For women who have a low BMI and smoke, the 10-year risk of fracture is 4.0/0.5 at age 50; 6.2/0.8 at age 55; and 8.5/1.5 at age 60. For women who have a low BMI and consume three or more units of alcohol per day, the 10-year risk of fracture is 4.5/0.5 at age 50; 7.1/0.8 at age 55; and 9.6/1.6 at age 60. For women who have a parental history of hip fracture and smoke, the 10-year risk of fracture is 7.6/0.4 at age 50; 12.0/0.7 at age 55; and 15.0/1.3 at age 60. For women who have a parental history of hip fracture and consume three or more units of alcohol per day, the 10-year risk of fracture is 8.7/0.4 at age 50; 13.0/0.7 at age 55; and 17.0/1.3 at age 60. For women who smoke and consume three or more units of alcohol per day, the 10-year risk of fracture is 4.6/0.4 at age 50; 7.2/0.8 at age 55; and 9.8/1.5 at age 60. For women who have a low BMI, a parental history of hip fracture, and smoke, the 10-year risk of fracture is 7.8/0.6 at age 50; 12.0/1.1 at age 55; and 16.0/2.0 at age 60. For women who have a low BMI, a parental history of hip fracture, and consume three or more units of alcohol per day, the 10-year risk of fracture is 8.8/0.6 at age 50; 14.0/1.1 at age 55; and 18.0/2.1 at age 60. For women who have a low BMI, smoke, and consume three or more units of alcohol per day, the 10-year risk of fracture is 4.9/0.7 at age 50; 7.6/1.3 at age 55; and 10.0/2.3 at age 60. For women who have a parental history of hip fracture, smoke, and consume three or more units of alcohol per day, the 10-year risk of fracture is 9.1/0.6 at age 50; 14.0/1.1 at age 55; and 18.0/2.0 at age 60. For women who have all four risk factors (low BMI, parental history of hip fracture, smoke, and consume three or more units of alcohol per day), the 10-year risk of fracture is 9.3/0.9 at age 50; 14.0/1.7 at age 55; and 19.0/3.1 at age 60.

Table 10 Summary of the Evidence

Number of studies | Design | Limitations | Consistency | Applicability | Overall quality | Findings
Effectiveness and Harms of Osteoporosis Screening in Reducing Fractures, Morbidity, and Mortality (Key Questions 1 and 4)
No trials
Performance of Risk Assessment Instruments to Stratify Individuals into Risk Categories (Key Question 2)
21 risk assessment instruments (in 33 articles) with BMD or fracture outcomes that reported AUC for the ROC curve and were externally validated; Subset of 64 total articles of risk assessment instruments | Cohort, cross-sectional | Most studies are cross-sectional and instruments have not been applied to a prospective clinical population | Not consistent | Difficult to apply population-determined results to individuals in a clinical setting | Fair | Although several risk instruments have been developed and validated, their performance in predicting low bone density or fracture is modest; simple models perform as well as complex ones, and none demonstrates superiority over the others.
Performance of Dual-energy X-ray Absorptiometry in Predicting Fractures in Men (Key Question 3a)
5 studies | Prospective cohort | Few large studies include men | Consistent | Population estimates may not apply to individuals | Fair to good | DXA is not a perfect predictor, but for each standard deviation reduction in femoral neck BMD, the hazard ratio for various fracture outcomes was increased to similar levels for men and women.
Performance of Peripheral Bone Measurement Tests in Predicting Fractures (Key Question 3b)
5 studies in men; 7 studies in postmenopausal women; and 1 systematic review | Prospective cohort, retrospective cohort, cross-sectional | Variability in how measures were used; focus on QUS | Consistent | Population estimates may not apply to individuals | Fair to good | Calcaneal QUS can predict fractures of the femoral neck, hip, or spine, although variation exists across studies. Correlation between DXA and QUS is low.
Screening Intervals (Key Question 3c)
1 study | Prospective cohort | Only one relevant study in postmenopausal women | Not applicable | Population estimates may not apply to individuals, particularly those different from the study cohort | Fair | Repeating a BMD measurement up to 8 years after an initial measurement did not significantly improve predictive performance for nonvertebral, hip, or vertebral fractures.
Efficacy of Medications for Reducing Osteoporosis-related Fractures (Key Question 5)
For women: 15 trials of bisphosphonates; 1 trial of PTH; 2 trials and 1 meta-analysis of raloxifene; 2 trials of estrogen For men: 1 trial of PTH | RCTs | Strength of evidence varies by medication | Consistent | Primary prevention trials are most applicable to a screen-detected population | Poor to good | For women, bisphosphonates, PTH, raloxifene, and estrogen with or without progestin reduce vertebral fractures. Bisphosphonates reduce nonvertebral fractures in sensitivity analysis. Medications are effective for BMD T-scores ≤ −2.5. For men, one trial of PTH showed trends for reduced fractures that were not statistically significant.
Harms Associated with Medications for Osteoporosis and Low Bone Density (Key Question 6)
21 studies of bisphosphonates; 1 systematic review of calcitonin and PTH; 5 studies of raloxifene; 8 studies of estrogen | RCTs, observational studies, case reports and series | Strength of evidence varies by medication | Consistent | Applicable | Poor to good | Serious GI events have been reported for all bisphosphonates, but they are not associated with a higher rate of serious GI events compared to placebo in controlled studies; results are mixed for atrial fibrillation and an FDA review found no increased risk. There are case reports of osteonecrosis, severe musculoskeletal pain, and esophageal cancer, but the incidence and degree of risk are difficult to estimate. Raloxifene and estrogen increase thromboembolic events; estrogen increases stroke; estrogen with progestin increases coronary heart disease and breast cancer.

Abbreviations: AUC = area under the curve; BMD = bone mineral density; DXA = dual energy x-ray absorptiometry; FDA = U.S. Food and Drug Administration; GI = gastrointestinal; PTH = parathyroid hormone; QUS = quantitative ultrasound; RCTs = randomized controlled trials; ROC = receiver operating characteristic.

Table 11 Screening Outcomes for Women Without Prior Vertebral Fractures

Assumptions based on population estimates and results of the Fracture Intervention Trial (FIT) for women with T-score ≤ −2.5.
| Age (years)
Variable | 55–59 | 60–64 | 65–69 | 70–74 | 75–79
Assumptions
Number undergoing screening | 10,000 | 10,000 | 10,000 | 10,000 | 10,000
Prevalence of osteoporosis (T-score −2.5 or less)^*^ | 0.0445 | 0.0650 | 0.1200 | 0.2025 | 0.2850
RR for clinical fracture with alendronate (95% CI 0.50–0.82)^†^ | 0.64 | 0.64 | 0.64 | 0.64 | 0.64
RR for vertebral fracture with alendronate (95% CI 0.31–0.82)^†^ | 0.50 | 0.50 | 0.50 | 0.50 | 0.50
RR for hip fracture with alendronate (95% CI 0.18–0.97)^†^ | 0.44 | 0.44 | 0.44 | 0.44 | 0.44
Outcomes, n
Cases of osteoporosis identified (10,000 x prevalence) | 445 | 650 | 1200 | 2025 | 2850
Clinical fractures expected with no therapy (24.50%)^†^ | 109 | 159 | 294 | 496 | 698
Clinical fractures expected with therapy (16.38%)^†^ | 73 | 106 | 197 | 332 | 467
Clinical fractures prevented | 36 | 53 | 97 | 164 | 231
Vertebral fractures expected with no therapy (7.25%)^†^ | 32 | 47 | 87 | 147 | 207
Vertebral fractures expected with therapy (3.63%)^†^ | 16 | 24 | 44 | 74 | 103
Vertebral fractures prevented | 16 | 23 | 43 | 73 | 104
Hip fractures expected with no therapy (2.75%)^†^ | 12 | 18 | 33 | 56 | 78
Hip fractures expected with therapy (1.25%)^†^ | 6 | 8 | 15 | 25 | 36
Hip fractures prevented | 6 | 10 | 18 | 31 | 42
Number needed to screen (NNS) to prevent fractures for 5 years
NNS to prevent one clinical fracture | 278 | 187 | 103 | 61 | 43
NNS to prevent one vertebral fracture | 625 | 435 | 233 | 137 | 96
NNS to prevent one hip fracture | 1,667 | 1,000 | 556 | 323 | 238

Abbreviations: CI = confidence interval; FIT = Fracture Intervention Trial; RR = risk ratio.

* From Melton et al, 1992.^49^

† From results of FIT for women with BMD T-score of femoral neck −2.5 or less (Cummings et al, 1998^50^). Event rates have been recalculated for 5-years.

Although many different risk-assessment instruments have been developed and tested, most include similar variables, such as age and weight. Studies that report AUC estimates for validated instruments demonstrate that they are modest predictors of low bone density or fracture, and simpler models perform as well as more complex ones, such as FRAX. No studies determined the effectiveness of these instruments in improving fracture outcomes.

Data from large population-based cohorts indicate that the predictive performance of DXA is similar for men and women. Calcaneal QUS using various types of devices can predict fractures of the femoral neck, hip, or spine in men and women, although variation exists across studies. Quantitative ultrasound has low correlation with DXA, and it is not clear how QUS can be used to select individuals for medications that were proven efficacious on the basis of DXA criteria.

Data are lacking to determine how frequently to obtain bone measurements, although one study indicated no advantage to repeated measures that were 8 years apart.138

No trials of medications report effects on fracture-related morbidity and mortality. For postmenopausal women, bisphosphonates, parathyroid hormone, raloxifene, and estrogen reduce primary vertebral fractures. Bisphosphonates significantly reduce nonvertebral fractures in sensitivity analyses that used alternative pooling methods or broadened our definition of primary prevention—consistent with meta-analyses of secondary prevention trials of alendronate and risedronate.161, 162 Estrogen also reduces nonvertebral fractures in trials when using unadjusted estimates, but results are not statistically significant when estimates are adjusted. In the only primary prevention trial that stratified results according to baseline BMD, benefits were only observed in patients with T-scores ≤ −2.5.^50^ For men, no primary prevention trials of bisphosphonates exist, and results from a single trial of parathyroid hormone did not reach statistical significance.

Trials and safety reviews have not supported consistent associations with serious upper gastrointestinal adverse events, atrial fibrillation, or osteonecrosis of the jaw in otherwise healthy patients taking bisphosphonates for fracture prevention. The FDA has recently highlighted case reports of esophageal cancer and severe musculoskeletal pain. An analysis of data from three trials published after our searches found no association between bisphosphonate use and atypical fractures of the subtrochanteric of diaphyseal femur, with an event rate of 2.3 per 10,000 patient-years.216 Evidence on harms associated with calcitonin and parathyroid hormone for treatment of osteoporosis is limited. Raloxifene and estrogen with and without progestin increase thromboembolic events; estrogen with and without progestin increases stroke; and estrogen with progestin increases coronary heart disease among older users and breast cancer.

## Limitations

Osteoporotic fractures result from several factors, and this review is limited by its focus on only some of them. Consideration of vision, physical function, risk for falls, and secondary causes of osteoporosis, for example, is also important in reducing fractures. However, these conditions are beyond the scope of this review.

Studies of risk-assessment instruments are limited by their lack of inclusion of men, and for many, by their study designs (cross-sectional analysis, consecutive rather than population-based recruitment). Several instruments include history of previous fracture, which is more relevant to case-finding than screening. Comparing AUC estimates of instruments is an imprecise method, and may not lend itself as the best method for assessing which instrument has better discriminate ability.

Studies of DXA and peripheral bone measurement tests are limited by their study designs and use of various measures. In general, however, the large population-based prospective studies provide a good method for evaluating the predictive performance of these tests. Studies that report both men and women and adjust for important confounders are the most robust. The consistency of findings across studies also attests to the reliability of the results. The biggest limitation relates to the applicability of estimates derived from populations to an individual in a clinical setting.

Trials of drug therapies vary in size, duration, quality, and applicability. The most important limitations to this evidence include the lack of primary prevention trials and trials that enroll men or enroll patients with mild bone loss (i.e., baseline BMD T-scores between −10 and −2.5). Applying the results of clinical trials to patient care is especially difficult when selection criteria are rigid and study subjects do not represent the community population. This is particularly true in older populations where co-morbidities and use of multiple medications are common would disqualify them for most RCTs.

## Future Research

Future research needs to focus on critical evidence gaps. Trials of the efficacy and harms of screening in reducing fractures and fracture-related outcomes are needed. Initial studies of screening effects support a benefit, but require collaborative evidence from large RCTs.217–221 In addition, studies about acceptability and barriers to screening and treatment, harms, optimal intervals, and starting and stopping ages would inform screening approaches. Screening will most likely detect many individuals with secondary causes of osteoporosis or prior fragility fractures who were not appropriately identified previously. Although they are not part of the true screening pool, identifying them and initiating appropriate management is important also. Studies capturing this aspect of detection would also be useful. Research that includes all types of interventions would provide a more comprehensive approach to fracture prevention. These include not only drug therapies, but also functional assessment, safety evaluations, vision examinations, nutrition, and others. Fracture registries that track individuals over time would be useful in determining effective prevention approaches, and evaluate if screening-detected individuals benefit over the long-term compared to those not screened.

## Conclusions

Osteoporosis and osteoporosis-related fractures are common in aging men and women in the United States. Fractures cause premature mortality, loss of independence and function, reduced quality of life, and substantial financial costs. Although methods to identify individuals with increased risk for osteoporotic fractures are available, and medications to reduce fractures are effective, no trials directly evaluate screening effectiveness, harms, and intervals.