# Appendix Tables

Appendix Table D1 Studies of Risk Assessment

Study | Population Setting, n | BMD Details (baseline mean, site) g/cm^2^ | Inclusion/Exclusion criteria | Study Design | Outcome (BMD/Fracture) | Risk Factors Included in Calculation | Results | Validation in a second group? Results
Adler et al, 2003^52^ | 181 men recruited from pulmonary and rheumatology clinics at a VA | Mean BMD: Spine 1.094 (SD 0.2) FN 0.802 (SD 0.18) TH 0.973 (SD 0.18) | Only patients with no prior DXA were eligible | Cross-sectional analysis | BMD T score of − 2.5 or below | OST | OST cutoff of 3 provided a sens of 93%, spec of 66%. AUC at LS = 0.85 (0.731–0.960) AUC at FN=0.814 (0.717–0.910) AUC at TH=0.866 (0.768–0.963) AUC at any site=0.836 (0.747–0.924) | Yes
Ahmed et al, 2006^87^ | Tromso study - all residents of Tromso born 1969 or earlier (n=27,159 overall, 5795 women age 55–74), final n=1410 | Mean BMD in those without hip fractures: Forearm 0.37 (SD 0.06) Mean BMD in those with hip fractures: Forearm 0.33 (SD 0.06) | Women ages 65 and older, no prior hip fracture, | Analysis of prospective cohort data | Fracture | Risk factors to complement Cummings' risk score: weight loss or BMD <20kg/m2, height ≥168 cm, maternal history of hip fracture, any non-hip fracture since age 50, self- reported good or poor health, physically inactivity (none), benzodiazepine use, anticonvulsant drug use, pulse >80 beats/min, caffeine ≥ 2 cups of coffee/day, unable to rise from chair without help, self-reported hyperthyroidism, age >80 at time of BMD measurement, forearm BMD | Risk score screening had PPV = 11% (CI 3.7–18.2%); selective BMD testing among those with 5 or more risk factors identifies 7 or 8 women with hip fractures as osteoporotic, the eight being osteopenic. 49 hip fracture among 1410 women >65 years. 5 women had 5 risk factors and normal BMD; 14 women had 5 risk factors and low bone mass, 54 women had 5 risk factors and BMD <−2.5. | This is a validation study of Cummings SOF-derived risk instrument
Ben Sedrine et al, 2001^53^ | White women from Belgium, n=4035 | Prevalence of osteoporosis (T≤− 2.5): TH 9.5% FN 18.5% LS (L2–4) 24.3% | All pts presenting for BMD measurement (spontaneous or referred) with data available | Regression to identify factors predicting low bone mass, additive scoring | BMD | SCORE: age, weight race, rheumatoid arthritis, history of nontraumatic fracture after age 45 years, and estrogen use. | For T score ≤ −2.5 with a SCORE cut-off of 6: FN AUC=0.75 (SE=0.010) TH AUC=0.78 (SE 0.012) LS AUC=0.66 (SE 0.10) Any site AUC=0.71 (SE 0.009) Results also reported for Sens, Spec, PPV and NPV presented for T scores ≤ −2.0, T score ≤ −1.0 and T score ≤ −2.5, for SCORE cutoff points of 6 and 8 | Yes - This is a validation study of SCORE
Black et al, 2001^88^ | Developed in SOF, n=7782 postmenopausal women; Validated in EPIDOS n=6679 | Overall mean TH BMD: 0.76 Mean hip BMD in those without fracture: 0.76 Mean hip BMD in those with fracture: 0.65 | Women age 65 and older, recruited from population- based listings, 6 U.S. sites | Analysis of SOF prospective cohort data (logistic regression) | Fracture | FRACTURE index (derived from SOF): age, fracture after age 50 years, maternal hip fracture, weight ≤ 125 lbs, smoking status and use of arms to stand from chair, with and without BMD T score | AUROC for FRACTURE index with and without BMD measurements. Also present 5 year risk of vertebral and non-vertebral fracture by quintile of FRACTURE score AUROC for Hip Fracture, without BMD in the model: 0.714 (no CI given); with BMD in the model 0.766 | Validated using EPIDOS fracture study (n=6679 women).
Brenneman et al, 2003^54^ | 416 women selected from managed care (group health) enrollment and invited for BMD testing | BMD T scores taken at proximal femur, TH, and spine on each subject: −2.5 or less: n=126 (30.3%) −2.0 or less: n=205 (49.3%) −1.0 or less: n=335 (80.5%) | Included if age 60 and older without prior diagnosis of osteoporosis | OPRA RCT comparison of SCORE and SOF | BMD at NOF and WHO criteria (T scores ≤ −2.5, − 2.0, −1.5; also assessed agreement between SCORE, SOF and the treatment/ testing thresholds recommended by NOF, WHO (T≤ − 2.5) and SOF^*^ | SCORE ≥ 7, SOF ≥ 5 | Sens, spec and AUROC presented for SCORE and SOF, for NOF treatment guideline, WHO criteria and SOF-based intervention. Respectively, SCORE identified 89%, 93% and 96% of women below the thresholds for intervention; SOF identified 30%, 32% and 85%. SCORE AUROC for identifying women recommended for treatment by NOF = 0.73 (SE 0.03); for identifying women with T score < −2.5 =0.73 (SE0.03); for identifying those recommended by SOF^*^ = 0.68 (SE 0.03). SOF-based tool AUCROC for identifying women recommended for treatment by NOF = 0.56 (SE 0.03); for identifying women with T ≤ − 2.5=0.54 (0.03); recommended for treatment by SOF decision rule^*^ | Yes - this is a validation study of other measures
Cadarette et al, 2000^55^ | CaMOS; 1,376 (926 for derivation, 450 for validation) cognitively normal women ≥45 years from 3 Ontario sites | Development cohort: Mean FN BMD: 0.74 (0.13 SD) Mean LS BMD: 0.97 (0.17 SD) Validation cohort: Mean FN BMD: 0.74 (0.13 SD) Mean L BMD: 0.97 (0.18 SD) | Excluded women with diagnosis of osteoporosis or taking bone active meds other than ovarian hormones | Cross-sectional analysis of cohort data (logistic regression) baseline DXA and covariates | BMD at 3 levels: 1) T score < −1.0 2) T score ≤ −2.0 3) T score ≤ −2.5 (compared to normal BMD for young Canadian women) | "Osteoporosis Risk Assessment": age (45–54=0 pts; 55–64=5 pts; 65–74=9 pts; ≥75=15 pts), weight (60kg; 60– 69kg:or ≥70kg) current estrogen use (yes/no). Women with score ≥ 9 would be selected for DXA screening | Derivation cohort: 1) Sens = 77.1% Spec = 45.1% PPV 32.5% 2) Sens = 90% Spec = 45.1% PPV =32.5% Area under ROC = 0.789 (SE 0.017) 3) Sens = 97.0%; spec = 41.3% PPV 0 16.9%. ROC presented is for derivation cohort only, not the validation cohort | Yes, validated in 450 women. 1) Sens =77.2% Spec = 56.8% PPV = 71.3% 2) Sens = 93.3% Spec = 46.4% PPV = 16.9% 3) Sens = 94.4% Spec = 41.4% PPV 18%
Cadarette et al, 2001^56^ | 2365 menopausal women from the CaMOS | Baseline: 755 (31.7%) had normal BMD, 1390 (58.3%) had BMD T score between −1.0 and − 2.5, 239 (10.0%) had T score <− 2.5 | Excluded women with physician-diagnosed bone disease, use of bone sparing medication other than ovarian hormones, missing data for any of the risk factors required by decision rules or NOF guidelines | Cross-sectional analysis of cohort data | BMD at 3 levels: 1) T score < −1.0 2) T score ≤ −2.0 3) T score ≤ −2.5 | NOF, SCORE, ORAI, ABONE, weight criterion (women <70 kg) | AUC for T score ≤ −2.5: NOF = 0.70 (0.02) SCORE = 0.80 (0.01) ORAI = 0.79 (0.01) ABONE = 0.72 (0.02) Weight criterion = 0.79 (0.02) | Yes - this is a validation study of other measures
Cadarette et al, 2004^57^ | Women aged ≥45 presenting for BMD testing and women attending two family practice clinics affiliated with the University of Toronto. 140 women from prospective recruitment and 504 from retrospective recruitment | 238 (38.5%) had normal BMD; 290 (45%) had BMD T score between −1.0 and −2.5, 106 (16.5%) had BMD ≤ −2.5 | Excluded women using bone sparing drug other than hormone replacement, prior fragility fracture, secondary cause for osteoporosis or missing DXA | Combination of prospective and retrospective chart review methods | BMD T score ≤ − 2.5 | Body weight criterion, ORAI, OST equation (previously described) and OST chart tool developed for this study | ORAI sens = 92.5%, spec 38.7% OST equation sens = 95.3%, spec = 39.6% OST chart sens = 91.5%, spec = 45.7% Body weight sens = 93.4%, spec = 34.6% AUC results: ORAI: 0.802 (SE 0.02) OST chart: 0.818 (SE 0.02) OST equation: 0.822 (SE 0.02) Body weight: 0.733 (SE 0.02) | Yes - this is primarily a validation study of other measures; OST chart tool is new and not validated
Carranza-Lira et al, 2002^58^ | 400 post- menopausal women, Mexico City | Mean FN BMD = 0.858 (SD 0.128). Mean L-L4 = 1.028 (SD 0.147). | Enrolled consecutive attendees at menopause clinic | Cross-sectional analysis of cohort data (logistic regression) | BMD (unclear what the cut-off was) | Age, BMI, time since menopause (each assigned a score | Present odds ratios for the risk factors (time since menopause, BMI, age). No ROC presented | Yes. Appears that the validation study (this one) includes the women in the derivation cohort (above), but also validated against T score
Carranza-Lira et al, 2002^59^ | 1,088 post- menopausal women, Mexico City | Mean L1–L4 BMD: 0.987 (0.157 SD) Mean BMD in FN: 0.834 (0.130 SD) Mean BMD in Ward's triangle: 0.705 (0.147 SD) | Enrolled consecutive attendees at menopause clinic | Cross-sectional analysis of cohort data (logistic regression), and comparison with T test. | BMD (unclear what the cut-off was) | Age, BMI, time since menopause (each assigned a score | Sens/spec appears to be correlation between clinical index and BMD at LS and FN. No ROC presented | Yes. Appears that the validation study (this one) includes the women in the derivation cohort (above), but also validated against T score
Carroll et al, 1997^89^ | 117 women ages 40– 80 | Mean LS BMD = 0.86±0.16gm/cm2 (SD) | Postmenopausal women (normal and osteoporotic) who were screened for or qualified to participate in osteoporosis trials. Targeted recruitment of normal and those with atraumatic vertebral fractures | Cross-sectional analysis of cohort data | Vertebral Fracture | BMD, age, years since menopause and weight | Figure of ROC presented for T score ranging 0 to −4.0, but no actual numbers given | No
Cass et al, 2006^60^ | N=226 postmenopausal women age ≥ 45 years | Normal BMD in 49–68% (reported by race/ethnic group | Recruited from university based family medicine clinic | Cross-sectional analysis of prospectively collected data | BMD | Female, age ≥45 years; excluded women taking bone active medication or those with other bone diseases (Paget’s, hip replacement) and women who exceeded the weight limit of the DXA scanner | ROC overall for ORAI 0.74 (0.63–0.84); for SCORE 0.67 (0.54–0.79) | Yes - this study is a validation of SCORE and ORAI instruments
Colon-Emeric et al, 2002^90^ | Duke and Iowa EPESE study Community dwelling older men and women age 65 and older. N=4,149 from Duke and 3,505 from Iowa | BMD not reported | Probability sample of community-dwelling adults | Analysis of prospective cohort data | Fracture (hip and all fractures) | Gender (female), age > 75 years, white race, BMI <22.8 kg/m2, history of stroke, cognitive impairments (Short Portable Mental Status Questionnaire ≥3 errors), 1 or more ADL impairments, one of more Rosow-Breslau impairments, anti-epileptic drug use | ROC presented for 3 models predicting fracture in each cohort. Significant risk factors for all subsequent fractures and/or hip fracture in the developmental cohort included: female sex (relative hazard 1.9–2.3), lowest quartile of BMI (1.3), Caucasian race (2.1–2.8), 1+ Rosow–Breslau physical function impairments (1.8–2.1), age 75+ years (2.1), history of stroke (1.9), cognitive impairment (2.2), 1+ impairments in the activities of daily living (1.5) and anti-seizure medication use (2.0). Three predictive models were highly significantly correlated with subsequent fractures with c-statistics in the developmental cohort at 3 and 6 years of 0.640–0.789. A simple count of risk factors had similar discriminative ability to the full model with a linear 35–65% increase in hazard of all fractures and hip fracture for each additional risk factor | Yes – this is a validation of Duke results using Iowa cohort. Sex, BMI and Rosow–Breslau impairment achieved significance in the validation cohort
Cook et al, 2005^61^ | 208 postmenopausal women (69% osteopenic or osteoporotic) | Osteoporotic at LS or hip: 21.6% (n=45) Osteopenic: 47.6% (n=99) Normal BMD: 30.8% (n=64) | Recruited through DXA clinics at Great Western Hospital, Swindon, UK. All were referred due to presence of 1+ clinical risk factor for osteoporosis. No exclusion criteria | Cross sectional | BMD as measured by DXA at the LS and TH. Compares use of ultrasound techniques to use of questionnaires | 8 tools assessed: OST (age and body weight) ORAI (age, weight and estrogen use) OSIRIS (age, weight, HRT use and history of low trauma fracture) SOFSURF (derived from SOF, includes age, weight, smoking, and history of postmenopausal fracture) pBW (body weight with >70 kg = low risk, between 57–70kg = moderate risk, and <57 kg = high risk) SCORE (race, rheumatoid arthritis, history of non-traumatic fracture, HRT use, age and weight) Sunlight Omnisense ultrasound CUBA Clinical ultrasound | Compared AUC for the ROC curves for each risk system and for the two ultrasound systems. AUC for T score of −2.5 was best for OSIRIS (0.747). Reported for each risk tool and for U/S measures for T score of -2.5, −2.0 and −1.0. Overall correlation between the questionnaires was moderate to excellent (r2=0.46–0.95). Compared sens/spec for various cut-off points for the risk instruments also. OSIRIS AUROC=0.747 (0.805-0.702) SOFSURF AUROC=0.717 (0.77–0.670) ORAI AUROC = 0.664 (0.739–0.595) OST AUROC= 0.716 (0.775–0.669) SCORE AUROC= 0.720 (0.779–0.674) Distal radius AUROC=0.676 (0.731–0.628) Proximal phalanx AUROC=0.678 (0.737–0.629) Mid-shaft tibia AUROC=0.582 (0.645–0.521) Sunlight combined AURCO=0.698 (0.751–0.654) BUS calcaneus AUROC=0.766 (0.805–0.743) VOS calcaneus AUROC=0.723 (0.781–0.676) pBW AUROC=0.655 (0.708–0.684) | Yes - this is a validation study of previously derived instruments.
Crabtree et al, 2002^91^ | Women > age 60 who suffered hip fracture, approached after surgery for evaluation with DXA on contralateral hip | NR | Subjects were a randomized subsample from two of the 10 participating sites for EVOS (European Vertebral Osteoporosis Study). 68 cases were from 2 sites, 800 controls from 11 centers | Case control study of Lunar DXA to predict fracture. Mainly a study of DXA - BMD, BMC, comparative stress, fall index, hip axis length (HAL) | Fracture | Age, BMI, FN BMD, c-stress in various combinations | FN-BMD AUROC curve was highest: 0.827 (no CI given). Age AUROC 0.788 (no CI given) Lower FN-BMD AUROC = 0.795 Upper FN-BMD AURCO = 0.825 BMI AUROC= 0.741 Compressive stress AUROC = 0.746 FN-BMD and age, AUROC = 0.856 Compressive stress and age, AUROC = 0.847 FN-BMD, age, and BMI = 0.863 Compressive stress, age and BMI AUROC = 0.875 | No
D’Amelio et al, 2005^62^ | Postmenopausal women presenting for BMD testing, n=525 Caucasian women | 32.2% were osteopenic, 20.4% were normal, 47.4% were osteoporotic | NR | Cross-sectional analysis of prospectively collected data | BMD | NOF, OST, Body weight, ORAI and AMMEB decision rule (age, years after menopause, age at menarche and BMI) | AUC for osteoporosis: NOF = 0.60; OST = 0.33, ORAI = 0.2, body weight = 0.13, AMMEB decision rule = 0.71–0.73. No SE or CI reported. | Yes, this is a validation of other measures (NOF, OST, body weight and ORAI). AMMEB is not validated
Dargent- Molina et al, 2002^92^ | Data from 7,575 French women age ≥ 75 years from the EPIDOS study. Subset of these for derivation and testing | Mean BMD FN: 0.71 (SD 0.11) | Women with hip fracture or bilateral hip replacement were excluded. From the complete cohort, this analysis excluded women with prolonged corticotherapy or immobilization | Analysis of prospective cohort data. Derivation of risk score used 1,588 women with weight below median and T score between −3.5 and −2.5 to determine risk factors (multivariate analysis); used entire analytic sample (n=6933) to evaluate sens/spec. Goal was to use risk assessment for those women with FN T-score between −2.5 and −3.5, those with weight below average and compare this to those identified as high risk on the basis of FN BMD <−3.5 alone | Fracture | Weight is used to select those in whom to measure BMD (yes for those with weight <59kg). Evaluated risk factors were age, history of falling, tandem walk, gait speed and visual acuity. Tried to simplify the score by excluding visual acuity, gait speed and tandem walk. Final score = age, history of falling, tandem walk, gait speed | Proposed strategy has a sens of 37.3% and spec of 15.5% for hip fracture. Reports incidence per 1,000 woman-years for fracture, according to risk score. The use of clinical risk score for women with T score between −3.5 and −2.5 and weight below average improves sens over BMD alone. Selective BMD screening followed by clinical risk assessment has approximately the same discriminant value for hip fracture as systematic BMD screening | No. The risk score (threshold) was derived from the overall cohort (n=7575) and was evaluated using a subset of that cohort (n=5910)
Dargent- Molina et al, 2003^93^ | 5,910 women, mean age 80.5 years. EPIDOS | Mean BMD FN: 0.72 (SD 0.11) | From EPIDOS French cohort study | Comparison of screening strategies: 1) BMD alone, 2) QUS alone; 3) QUS triage followed by BMD, and 4) selective BMD screening followed by clinical evaluation. | Fracture | Weight is used to select women for DXA. Clinical risk factors evaluated after DXA included age, fall history, balance performance and gait speed | Reports sens and spec for the screening strategies. Determined that all 4 strategies were equivalent in distinguishing high risk (>20 per 1,000 person years ) from a person at low risk (below the average population). Two strategies with best discriminatory value compared to systematic BMD screening are 1) QUS triage and 2) selective BMD screening + clinical evaluation. QUS triage: sens 32%, spec 89% selective BMD screen + clinical evaluation: sens 36%, spec 86%. No ROC given | No
De Laet et al, 2005^94^ | Theoretical modeling paper that used risk factors from women in the Rotterdam Study, but arbitrary weights to calculate risk scores | NR | Rotterdam cohort | Created a theoretical continuous risk score for women age 55 years and older using arbitrary weights, based on age, BMD and previous fracture. Tested this risk indicator for normality. Assumed normal distribution for the risk indicators. | Fracture | Age, BMD, previous fracture | Gradient (Score/SD) ranges from 2–5. The proportion (%) of individuals detected according to a certain score/SD depends on the population risk. For example, a score/SD of 4, and a risk threshold (risk vs. population risk) of 2 (double the population risk), 24% percent of the individuals are identified | No
Devlin et al, 2007^63^ | 671 women age 45–70 years. | TH, FN, LS | Excluded pregnant women | Compared diagnostic ability of dental radiographs to NOF and ORAI | BMD | NOF (age >65, weight <57.6kg, maternal/parental history of fracture, current smoking, personal history of fracture) vs. ORAI (age, weight, estrogen) | Manual and digital radiographs of inferior mandibular cortex correlated with hip BMD (correlation coefficient = 0.328–0.460, p<0.001). ROC curves for the 3 risk tools are shown. Both manual and digital performed as well as ORAI which was superior to NOF | No
Diez-Perez et al, 2007^95^ | 5,201 Caucasian women age ≥65 years in Spain | Mean BMD of right calcaneus (heel bone) Fracture group: n=311 0.403 (SD −1.58) Non-fracture group: n=4835 0.439 (SD −1.26) | Excluded Paget’s disease, mult myeloma, known bone metastases, creatinine <265 umol/dL, serum ca >11.0 mg/dL, immobilization for >3 months, anomalies of the R foot interfering with U/S, therapeutic doses of fluoride (>20mg-day) for >3 months of past 2 years, or participation in any investigational study of pharmaceuticals | Cohort study with average of 3.1 years of follow-up | Fracture (incident non-spine fragility fracture) | Best model included age, history of falls, family history of fracture, personal history of fracture, Ca intake (dairy products) <250mg/day and either QUI or e-BMD T score | AUCs: All non-spine fracture = 0.672 (SE=0.016) Main non-spine fractures (hip, wrist/forearm, humerus, pelvis, clavicle, leg) = 0.680 (SE=0.017) Hip fractures 0.686 (SE=0.41) Wrist/forearm fractures = 0.676 (SE 0.026) Humerus fractures=0.689 (SE 0.038) | No
Donaldson et al, 2009^96^ | 3221 Caucasian women from placebo group of FIT, age 55– 81 | FN BMD T score > −2.5: n=1276 | Women who were postmenopausal for 2 years or more, with low FN BMD | Analysis of risk factors and BMD from placebo group of FIT (cohort) | Fracture | FRAX with and without age and FN BMD | Age alone: 0.65 (CI 0.62–0.69) FN BMD: 0.66 (0.63–0.70) FN BMD + age: 0.71 (0.67–0.74) FRAX without FN BMD: 0.68 (0.65–0.71) FRAX with FN BMD: 0.71 (0.68–0.74) history of fracture + age: 0.68 (0.65–0.71) history of fracture + FN BMD + age: 0.72 (0.69–0.75) baseline vertebral fracture + FN BMD + age: 0.76 (0.72–0.79) baseline vertebral fracture + FRAX with FN BMD: 0.75 (0.72–0.78) | Yes – this is validation of FRAX
Durosier et al, 2008^97^ | 12,958 women from EPISEM which includes: 7062 women from SEMOF and 5896 from EPIDOS. Ages 70– 100 years old | BMD reported for EPIDOS cohort only. Mean FN BMD T score = −2.6 | NR | Longitudinal evaluation of 3 year fracture outcomes for women in 3 cohorts with risk factors and BMD ultrasound measurements | Fracture (3 year follow-up) | 5 clinical risk factors, age, BMI and QUS-derived heel SI expressed as a Z-score (validation of Hans) | No ROC reported. kappa statistic is 0.16 for all three groups. 79% of the hip fracture group was correctly classified as high risk. Among osteoporotic women, 66.4% classified in high risk group, 29% in moderate risk group and 4.6% in low-risk group | Yes – this is validation of CRF plus ultrasound (Hans, 2008)
Ensrud et al, 2009^98^ | SOF: 6252 women age 65 and older. | Mean FN BMD 0.65 (SD 0.11) | All those from SOF cohort who had data available to calculate FRAX score | Longitudinal study of cohort data | Fracture (10 years of follow-up) | FRAX with BMD vs. age + BMD, and FRAX without BMD vs. age + fracture history alone | ROC for hip fracture: FRAX without BMD: 0.71 (95% CI 0.68– 0.73) age + prior fracture: 0.71 (0.68–0.73) (p for comparison = 0.91) ROC for major osteoporotic fracture: FRAX without BMD: 0.64 (95% CI 0.62–66) age + prior fracture: 0.64 (0.62–0.66) (p for comparison = 0.89) FRAX without BMD: 0.61 (95% CI 0.59–0.62) age + prior fracture: 0.61 (0.59–0.63) (p for comparison: 0.70) | Yes – this is validation of FRAX and simple models
Ettinger et al, 2005^99^ | Derivation: KPMC Northern California enrollment, ≥ age 45 (70% non-Hispanic white, 7.5% AA, 8% Latino, 13.5% Asian) females. Validation: Canadian Multicentre Osteoporosis Study and SOF cohorts | NR | Entire membership data used | Model derived from Geelong Australia study | Fracture | Model included modified age-based expected fracture risk with 1) low body weight, current smoking, hip fracture in mother or sister, personal fracture history and 2) deviation of BMD from age-expected value (Z score) | The model predicted non-spine fracture rates 2-fold higher than SOF and 3-fold higher than CaMOS. Model predicted spine fractures that were about 3-fold higher than CaMOS and similar to the rate in SOF. No ROC presented | Yes - Validated by comparison to actual fracture rates in CaMOS Study and SOF (instrument overestimates the fracture rates observed in SOF and CaMOS)
Geusens et al, 2002^64^ | 1102 postmenopausal women from U.S. clinics, 3374 women from Rotterdam Study, 23,833 women screened for study of alendronate, 4204 women from general practice in the Netherlands | BMD at hip. Mean FN T score = −1.36 | Excluded if any medical problems that precluded 3 years of participation, severe malabsorption, BP > 210 mm Hg systolic or 105 mmHg diasolic, myocardial infarction within 6 months, unstable angine, hypothyroidism, hyperthyroidism, hyperparathyroidism, significant renal or hepatic dysfunction, history of major GI mucosal erosive disease, recurrent or recent ulcer disease, esophageal/gastric varicies, or dyspepsia requiring daily medication | Cross-sectional analysis of data from several different sources | BMD | OST, ORAI, SCORE, SOFSURF and NOF definition (T score ≤− 2.5) | AUC NR OST < −3 had LR of 8.71 ORAI >17 had LR of 5.60 SCORE > 15 had LR of 7.62 SOFSURF > 4 had LR of 0.82 | This is a validation study of other measures
Girman et al, 2002^100^ | 1427 white female nursing home residents age >65 years (average age 85), from 47 randomly selected nursing homes in Maryland | Mean BMD taken from distal radius of the dominant arm: 0.302 (SD − 3.5) | Age >65, absence of terminal cancer and bone mets, not comatose, at least one wrist/forearm free of prosthetic implants and open lesions, not admitted for rehab only, able to have BMD measured | Prospective study with 18 months follow-up. Test of a scoring algorithm derived from minimum data set variables | Fracture | Age, weight, height, locomotion on the unit (independent, supervised or limited assistance needed), fall in past 180 days, ADL score (>4, ≤4), MDS cognition scale score (≤3, >3), incontinence (usually continent or usually not, vs. occasionally incontinent) | OR for predicting fracture vs. not was 1.3 (95% CI = 1.2–1.5) in the derivation cohort. Sens for predicting fracture in validation cohort was 70.2% with spec of 38.6%, OR 2.1 (95% CI = 1.4–3.0). C-statistic for fracture = 0.63+0.043 | Yes - Algorithm derived from a subset of the data, with the remainder serving as validation cohort
Gnudi et al, 2005^65^ | 1187 consecutive white postmenopausal women from Bologna Italy, recruited from 1366 who were screened (709 development, 478 validation) | Mean BMD Development group n=709 Spine (L2–L4) 0.864 ± 0.158 FN 0.684 ± 0.106 (SD − 2.0 ± 0.9) Validation group n=478 Spine (L2–L4) 0.879 ± 0.171^a^ FN 0.691 ± 0.112^a^ (SD − 1.9 ± 0.9^a^) ^a^ T-Test: not significant compared to the development group | Women with diabetes, hyperthyroidism, liver, kidney and lung failure, malignancies, rheumatoid arthritis and long-term immobilization and those treated with glucocorticoids or other drugs known to affect bone mass | Cross-sectional analysis, logistic regression | BMD at spine and FN by DXA | For T score cutoff of − 2.5: years since menopause, age at menarche, weight, previous fracture, maternal fracture, arm help to get up from standing. For T score cutoff of − 2.0: years since menopause, weight, maternal fracture, arm help to get up from sitting and age | 709 women from the first 8 months of enrollment in the development group. Sens reports for 99%, 98% and 97% at various cutoffs for each T score threshold. Sens ranges from 13.8–32.1% AUC: 0.744, SE 0.023 | Yes – validated in 478 subjects from the last 6 months of enrollment
Gourlay et al, 2005^66^ | 4,035 postmenopausal women age 45–96 years in Belgium; this paper focused on women ages 45–65 | Mean BMD FN 45–64 years: n=2539 0.730 (0.118) 65–96 years: n=1496 0.657 (0.107) | Recruited from outpatient osteoporosis center. Excluded premenopausal pts, those with Paget's or advance OA | Secondary data analysis (previously recruited sample) | BMD by DXA | OST, ORAI, and SCORE base on data obtained from chart review (age, weight, race, history of rheumatoid arthritis, history of non-traumatic fracture of wrist, rib or hip after age 45, and estrogen use) | Compared area under ROC of the three risk assessment tools, and compared the area under ROC for age groups: 45–64 and age > 65years. Presented LR's for the 3 risk tools (scores of low, medium, high). OST (Transformed to-OST) for age 45–64: OST AUC = 0.768 (0.730–0.806) ORAI AUC 0.750 (0.714–0.787) SCORE AUC 0.757 (0.715–0.799) for age ≥65: OST AUC = 0.762 (0.730–0.794) ORAI AUC = 0.747 ().714–0.779) SCORE AUC = 0.745 (0.712–0.777) | Yes - this was a validation of previously derived scoring tools
Hans et al, 2008^101^ | EPISEM: 12,958 women between age 70–100 yr, from two prospective multicenter population-based cohorts (EPIDOS and SEMOF) in French and Swiss women | NR | NR | Combined prospective cohort studies | Hip fracture at 3.2±0.9 year | Stiffness index derived by combining BUA and SOS from calcaneal ultrasound. Clinical risk factors included: BMI, history of fracture after age 50, chair test, history of fall in past 12 months, current smoking, diabetes mellitus | Combined ages: AUC=0.66 for gradient of risk for stiffness index alone. AUC=0.62 for risk factors alone. AUC = 0.70 for combined stiffness index plus risk factors | No
Harrison et al, 2006^67^ | 70 osteoporotic and 137 non-osteoporotic white women ages 55–70 referred for BMD | Mean MBD: hip FN TH LS (L1 L4) Non-Osteoporotic patients: 0.463 (SD − 0.46) Osteoporotic patients: 0.369 (SD − 1.64) | Reasons for referral included suggested osteopenia on radiograph, low trauma fracture, estrogen deficiency, secondary causes of osteoporosis, glucocorticoid excess or therapy, monitoring of therapy, or other reason (family history) | Cross-sectional; logistic regression used to build risk model using 1) presence or absence of osteoporosis at TH, FN or LS, 2) one risk index OSIRIS, and 3) peripheral T score measurement. Peripheral scanners and OSIRIS regression coefficients were multiplied by 10 and rounded-off to integers. Combined algorithm = integer multiplied by peripheral T score measure or risk index and these summed to produce combination algorithms | Hip BMD measured by DXA, and calcaneal BMD measured by QUS (McCue Cuba Clinical and GE Lunar Achilles methods) and peripheral DXA (GE Lunar PIXI) | ORAI, OSIRIS, SCORE, OST, and combinations of scan + risk index: PIXA + OSIRIS, CubaClinical+OSIRIS and Achilles+OSIRIS. OSIRIS was chosen because it had the highest ROC | AUC for ROC for BMD: Achilles 0.77, CubaClinical 0.75, PIXI 0.80, SCORE 0.67, ORAI 0.67, OSIRIS 0.70, OST 0.69, CubaClinical+OSIRIS 0.78, PIXI+OSIRIS 0.82, Achilles+OSIRIS 0.81 | Yes - this is a validation of previously published instruments alone and in conjunction with BMD by QUS
Henry et al, 2008^102^ | Women > 50 years who had sustained a fracture of hip, spine, humerus, and wrist after low-trauma event (n=291, mean age 72); and a control population who had not sustained a fracture (n=823); mean age 70 years | BMD at FN ranges from 0.710–0.844 g/cm^2^ | Pathologic fractures excluded | Case control | Fracture | Fracture Risk Score (T score, age and interaction term derived from discriminant analysis) | No AUC reported | No, this was derivation
Hippisley-Cox et al, 2009^103^ | 535 practices in England and Wales. Men and women. Derivation cohort: 2,357,895 Validation cohort: 1,275,917 | NR | Excluded if prior fracture | Analysis of administrative data – development of the risk assessment tool by proportional hazards regression, and subsequent validation | Fracture | QFracture: 17 risk factors identified from derivation cohort | ROC for hip fracture: 0.89 for women and 0.86 for men. ROC for overall fracture: 0.79 for women 0.69 for men | Yes, separate validation cohort
Kanis et al, 2007^104^ | 9 population based cohorts for development and 11 population based cohorts for validation | NR, but available from published reports of each cohort | Varied for each cohort | Meta-analysis of individual person-level data, with regression to derive risk factors | Fracture | Risk factors chosen based on prior work. Age, BMI, family history of fracture, glucocorticoids, prior fracture, even smoking, alcohol use, rheumatoid arthritis, and FN BMD | Risk factors were chosen based on prior work. AUC for hip fracture age 50: BMD along | Yes, separate validation cohorts
LaCroix et al, 2005^117^ | Women aged 60–80 randomly sampled from HMONTHS and followed for 33 months (recruited 9,268 women | Mean BMD TH posterior–anterior spine | Excluded women on hormone therapy or osteoporosis medication for the previous 12 months | RCT of three screening strategies: 1) Universal screening group - all offered BMD testing 2) SCORE group, invited for BMD only if ≥7 on the SCORE questionnaire 3) SOF group, invited for BMD only if ≥ 5 hip fracture risk factors | 1) Initiation of osteoporosis treatment; 2) Fracture rate (hip and total) over 33 months of follow-up. 3) Knowledge of osteoporosis 4) change in fracture risk factors 5) satisfaction with the program | Universal - none SCORE: age, race/ethnicity, RA, prior fracture, ever taken estrogen, current weight. SOF: health status, AA race, smoking, 1st degree relative with hip fracture, weight loss since age 25, dementia, use of corticosteroids, anti-epileptic medications, long-acting benzodiazepines, walk for exercise, get up and go unassisted, prior fracture at age 50 or older, current age >80 years, postmenopausal not on hormone therapy, ambulation <4 hrs/day, HR>80 bpm at rest, height of 5'7"or taller at age 25 | Osteoporosis treatment rates did not differ among all women contacted, but were slightly higher among universal and SCORE groups (NS). BMD testing was performed in 100% of the universal group, 73.8% of the SCORE group, and 6.9% of the SOF group | Yes - this is a validation study of SCORE, SOF
Leslie et al, 2003^105^ | 213 consecutive Caucasian postmenopausal women presenting to bone density program in Sr. Boniface General Hospital, age 50–88 | Mean BMD: TH 0.872 (SD 0.143) Hip t-score (− 1.1±1.2) Hip z-score (0.0±1.1) | Excluded women with age <50, non-white, and those for whom the risk factor profile was incomplete | Comparison of two strategies for predicting absolute fracture risk using BMD alone or with clinical risk factors | Absolute fracture risk, but not known fracture risk | Comparison of two models: 1) full model which includes age, clinical risk factors, bone density-this described in Leslie 2003 Journal of Clinical Densitometry and 2) BMD alone. Full model starts with risk estimates for average women of equal age then sequentially incorporates the clinical risk factors and TH BMD (fracture after age 50, reduced health status, unable to rise from chair without arms, height at age 25 >168 cm, past hyperthyroidism, height loss > 3 cm, fall in past 12 mo, on feet < 4 hrs per day, current smoker, family history, current weight < 57.8 kg | Average results for the two models were similar, but there was considerable scatter in the Bland-Altman plots indicating a large amount of disagreement between the risk estimates | Yes, this is a validation study of Osteoporosis Canada risk instrument
Leslie et al, 2009^106^ | 16,205 white women ≥50 years of age living in Manitoba, CA who had a bone density between 1998–2002 | Baseline BMD T scores: TH: − 1.1±1.2 FN: − 1.3±1.2 LS: − 1.3±1.2 | For patients with more than one DXA measurement, only the first was used | Retrospective cohort study | Fracture | Simplified (semiquantitative) system uses age, sex, measured BMD; estimation of 100-yearabsolute fracture risk is summarized on a pocket-sized laminated card available from the author | No ROC presented | Yes
Lindh et al, 2008^68^ | 600 women aged 45–70 from 4 centers (Greece, Sweden, UK and Belgium). Recruited at routine/emergent dental visits, from hospital/university/local staff and advertisements/word of mouth, and women undergoing DXA with noted T score <− 2.5 | 473 people had normal BMD, 127 had T score <− 2.5 | Targeted a high risk population that included those with known osteoporosis, prior fragility fracture, early menopause, low body weight (thinness), family history of osteoporosis or loss of height. Excluded women with prior treatment for low BMD, secondary osteoporosis, primary hyperparathyroidism, thyrotoxicosis, malabsorption, liver disease, alcoholism | Cross sectional analysis, inter-rater reliability was evaluated between 5 observers | BMD T score ≤ − 2.5 | Periapical radiography of the premolar region of the upper and lower jaw | AUC NR. Diagnostic LR for various patterns at the upper and lower jaws ranged from 2.20 to 15.35 | No.
Lynn et al, 2008^69^ | 4,658 U.S. Caucasian men and 1914 Hong Kong Chinese men | Reported elsewhere | MrOS: community-dwelling older men (age ≥65 years) in the U.S. Similar for Hong Kong. Excluded if bilateral hip replacements or unable to walk without assistance | Cross-sectional analysis of cohort data | BMD T score ≤−2.5 | MOST = body weight and QUI. OST, body weight and QUI also evaluated separately | AUC for T score < −2.5 at any site (LS, TH or FN): OST = 0.714 (SE 0.012). MOST=0.799 (includes QUI). QUI = 0.738 (SE 0.014). Weight = 0.702 (SE 0.014) | Yes - this is a validation of OST, MOST, QUI and weight
Martinez-Aguila et al, 2007^70^ | 665 Spanish postmenopausal women (mean age 54) referred by gynecologist for BMD testing. Frequency of osteoporosis at either LS or FN = 17.6% (16.7% at LS, 3.8% at FN) | Mean BMD: LS 0.906 ± 0.146 t-score: −1.19 ±1.38 z-score: −0.14 ± 1.14 FN 0.742 ± 0.108 t-score: −0.90 ± 0.99 z-score: −0.02 ± 1.10 | Excluded women with age < 40 or > 69 and missing data | Cross-sectional | BMD | Comparison of 4 decision rules: ORAI, OST, OSIRIS and body weight criterion | AUROC, sens, spec, PPV, NPV or 4 tools in total population. AUC for OST = 0.640 (0.586–0.694) ORAI = 0.615 (0.560–0.671) OSIRIS = 0.630 (0.573–0.687) BWC = 0.586 (0.532–0.639) In a subset of 507 women without low impact fracture: OST = 0.661 (0.599–0.724) ORAI 0.634 (0.570–0.699) OSIRIS = 0.635 (0.566–0.704) Body weight criterion = 0.585 (0.522–0.648) | Yes - This was a validation testing of 4 instruments
Masoni et al, 2005^71^ | 195 (131 + 64) postmenopausal women attending menopause clinic (original cohort and separate validation cohort) | Mean BMD Lumbar (L2–L4) (grouped post-test) Normal: n= 33 1.0037 ± 0.017 Osteopenic n= 52 0.816 ± 0.005 Osteoporotic n= 46 0.660 ± 0.008 | Excluded primary hyperparathyroidism, Paget’s, estrogen treatment | Cross-sectional | BMD | Final model included BMD, calcium intake, menopause > 10 years, kyphosis, personal fax, kyphosis and personal fracture | ROC = 0.833 (0.757–0.909). Also report probability of osteoporosis for various risk factors combinations. | Yes - Validated in 64 people
Mauck et al, 2005^72^ | 202 women age > 45 years enrolled in the Rochester Epidemiology Project | Mean BMD FN: Greater than − 2.0 95 (47)−2.0 or less 107 (53) − 2.5 or less 69 (34) Age 45–64 years 11 (5) Age 65 years 58 (29) LS: −2.5 or less 15 (7) Age 45 –64 years 3 (1) Age 65 years 12 (6) | Secondary data analysis, cross- sectional | Excluded dementia, pregnancy, radiation workers, those participating in a trial of osteoporosis medications | BMD | Comparison of 3 risk prediction rules: SCORE, ORAI, and NOF (age >65, weight<57.6kg, history of fracture after age 40, family history of fracture after age 50, current smoker) | ORAI LR=1.5 (ROC 0.84) SCORE LR=1.3 (ROC 0.87) NOF LR=1.1 (ROC 0.70) | Yes - this is a validation study of ORAI, SCORE, NOF
McGrother et al, 2002^107^ | 1289 women age ≥70 years followed for 5.5 years or until death. Population-based sample from England. | Mean BMD: BUA of the calcaneus (heel bone) 65.2 (SD 21.4) | Invited by letter from Chiropody clinic in Leicestershire, England, included women in residential care | Multivariate analysis of 3 and 5 year follow-up data | Fracture | 3 year model: weight, trunk maneuver, epilepsy, kyphosis, poor circulation, short term steroid use. 5 year model: weight, reported poor health, epilepsy, age | OR for 3 year and 5 years models, also AUROC for both. ROC for 3 year = 0.82 ROC for 5 year = 0.73 | Not – Internal validation only (cross-validation in SAS using a one-step approximation method)
Miller et al, 2004^108^ | 57,421 postmenopausal white women with baseline T score −2.5 to −1.0 | Mean BMD: Forearm/Heel (pooled results) With fracture (n = 1130) − 1.72 (SD 0.41) With no fracture (n = 56 291) −1.61 (SD 0.40) | Age < 50, osteoporosis, BMD measured within past 12 months, use of bisphosphonate, calcitonin or raloxifene, participation in any other trial for osteoporosis | Multivariate analysis using classification trees | Fracture | NORA 32 risk factors entered into regression tree to build algorithm. Tree-based prediction rule included: previous fracture, T score by central DXA, health status (fair or poor), poor mobility (2 or more positive responses to 4 questions) | Algorithm correctly classified 74.1% of women who experienced a fracture within 1 year. Identified 55% of women as being at risk for fracture | No – Internal validation only (10-fold cross validation by splitting the data into approximately 10 parts)
Minnock et al, 2008^73^ | 274 postmenopausal women, Caucasian referred to DXA scanning clinic at Great Western Hospital, Swindon, UK | 23.8% had BMD T score of ≤− 2.5 at any site | Excluded if disease known to cause secondary osteoporosis | Cross sectional analysis of prospectively collected data | BMD by DXA | QUS measurement using CUBA Clinical system and Sunlight Omnisense; combined QUS measurement with risk factors. Also tested OSIRIS | OSIRIS ROC = 0.80 (those between ages 60 and 80). ROC for risk factors alone = 0.85 (TH) and 0.79 (lumbar spine). Questionnaire and broadband ultrasound attenuation: 0.82 for LS and 0.91 for TH | Yes for OSIRIS. The new measure described here is not validated
Nguyen et al, 2004^74^ | 1256 women from the DOES | Mean BMD: Development cohort (n=846) FN 0.77±0.13 LS 1.03 ± 0.19 Validation cohort (n=410) FN 0.77 ± 0.13 LS 1.03 ± 0.19 | Women age ≥60 years living in Dubbo | Analysis of longitudinal cohort data. Development and validation performed by randomly dividing the sample into two groups: 846 for development and 410 for validation) of the DOEScore | BMD and Fracture | DOEScore: Age, body weight and history of fracture. Compared to FOSTA, SOFSURF, ORAI | ROC curves for DOEScore only; also compared sens and spec for DOEScore with FOSTA, SOFSURF and ORAI. AUC for T score <− 2.5 =0.75 AUC for T score <− 2.0 = 0.72 (LR+=1.49). AUC for incident fracture = 0.48. DOEScore for T <− 2.5 in valid cohort LR+=1.71). DOEScore for T<− 2.0 in validation cohort LR+=1.49. LR+ for FOSTA = 0.54 LR+ for SOFSURF = 1.23. LR+ for ORAI = 1.88 | Yes Sens = 0.82 and Spec = 0.52 for selecting women with T score < − 2.5 in the validation cohort
Nguyen et al, 2007^109^ | 1208 women and 740 men (98% Caucasian) from the DOES with 13 years of follow-up | Mean BMD: FN − 0.12 (HR 2.62) LS − 0.20 (HR 2.37) | Population-based recruitment, age ≥60 years living in Dubbo, Australia. | Development of a nomogram-based risk assessment tool using Bayesian model average analysis leading to most parsimonious model | Fracture | Age, BMD (FN BMD T-score), prior fracture, fall in the last 12 months | ROC curves: women AUC=0.85 (no CI) men AUC=0.85 (no CI) Compared this to BMD alone: men 0.78 (no CI) women 0.80 (no CI) | No
Pluijm et al, 2009^110^ | 4157 women age ≥ 60 years from the Rotterdam Study (mean follow-up 8.9 year), 762 women age ≥65 year from the LASA study (mean follow-up 6.0 years) | NR | Rotterdam is a prospective, ongoing cohort study of men and women age 55, in Rotterdam. LASA is an ongoing cohort study of older men and women (55–85) in the Netherlands (west, northeast and south regions). Exclusions include missing data for both hips and fragility fractures | Linear regression to identify risk factors and develop a risk score. Validation by imputation | Hip fracture and fragility fracture (hip, pelvis, proximal humerus and wrist) | Age, prior fracture, body weight <60kg, use of a walking aid and current smoking | AUC = 0.77 for hip fracture, 0.71 for fragility fracture. Compared this to FRAX which had AUC of 0.76 | No – internal validation only (validation by imputation: models were constructed in each of five data sets that were completed by imputation; then internally validated using bootstrapping techniques)
Reginster et al, 2004^75^ | 889 postmenopausal women from rheumatology clinics in France | NR. 16.6% and 24.2% of the development and validation cohorts had BMD T score < −2.5 | Postmenopausal women seen in rheumatology clinics | Cohort recruitment was not standardized or sequential. Two participants recruited by each rheumatologist. Cross-sectional evaluation | BMD | Age, body weight, current HRT use and history of previous low impact fracture | No ROC presented. In validation cohort, prevalence of osteoporosis in those with OSIRIS score <−3 was 62%. Prevalence of osteoporosis in those with OSIRIS score > +1 was 16.8% | Yes, this is the validation of OSIRIS as previously published
Richards et al, 2007^111^ | 6646 men and women from CaMOS, 71.2% women and 95.6% white | Mean BMD: TH, FN, Trochanter LS (L1–L4) | Only those who underwent baseline BMD testing were included in analysis. Original cohort was population based, enrolling women living within 50km of 1 of 9 regional centers, non-institutionalized | Comparison of 3 risk prediction tools | Fracture | 1) Age, sex and 2 clinical risk factors; 2) comprehensive - age, sex, BMD and seven clinical risk factors; and 3) WHO 1994 BMD based system | Prevalence of high risk for osteoporotic fracture by age group for men and for women. Comparison of T score ≤ −2.5, simplified risk factor system and comprehensive risk factor system. No ROC reported | Yes - This is a validation study of other risk assessment instruments
Richards et al, 2008^116^ | Men > age 50 attending a rheumatology clinic | Low BMD: 29 (57%) | Male patients over the age of 50 who completed a checklist were eligible. Patients with a prior diagnosis of osteoporosis were on treatment for osteoporosis, or previously had a DXA were excluded | Men presenting for clinic were given a checklist of risk factors. Retrospective comparison evaluating DXA requests before and after the intervention | Clinician referral of pt for DXA | Adapted the SOF ten-item checklist to be used for men, leaving off question about hypogonadism because of concern about acceptance. Final risk factors: weight <130 lbs, fracture after age 50, medications (seizure, thyroid, steroid), alcohol >3/day, rheumatoid arthritis, avoid dairy, elderly relatives with fracture, hormonal therapy for prostate cancer, shorter now than at age 25, ever smoked >10 cigarettes/day for >10 years | Before the checklist intervention: 14% of men over age 65 had DXA, 5% of AA and 29% of whites. After the checklist intervention: 32% of men had DXA request, 23% of AA and 46% of whites. | No
Richy et al, 2004^76^ | Two cohorts of postmenopausal women aged 45 years and older recruited from public screening: 407 in development cohort and 202 in validation cohort | Mean BMD: FN Development cohort: 0.72 (0.13) Validation cohort: 0.73 (0.15) | Osteoporosis, Paget disease, RA, use of bone active drugs other than HRT | Comparison of QUS at the phalanx alone, in ORACLE to OST | Femoral neck BMD | ORACLE index constructed from validation cohort by use of logistic regression. QUS UBPI, age, BMI, current HRT use, and history of fracture at age > 45 years | In the derivation cohort, AUC for ORACLE were 0.81 for osteoporosis (T<−2.5) and 0.76 for low bone mass or osteoporosis (T<−1.0). Cutoff of 0.27 for ORACLE sens was 90% and spec was 50% for osteoporosis. AUC for OST = 0.76 (SE 0.033, CI 0.70–0.83) AUC for ORACLE = 0.81 (SE 0.03, CI 0.75–0.87) | Yes - In the validation cohort, AUC for identifying osteoporosis and low bone mass were 81% and 76% for ORACLE, 69% and 64% for QUS T score, 71% and 68% for QUS UBPI, and 76% and 75% for OST, respectfully
Robbins et al, 2007^112^ | 93,676 women from the observation al component of WHI (development) and 68,132 women from the clinical trial (for validation) Tested the addition of BMD in 10,750 women who had BMD measured by DXA | BMD performed only on 10,750 women. Pts not recruited on the basis of osteoporosis | Postmenopausal women aged 50–79. Women were ineligible if they did not want to discontinue hormone therapy upon entry, or had a history of breast cancer; they were ineligible for the diet portion if they already followed a low-fat diet or too frequently ate away from home; they were ineligible for the calcium/vitamin D component if they had a history of kidney stones or were unwilling to limit vitamin D intake. Those who were screened for the clinical trial but were ineligible or unwilling to participate in randomization were asked to enroll in the observational study | Prospective cohort study derived from both observational cohort and RCT cohort. 5 years of follow-up | Hip Fracture at 5 years | General health, height, weight, fracture after age 55yr, race/ethnicity, physical activity, current smoking, parental hip fracture, corticosteroid use, diabetes, age | In development cohort: AUROC for all 11 risk factor model: 0.80 AUROC for age alone: 0.76 AUROC for all predictors except age: 0.67 All other risk factor had AUC <0.60 individually. (no CI given). In the validation cohort: 0.80 (0.77–0.83) In the 10,750 women who had BMD measured: AUC for BMD alone = 0.79 (0.73–0.85) WHI algorithm AUC = 0.71 (0.66–0.76) DXA plus WHI algorithm =0.80 (0.75–0.85) | Yes, used RCT cohort for the validation; performed secondary analyses excluding and including each different treatment arm with no change in AUC (all 0.78–0,81)
Rud et al, 2005^77^ | 2016 white women recruited for the Danish Osteoporosis Prevention Study | Mean BMD: LS (L2–L4): 1.027 (0.139) FN: 0.797 (0.114) TH:0.917 (0.118) | Excluded: metabolic bone disease including osteoporosis (non-traumatic vertebral fractures on x-ray), 2) current estrogen or past 3 months, 3) current glucocorticoid use, 4) current or past malignancy, 5) thromboembolic disease, 6) newly diagnosed or uncontrolled chronic disease or 7) alcohol or drug dependency. | Test of SCORE; ORAI and OST as to whether they yield 90% sens; compare performance of case finding based on presence of a major risk factor vs. the three decision rules for younger women with low BMD for densitometry | BMD by DXA at L2–L4, FN and TH | SCORE, ORAI, and OST vs. case finding based on presence of a major risk factor (CFMRF). CFMRF defined as one or more of the following: age at natural menopause < 45 years, secondary amenorrhea > 1 year, hip fracture in mother, BMD <19kb-m2, fragility fracture >45 years (wrist, hip, spine, rib, humerus, pelvis), rheumatoid arthritis, COPD, immobilization > 1 month after age 45 years | ROC analysis for various cut-offs for all 4 risk assessment tools (sens, spec, PPV, NPV, number needed to refer to identify one women with lowest T score ≤ −2.5) | Yes for SCORE, ORAI and OST. No for CFMRF
Russell et al, 2001^78^ | 989 postmenopausal women > age 45, referred for DXA BMD testing (95% Caucasian) | Mean BMD: Spine Hip | Outpatients from Northern Alberta, referred for DXA, otherwise unselected. | Assessment of SCORE to predict BMD | BMD (T score < −2.5) | Age, atraumatic fracture history over age 45, rheumatoid arthritis, race, estrogen treatment, weight | False positives, true positives, true negatives, and false positives for L spine and FN, by age group | Yes - This is a validation study of SCORE, approach of using cut-point of <10 validated in prospective study of 54 pts over age 65
Salaffi et al, 2005^79^ | 1,522 postmenopausal women > age 50, who underwent DXA (outpatient osteoporosis center) in Italy | Mean BMD: FN: 0.701 ± 0.125 LS (L1–L4): 0.889 ± 0.146 | Exclude those taking bone active medications (ovarian hormones, calcitonin, bisphosphonates, fluoride) | Development and validation of OPERA tool | BMD | Estrogen (never), diseases affecting the skeleton, late puberty (after age 15), family history of osteoporosis and > 6 months use of medications affecting the skeleton | ROC, discriminatory performance for T = −2.5 at the LS and FN, by number of variables in the algorithm (1–5) | Yes - This was the validation of the OPERA tool, derived from systematic review of the literature about risk factors, and expert input for content validity
Sandhu et al, 2010^113^ | Medical records of patients attending Fracture and Bone and Calcium clinics in Sydney Australia; n=200. 56 men and 144 women Caucasian age 60–90 | Mean T score for groups (men/women, fracture/no fracture): −1.7 to −2.2 | Included if data available; excluded if any prior major osteoporotic fracture, any treatment with bone-specific agent for > 30 months, or presence of metabolic bone disorder (Paget’s, skeletal mets) | Chart review | Fracture | FRAX and Garvan nomogram | Mean ROC (SD) for women: Garvan: 0.84 (0.03) FRAX-US 0.77 (0.04) FRAX-UK 0.78 (0.04) Men: Garvan: −.76 (0.07) FRAX-US 0.54 (0.07) FRAX-UK 0.57 (0.08) | This is a validation of FRAX and Garvan nomogram
Sedrine et al, 2002^80^ | 1303 postmenopausal women from outpatient clinic | Mean BMD Spine: 1.210 (± 0.15) TH: 0.890 (± 0.10) FN: 0.850 (± 0.10) | Inclusion based on menopausal status, age 60–80, absence of prior or current pharmacologic treatment for osteoporosis other than HRT, calcium or vitamin D | Retrospective database analysis | BMD | OSIRIS: age, weight, current HRT and prior low impact fracture | Sens, spec, PPV and NPV for various OSIRIS index scores. Values ranged from −8 to +12. The AUC or the ROC curves for OSIRIS was 0.71 | Yes - This is a validation study of OSIRIS
Shepherd et al, 2007^81^ | Men age ≥ 50 years. 1497 in development cohort and 1498 in validation cohort (randomly assigned) | Details of the sampling and data collection have been described elsewhere: National Center for Health Statistics. National Health and Nutrition Examination Survey. http://www.cdc.gov/nchs/about/major/nhanes/nh3data.htm. Accessed June 21, 2006 | Men age ≥ 50 years included in NHANES III dataset who had a valid DXA | Development and validation of MORES tool via regression analysis. Excluded any variable with >10% missing | BMD | MORES: age, weight and history of COPD | Sens, spec, ROC curves for MORES score of ≥6: sens = 0.91, spec = 0.58, AUROC=0.822 | Yes. In validation cohort, sens=0.95, spec =0.61, and AUROC=0.832
Sinnott et al, 2006^82^ | N=128, African American men recruited from general medicine clinics at the Jesse Brown VA Medical Center | FN BMD 1.02 (0.18) g/cm^2^ | Excluded if history or evidence of metabolic bone disease, atraumatic fractures, history of any medical conditions predisposing to low bone mass, history of cancer in preceding 10 years or use of medications that cause or treat low bone mass (except Calcium and vitamin D) | Cross-sectional analysis, logistic regression. | BMD by DXA | OST, weight alone, BMI alone and heel T-score by ultrasound | For BMD T score by DXA < −2.5 Heel T score : 0.93 (95% CI 0.87–0.99) Weight (<85kg): 0.75 (0.57–0.92) BMI: 0.67 (0.47–0.87) OST: 0.89 (0.75–1.03) | Yes - This was validation of OST and body weight
Smeltzer et al, 2005^83^ | 307 women with disabilities who underwent peripheral BMD screening, age 20–84. Mean T score was −1.1±1.8 | Mean BMD: Os calcis (heel) −1.10 ± 1.8 | Convenience sample of women with disabilities recruited from health fairs or educational workshops | Cross-sectional | BMD | SCORE: age, weight race, rheumatoid arthritis, history of hip/rib/wrist fracture and estrogen use | Sens, spec, accuracy for SCORE ≥6 for predicting T ≤ −2.5 and ≤ −2.0. For T ≤ −2.5, sens = 65.7%, spec = 61% | Yes - This was a validation study of SCORE for women with disabilities
Timmer et al, 2009^84^ | 206 patients over 50 presenting to ER with low-energy fall | 41% had osteoporosis; 44% had osteopenia; 16% had normal BMD | Excluded if dementia, on treatment for osteoporosis, short life expectancy, living in a nursing home or refusing to participate | Prospective | BMD | Their own prediction rule for the risk of osteoporosis (BMD) in patients presenting to the ER with low-energy fracture | AUC=0.79 after optimism correction | No - internal validation only. (“internally validated with a standard bootstrap procedure”)
Vogt et al, 2000 et al.114 | 25,816 women age ≥ 55 years. From FIT intervention trial | Mean BMD FN: Vertebral fracture: n=2680 0.563 (0.068) No vertebral fracture: n=10,371 0.591 (0.059) | Used data from the recruitment phase of FIT intervention trial to assess ability of questionnaire to identify women with existing vertebral fractures | Cross-sectional. Includes development of tool the vertebral fracture index (PVFI) from data obtained at screening visit for FIT trial, to predict prevalent vertebral fracture | Prevalent Vertebral Fracture | PVFI: history of vertebral fracture, history of nonvertebral fracture, age, height loss and diagnosis of osteoporosis | PVFI score of ≥ 4 sens = 65.5%, spec = 68.6%. Excluding 881 women who reported a prior vertebral fracture, PVFI score ≥4 sens was 53.6% and spec was 70.7% | No
Wallace et al, 2004^85^ | 174 postmenopausal Africa-American women recruited from churches in east Texas | Mean BMD FN: Normal (±−1.0SD) 122 (70.1%) Osteopenia (−1.0SD> t-score >−2.5SD) 26 (14.9%) Osteoporosis (±−2.5SD) 26 (14.9%) | Screened by personal physician for participation. Inclusion criteria: apparently healthy, ≥5 year post-menopause; U.S. native age 35–80. Exclusions: renal disease, GI disorder affective digestion and absorption, long-term use of meds known to affect bone | Cross-sectional | Low BMD defined as T score ≤ −2.0 | Comparison of ABONE, ORAI, OST, SCORE and body weight. ABONE = age, body size, no estrogen | Sens, spec, NPV, PPV, AUC for ROC. ABONE ≥ 2: sens 73.0%, spec 59.6%. ORAI ≥9: sens 65.6%, spec 78.9%. OST <2: sens 75.4%, spec 75.0%. SCORE ≥6: sens 83.6%, spec 53.9%. Weight <70kg: sens 68.9%, spec 69.2%. Discriminatory performance of OST: cut-off of ≤ −1 for OST has sens of 91.0% and spec of 48.1% | Yes - This is a validation study of other instruments
Wei et al, 2004^115^ | 469 women military primary care clinic age ≥ 40 year (mean age 69) | NR, only 39% reported having had prior BMD testing; not done as part of the study | At least 40 years old, presenting for routine medical care. Excluded if not menopausal | Cross-sectional survey | Fracture History (self-reported) | Comparison of ORAI, ABONE, body weight < 70 kg | ORAI ≥9: sens 83%, spec 31%, RR of fracture 2.0. ABONE ≥2: sens 74%, 46% specific, RR 2.2. weight: 64% sens, 56% specific, RR 2.0. ORAI >9: AUC= 0.65 (0.57–0.73) ABONE >2: AUC =0.63 (0.54–0.71) weight: AUC= 0.60 (0.52–0.68) | Yes - This is a validation study of other instruments
Wildner et al, 2003^86^ | 959 postmenopausal non-Hispanic women age ≥51 from NHANES | Mean BMD: Whole proximal femur FN | NHANES phase 3 participants, with acceptable hip bone scan | Development of predictive model based on regression; determined use of weight and age gave optimal sens/spec | TH BMD: T score ≤ −2.5, and also at T scores of −2.3, −2.0, −1.7, −1.5 | Comparison of several models with different numbers of risk factors. Preferred model included age and measured weight | AUC, c-value; sens, spec, PPV, and NPV for various T score cut-offs. Using age and weight to predict T score of ≤ −2.5 at the total proximal femur: sens = 31.75%, spec = 97.40%, PPV=75.00, NPV 85.32 | No

Abbreviations: ADL = activities of daily living; AUC = area under the curve; AUROC = area under the receiver operating characteristic; BMD = bone mineral density; BUA = broadband ultrasound attenuation; c-stress = compressive stress; CaMOS = Canadian Multicentre Osteoporosis Study; CI = confidence interval; DOES = Dubbo Osteoporosis Epidemiology Study; DXA = dual-energy x-ray absorptiometry; EPESE = Established Population for Epidemiology Studies of the Elderly; FIT = Fracture Intervention Trial; FN = femoral neck; HRT = hormone replacement therapy; LASA = Longitudinal Aging Study Amsterdam; LS = lumbar spine; MORES = Multiple Outcomes of Raloxifene Study; MrOS = Osteoporotic Fractures in Men Study; NHANES = National Health and Nutrition Examination Survey; NOF = National Osteoporosis Foundation; NORA = National Osteoporosis Risk Assessment tool; NPV = negative predictive value; NR = not reported; ORACLE = Osteoporosis Risk Assessment by Composite Linear Estimate Study; OPERA = Osteoporosis Prescreening Risk Assessment; OPRA = Osteoporosis Prospective Risk Assessment; OR = odds ratio; ORAI = Osteoporosis Risk Assessment Instrument; OSIRIS = Osteoporosis Index of Risk; OST = Osteoporosis Self-assessment Screening Tool; PIXI = Peripheral Instantaneous X-ray Imager; PPV = positive predictive value; QUI = quantitative ultrasound index; QUS = quantitative ultrasound; RA = rheumatoid arthritis; RCT = randomized controlled trial; ROC = receiver operating characteristic; SCORE = Simple Calculated Osteoporosis Risk Estimation study; SD = standard deviation; SE = standard error; SEMOF = Swiss Evaluation of the Methods of measurement of Osteoporotic Fracture risk; sens = sensitivity; SOF = Study of Osteoporotic Fractures; SOFSURF = Study of Osteoporosis Fractures—Study Utilizing Risk Factors; spec = specificity; TH = total hip; UBPI = ultrasound bone profile index; VA = Veteran’s Administration; WHI = Women’s Health Initiative; WHO = World Health Organization.

* SOF-based decision rule: Intervene if fracture after age 50; measure BMD if SOF score is >5, and intervene among those who meet intervention criteria (age<65 with T score <−2.5; age >65 with >5 risk factors and Z score −0.43; or previous fracture after age 50).

Appendix Table D2 Descriptions of Variables Included in Validated Risk Instruments

Name of Instrument | References | Age | Weight | Other | Scoring Method and Interpretation
ABONE | Cadarette et al, 2001^56^ Wallace et al, 2004^85^ Wei et al, 2004^115^ | X | X | Estrogen | Age: 1 point if >65 years Weight: 1 point if <63.5 kg Estrogen therapy: 2 points if currently taking; 0 points if not taking. Score ≥ 2 as high risk
Body weight criterion (pBW) | Cadarette et al, 2001^56^ Cadarette et al, 2004^57^ Cook et al, 2005^61^ D’Amelio et al, 2005^62^ Lynn et al, 2008^69^ Martinez-Aguila et al, 2007^70^ Wallace et al, 2004^85^ Wei et al, 2004^115^ | | X | | Weight in kg as only risk consideration Weight >70kg = low risk Weight 50–70 kg = moderate risk Weight <57kg = high risk
Carranza-Lira et al, 2002 | Carranza-Lira et al, 2002^58, 59^ | X | X (BMI) | Time since menopause | 1 point for each: age >48, BMI <32 for spine and <30 for FN, time since menopause >5 years.
DOEScore | Nguyen et al, 2004^74^ | X | X | Prior fracture | Sum of points: Age <65=1, 65–69=1, 70–74 and 75–79=2, 80–84=3, 85+=4, 80–84 =8, 85–89=11, 90+=16; Weight: <55kg =1, 55–59 and 60–64kg=2; 65–69kg=3; 70–74kg=4; 75–70kg=6 Prior Fracture: No=1; Yes=2 <10 vs. >10 for T score <−2.5
Gnudi et al, 2005 | Gnudi et al, 2005^65^ | | X | Age at menarche, years since menopause, arm help to rise from seated position, pervious fracture, maternal history of fracture | Clinical risk factors for the validation group were entered into the regression model for the development group to arrive at a T score
EPESE | Colon-Emeric et al, 2002^90^ | X (>75 years) | X (BMI) | Female sex, white race, BMI, history of stroke, cognitive impairment (SPMSQ≥3 errors), 1+ ADL impairments, 1+ Rosow-Breslau impairments, antiepileptic drug use | Full score is weighting with parameter estimates obtained from logistic regression Risk score is weighted count of risk factors with B rounded to nearest 0.5. Risk count is unweighted sum of risk factors
Ettinger et al, 2005 | Ettinger et al, 2005^99^ | X | X | Height, current smoking, mother or sister with hip fracture, prior non-spine fracture, Z score at hip and spine | Computer model for risk calculation given in the appendix
Fracture Index | Black et al, 2001^88^ | X | X | Fracture after age 50, maternal hip fracture after age 50, weight ≤125 lbs, current smoking, uses arms to stand from chair, total hip T score | Sum of points: 1 point for each 5 years over age 65 (up to 5 points for those >age 85), 1 point each for personal fracture, family history of fracture, weight <125, current smoking, 2 points for no/don’t know on chair stand; T score >−1 (0 point), T between −1 and −2 (2 points), T score between − 2 and −2.5 (3 point), T score <−2.5 (4 points)
FRAX | Donaldson et al, 2009^96^ Ensrud et al, 2009^98^ Kanis et al, 2007^104^ Sandhu et al, 2010^113^ | X | X (BMI) | Age, sex, BMI, family history of fracture, glucocorticoid use, prior fracture, current smoking, alcohol, rheumatoid arthritis, hip T score | Risk calculator is available at www.shef.ac.uk, but the algorithm itself (equation for obtaining the risk score) is not published.
Minimum Data Set (Girman et al, 2002) | Girman et al, 2002^100^ | X | X | Height, locomotion on unit, Fall in past 180 days, ADL score, MDS cognition scale score, urinary incontinence | Age 75–84=1 point, age 85–94=2 points, age ≥95=3 points; weight<170lbs=1 point; height ≤ 58 inches=2 points, height >58 inches and ≤ 63 inches = 1 point; fall = 1 point, ADL ≤4 = 1 point; MDS cognition scale score ≤3 = 1 point; occasionally incontinent (vs. usually continent or usually incontinent) = 1 point. Sum of scores. If sum≤4 the observed 18 months fracture rate = 8.05%; if score >4 the observed fracture rate = 15.25.
Masoni et al, 2005 | Masoni et al, 2005^71^ | | X (BMI) | >10 years since menopause, calcium intake<1200 mg/day, personal history of fracture, kyphosis, personal history of fracture + kyphosis | Risk calculated from regression equation
MORES | Shepherd et al, 2007^81^ | X | X | History of COPD | Sum of points: Age 56–74 years = 3 points; ≥75 years = 4 points. Weight ≤70 kg = 6 point; weight >70kg but ≤80kg = 4 points. >80 kg = 0 points; COPD = 3 points
NOF guideline 1994 | Cadarette et al, 2001^56^ D’Amelio et al, 2005^62^ Devlin et al, 2007^63^ Geusens et al, 2002^64^ Mauck et al, 2005^72^ | X | X | Personal history of any fracture >age 40, current smoking, maternal and/or parental history of hip, wrist or spine fracture ≥ age 50 | 1 point for each: age >65, weight < 57.6 kg, personal history of any fracture >age 40, current smoking, maternal and/or parental history of hip, wrist or spine fracture >age 50
Osteoporosis Canada simplified score | Leslie et al, 2009^106^ Richards et al, 2007^111^ | X | | BMD, systemic corticosteroid use, prior fragility fracture, gender | Within age and gender categories, corticosteroid use and prior fracture tallied (1 point for each). Absolute fracture rates obtained from Malmo population data
OPERA | Salaffi et al, 2005^79^ | X | X | History of minimal trauma fracture, early menopause, systemic glucocorticoids | One point for each risk factor
ORAI | Cook et al, 2005^61^ Cass et al, 2006^60^ Cadarette et al, 2000^55^ Cadarette et al, 2001^56^ Cadarette et al, 2004^57^ Devlin et al, 2007^63^ Geusens et al, 2002^64^ Gourlay et al, 2005^66^ Harrison et al, 2006^67^ Martinez-Aguila et al, 2007^70^ Mauck et al, 2005^72^ Nguyen et al, 2004^74^ Rud et al, 2005^77^ Wallace et al, 2004^85^ Wei et al, 2004^115^ | X | X | Current use of estrogen | Sum: +2 points for non-current estrogen use, +9 points for weight <60kg or +3 points for weight between 60–70kg, 0 points for weight >70 kg. +15 points for age ≥75 years; +9 points for ages between 65–74; +5 points for ages between 55–64, 0 points for ages 45–54. Score 9 = low risk >9 and <17 = moderate risk >17 = high risk 23:23
OSIRIS | Cook et al, 2005^61^ Harrison et al, 2006^67^ Martinez-Aguila et al, 2007^70^ Minnock et al, 2008^73^ Reginster et al, 2004^75^ Sedrine et al, 2002^80^ | X | X | Estrogen and history of fracture | Current age (−2) and truncated to integer, weight in kg times 2 and truncated to integer, +2 points if current HRT, and −2 points if history of prior low impact fracture. >+1 = low risk; < +1; >−3 = intermediate risk; <−3 high risk
OST | Adler et al, 2003^52^ Cadarette et al, 2001^56^ Cadarette et al, 2004^57^ Cass et al, 2006^60^ Cook et al, 2005^61^ D’Amelio et al, 2005^62^ Geusen et al, 2002^64^ Gourlay et al, 2005^66^ Harrison et al, 2006^67^ Martinez-Aguila et al, 2007^70^ Mauck et al, 2005^72^ Richy et al, 2004^76^ Rud et al, 2005^77^ Wallace et al, 2004^85^ | X | X | | (Weight in Kg minus age in years) (0.2), truncated to the integer. OR (Weight in kg ) (0.2) minus (0.2) (age in years); drop last digit from each to give integer and add the resulting values together. For Caucasians: >+2 = low risk; +2 to −3 moderate risk; <−3; high risk for low BMD
SCORE | Brenneman et al, 2003^54^ Cadarette et al, 2001^56^ Cass et al, 2006^60^ Cook et al, 2005^61^ Geusens et al, 2002^64^ Gourlay et al, 2005^66^ Harrison et al, 2006^67^ La Croix et al, 2005^117^ Mauck et al, 2005^72^ Rud et al, 2005^77^ Russell et al, 2001^78^ Sedrine et al, 2001^53^ Smeltzer et al, 2005^83^ Wallace et al, 2004^85^ | X | X | Race/ethnicity, rheumatoid arthritis, estrogen use and history of fracture after age 45 | Sum: + 5 points for race other than Black, +4 points for RA, +4 points for each non-traumatic fracture after age 45; +1 if never estrogen, 3 times the first digit of pt’s age and −1 times the patients weight in lbs, divided by ten and truncated to an integer. < +7 = low risk; > +7 to < +15 = moderate risk; > +15 = high risk Some use SCORE >6 for BMD testing
SOF/Cummings | Ahmed et al, 2006^87^ Brennamen et al, 2003^54^ LaCroix et al, 2005^117^ Richards et al, 2008^116,*^ | X | X | Weight < that at age 25, height at age 25 ≤168cm, maternal hip fracture, personal fracture after age 50, self-rated health - fair, poor or very poor; no walking for exercise, current use of benzodiazepines or anticonvulsants; resting pulse>80 bpm, caffeine >2 cups of coffee/day, inability to rise from chair without using arms, previous hyperthyroidism, age ≥80, on feet ≤4 hours/day, lowest quartile of depth perception, lowest quartile of contrast sensitivity, calcaneal BMD | Sum of weights for each factor; Age: 75=0, 76–79=1, 80–84=2, 85 and older =3. History of falling: No=0, Yes=1. Tandem walk: Able with or without trials=0, Unable=2. Gait speed >1.4mg/s=0, 1.0–1.4mg/s=1, 0.6 1.0m/s =2, <0.6m/s=3. Ahmed et al, 2006 allocated women into groups by number of risk factors. Score >5 is increased risk.
SOFSURF | Cook et al, 2005^61^ Geusens et al, 2002^64^ Nguyen et al, 2004^74^ | X | X | Smoking, history of postmenopausal fracture | Index calculated as +0.2 points for every year over age 65, −0.2 points for every year under age 65; +3 points for weight below 130 lbs and +1 point for wet between 130–150 lbs, +1 point for current smoker, +1 point for history of post-menopausal fracture <0=low risk; 0 and <+4=intermediate risk; > +4 high risk
WHI | Robbins et al, 2007^112^ | X | X | Self-reported health, height (in), weight (lb), fracture at age ≥55 years, race/ethnicity (white/non-white), physical activity, smoking status, parental history of hip fracture, corticosteroid use, use of hypoglycemic agent | Age: (1/2 point per year) >50 Self reported health: fair/poor =3 points; good =1 point, very good =0 (all vs. excellent) Height: 1/2 point per inch >64 Weight: 1 point per 25 lb <200 Fracture at ≥55 years: yes =2 points (vs. no) Race/ethnicity: white =3 points (vs. non-white) Physical activity METS: inactive =1 point. Smoking status, current =3 points. Parental history of hip fracture: yes =1 point. Corticosteroid use: yes =3 points. Hypoglycemic agent use: yes =2 points. Total point score of 9 yields a probability of fracture of 0.1%; point total of 18 yields a probability of fracture of 1%; a point total of 24 yields a probability of fracture of 5%

Abbreviations: ABONE = Age, body size, no estrogen; ADL = activities of daily living; BMD = bone mineral density; BMI = body mass index; COPD = chronic obstructive pulmonary disease; DOEScore = Dubbo Osteoporosis Epidemiology Study score; EPESE = Established Populations for the Epidemiologic Study of the Elderly; FN = femoral neck; HRT = hormone replacement therapy; MDS = minimum data set; METS = metabolic equivalents; MORES = Male Osteoporosis Risk Estimation Score; NOF = National Osteoporosis Foundation; OPERA = Osteoporosis Prescreening Risk Assessment; ORAI = Osteoporosis Risk Assessment Instrument; OSIRIS = Osteoporosis Index of Risk; OST = Osteoporosis Self-assessment Tool; SCORE = Simple Calculated Osteoporosis Risk Estimation; SOF = Study of Osteoporotic Fractures; SOFSURF = Study of Osteoporosis Fractures—Study Utilizing Risk Factors; WHI = Women’s Health Initiative.

* Includes 10 items adapted from the SOF risk assessment instrument.

Appendix Table D3 Primary Prevention Randomized Controlled Trials

Author year | Study design/duration | Inclusion criteria | Population | Interventions | Routine lumbar radiography to identify new fractures | Fractures | Adverse events and withdrawals | Comments
Ascott-Evans et al, 2003^139^ | Double-blind, randomized PCT 1 year | Postmenopausal aged <80 years; previous use of HRT for at least 1 year; baseline T-score −3.5 to −1.5 | n=144 aged <65 years: 85% mean T-score: −2.3 previous fractures: excluded | Alendronate 10 mg qd vs. placebo | No | Alendronate vs. placebo Any fracture: 0/95 (0%) vs. 0/47 (0%) | Alendronate vs. placebo Withdrawals: 25/144 (17.3%); 12/95 (13%) vs. 13/49 (26%) Withdrawals due to AEs: 10/95 (10%) vs. 10/49 (20%) | Fracture incidence was not an efficacy outcome
Chesnut et al,1995^140^ | Double-blind, randomized PCT 2 years | At least 5 years postmenopausal aged 43–75 years; lumbar spine BMD ≤0.88 g/cm^2^ (~−2.0 SD below normal) | n=188 mean age: 63 years mean hip T-score: −1.1 previous fractures: excluded | Alendronate 10 mg qd vs. placebo | Yes | Alendronate vs. placebo Vertebral fracture: 0/30 (0%) vs. 0/31 (0%) Non-vertebral fracture: 13 total, results not stratified by treatment group | Withdrawals: 34/188 (18%) overall (not stratified by treatment group) Other adverse events not stratified by treatment group
Cummings et al, 1998^50^ Fracture Intervention Trial (FIT) | Double-blind, randomized PCT 4 years | At least 2 years postmenopausal age 55–80 years; femoral neck BMD ≤0.68 g/cm^2^ (~−1.6 SD below normal) | n=4,432 mean age: 67.7 years mean T-score: −2.2 previous fractures: excluded | Alendronate 5 mg qd for 2 years, then 10 mg qd for 1 year vs. placebo | Yes | Alendronate vs. placebo Vertebral fracture - first fracture: 43/2214 (1.9%) vs. 78/2218 (3.5%); RR 0.56 (CI 0.39–0.80; p=0.002) Nonvertebral fracture: 261/2214 (11.8%) vs. 294/2218 (13.3%) placebo; RR 0.88 (CI 0.74 to 1.04; p=0.13) Hip fracture: 19/2214 (0.9%) vs. 24/2218 (1.1%) Wrist fracture: 83/2214 (3.7%) vs. 70/2218 (3.2%) | Alendronate vs. placebo Withdrawals due to AEs: 221/2214 (9.9%) vs. 227/2218 (10.2%) All-cause mortality: 37/2214 (1.7%) vs. 40/2218 (1.8%) Any upper GI event: 1052/2214 (48%) vs. 1047/2218 (47%) Abdominal pain: 322/2214 (14%) vs. 325/2218 (15%) Esophagitis: 19/2214 (0.9%) vs. 10/2218 (0.5%) Esophageal ulcer: 4/2214 (0.2%) vs. 4/2218 (0.2%) Other esophageal: 44/2214 (2.0%) vs. 41/2218 (1.8%) Acid regurgitation/reflux: 204/2214 (9.2%) vs. 194/2218 (8.7%)
Dursun et al, 2001^141^ | Randomized PCT 1 year | Postmenopausal with BMD ≤ −2.0 SD below mean at lumbar spine or femoral neck | n=151 mean age: 61.2 years mean T-score: −1.5 previous fractures: unknown | Alendronate 10 mg + calcium 1000 mg qd vs. calcium 1000 mg qd | Yes | Alendronate vs. placebo Vertebral fracture: 12/51 (24%) vs. 14/50 (28%) Nonvertebral fracture: not reported | Withdrawals due to AEs: none in either treatment group
Greenspan et al, 2007^151^ | Double-blind, randomized PCT 18 months | Postmenopausal age 45–54 years with T-score ≤ 3.0 below mean for young women with no prevalent vertebral fracture or T-score −2.5 with 1–4 vertebral fractures | n=2532 (n=2061 without baseline fracture) mean age: 64.4 years mean T-score: −2.2 previous fractures: 19% | PTH 100μg qd vs. placebo | Yes | PTH vs. placebo. Vertebral fracture (results for participants without baseline fracture): PTH 7/1050 (0.7%) vs. placebo 21/1011 (2.1%) Nonvertebral fracture (results not stratified by baseline fracture status): 72/1286 (5.6%) vs. 72/1246 (5.8%) | Parathyroid hormone vs. placeboWithdrawals: 831/2532 (32.8%) Withdrawals dues to AEs: 154/1286 (12%) vs. 76/1246 (6.1%) All-cause mortality: 1/1286 (0.08%) vs. 2/1246 (0.16%) Arthralgia: 282/1286 (22%) vs. 276/1246 (22%) Myalgia: 64/1286 (5.0%) vs. 62/1246 (5.0%)
Herd et al, 1997^144^ | Double-blind, randomized PCT 2 years | 1–10 years postmenopausal | n=152 mean age 54.8 years mean T-score: −1.3 prior fractures: excluded | Cyclical etidronate 400 mg qd vs. placebo | Yes | Etidronate vs. placebo Any fracture: 0/75 (0%) vs. placebo 0/77 (0%) | Etidronate vs. placebo Withdrawals: 11/75 (14.7%) vs. 6/77 (7.8%) Withdrawals due to AEs: 5/75 (6.7%) vs. 0/77 (0%) Back pain: 12/74 (16%) vs. 14/76 (18%) | Fracture incidence not an efficacy outcome
Hooper et al, 2005^147^ | Double-blind, randomized PCT 2 years | 6–36 months postmenopausal | n=383 mean age: 53 years mean T-score: −0.7 previous fractures: unknown | Risedronate 2.5 to 5.0mg qd vs. placebo | Yes | Risedronate 2.5 mg vs. 5 mg vs. placebo Vertebral fractures: 11/127 (8.7%) vs. 10/129 (7.8%) vs. 10/125 (8.0%) Nonvertebral fractures: 3/127 (2.4%) vs. 5/129 (3.9%) vs. 6/125 (4.8%) | Risedronate vs. placebo Withdrawals: 52/256 (20%) vs. 32/125 (26%) Withdrawals due to AEs: 19/256 (7.4%) vs. 8/125 (6.4%) Abdominal pain: 18/256 (7.0%) vs. 6/125 (4.8%)
Hosking et al, 1998^142^ | Double-blind, randomized PCT 2 years | ≥6 months postmenopausal with no clinical or laboratory evidence of systemic disease | n= 1609 mean age 53.3 years mean T-score: −0.1 previous fractures: unknown | Alendronate 5 mg qd vs. placebo | No | Alendronate vs. placebo Vertebral fracture: 0/498 (0%) vs. 0/502 (0%) Nonvertebral fracture: alendronate 2.5 mg 22/499 (4.4%) vs. alendronate 5 mg 22/498 (4.4%) vs. placebo 14/502 (2.8%) | Withdrawals: 139/1609 (8.6%); 89/997 (8.9%) alendronate vs. 46/503 (9.2%) placebo vs. 4/110 (3.4%) estrogen-progestin Withdrawals due to AEs: 67/997 (6.7%) alendronate vs. 27/503 (5.4%) placebo vs. 15/110 (13.6%) estrogen-progestin Upper GI AEs, any type: 300/997 (30%) alendronate vs. 148/502 (29%) placebo vs. 31/110 (28%) estrogen-progestin CV AEs: 99/997 (10%) alendronate vs. 47/502 (9.4%) placebo vs. 15/110 (14%) | Baseline data and efficacy outcomes assessment included only women with baseline LS BMD and at least one on-treatment measurement; safety data included all randomized patients
Liberman et al, 1995^47^ | Double-blind, randomized PCT 3 years | Age 45–80 years, ≥5 years postmenopausal with BMD T-score worse than −2.5 | n=637 (no prior fracture) mean age: 64 years (with or without prior fracture) mean T-score: −2.2 previous fracture: 21% | Alendronate 5 or 10 mg qd for 3 years or 20 mg qd for 2 years followed by 5 mg qd for 1 year vs. placebo | Yes | Alendronate (all doses) vs. placebo Vertebral fracture (in women without prior vertebral fracture) 4/384 (1.0%) vs. 5/253 (2.0%) | Alendronate 10 mg vs. placebo (with or without vertebral fracture at baseline) Withdrawals: 26/196 (13.3%) vs. 65/397 (16.4%) Withdrawals due to AEs: 35/597 (5.8%; all doses of alendronate) vs. 24/397 (6.0%) Withdrawals due to upper GI AEs: 2/196 (1.0%) vs. 8/397 (2.0%) Abdominal pain: 13/196 (6.6%) vs. 19/397 (4.8%) Musculoskeletal pain: 8/196 (4.1%) vs. 10/397 (2.5%) Nausea: 7/196 (3.6%) vs. 16/397 (4.0%) Dyspepsia: 7/196 (3.6%) vs. 14/397 (3.5%) Constipation: 6/196 (3.1%) vs. 7/397 (1.8%) Diarrhea: 6/196 (3.1%) vs. 7/397 (1.8%) | Non-vertebral fractures not reported in subgroup of women without baseline fracture
McClung et al, 2001^41^ | Double-blind, randomized PCT 3 years | Women 70–79 years with BMD T-score worse than −4 or worse than −3 with non-skeletal risk factors for fall | n=2648 (no prior fracture) mean age: 74 years (with or without prior fracture) mean T-score: −3.7 (with or without prior fracture) previous fractures: results of subgroup with no previous fractures reported | Risedronate 2.5 or 5 mg qd vs. placebo | No | Risedronate 2.5 or 5 mg vs. placebo Hip fracture (in women without prior vertebral fracture): 14/1773 (1.0%) vs. 12/875 (1.6%) | Risedronate 5 mg vs. placebo (with or without vertebral fracture at baseline) Withdrawal due to AEs: 550/3104 (18%) vs. 564/3134 (18%) Serious AEs: 943/3104 (30%) vs. 973/3134 (31%) Any AEs: 2786/3104 (89.8%) vs. 2805/3134 (89.5%) Any upper GI AEs: 657/3104 (21%) vs. 684/3134 (22%) Moderate to severe upper GI AEs: 279/3104 (9.0%) vs. 258/3134 (8.3%) Abdominal pain: 250/3104 (8.1%) vs. 288/3134 (9.2%) Dyspepsia: 255/3104 (8.2%) vs. 254/3134 (8.1%) Esophagitis: 54/3104 (1.7%) vs. 59/3134 (1.9%) Esophageal ulcer: 9/3104 (0.3%) vs. 14/3134 (0.4%) | Hip fractures reported in subgroup of women without baseline fracture
Meunier et al, 1997^145^ | Double-blind, randomized PCT 2 years | 6–60 months postmenopausal women within 15% of normal BMI, normal BMD (+/− 2SD expected value) | n=54 mean age: 52.7 years mean T-score: −1.1 previous fractures: not reported | Cyclical etidronate 400 mg qd vs. placebo | Yes | Etidronate vs. placebo Vertebral fracture: 1/27 (3.7%) vs. 0/27 (0%) Non-vertebral fracture: 2/27 (7.4%) vs. 3/27 (11%) | Etidronate vs. placebo Withdrawals: 2/27 (7.4%) vs. 3/27 (11%) Withdrawals due to AEs: 0/27 (0%) vs. 2/27 (7.4%) Pain: 5/27 (18%) vs. 5/27 (18%) Abdominal pain: 4.27 (15%) vs. 1/27 (3.7%) | All reported fractures described as traumatic
Mortensen et al, 1998^148^ | Double-blind, randomized PCT 2 years treatment, outcomes assessed through 3 years | 6–60 months postmenopause, weight 45–90kg, within 25% of normal weight and height | n=111 mean age: 51.5 years mean T-score: −1.1 previous fractures: not reported | Risedronate 5 mg (daily or 2-week cyclical dosing) vs. placebo | Yes | Risedronate daily vs. risedronate cyclic vs. placebo Vertebral fractures: 1/37 (2.7%) vs. 1/38 (2.6%) vs. 0/36 (0%) Nonvertebral fractures: 0/37 (0%) vs. 3/38 (7.9%) vs. 3/36 (8.3%) | Risedronate vs. placebo Withdrawals: 15/111 (13.5%) overall Withdrawals due to AEs: 5/75 (6.7%) vs. 3/36 (8.3%) Abdominal pain: 8/75 (11%) vs. 4/36 (11%) | Nonvertebral fractures were all described as traumatic Withdrawals reported through year 1 - continuation in study beyond that point was at patient's discretion
Orwoll et al, 2003^159^ | Double blind, randomized PCT planned for 2 years, study stopped after median 11 months | Men age 30–85 years, ambulatory, free of chronic, disabling conditions other than osteoporosis, lumbar spine of proximal femur BMD ≥ −2 SD below mean for healthy young men | n=437 mean age: 59 years mean T-score −2.7 previous fractures: unknown | Teriparatide 20 or 40 μg subcutaneous injection qd vs. placebo | Yes | Teriparatide 20 ug vs. 40 ug vs. placebo Vertebral fractures: not reported Nonvertebral fracture: 2/151 (1.3%) vs. 1/139 (0.7%) vs. 3/147 (2.0%) | Teriparatide vs. placebo Withdrawals due to AEs: 32/290 (11.0%) vs. 7/147 (4.8%) Nausea: 34/290 (11.7%) vs. 5/147 (3.4%)
Pols et al, 1999^143^ | Double-blind, randomized PCT 1 year | ≤ 3 years postmenopause, ≥ 85 years, BMD of Lumbar spine (L2–4) ≥ −2 SD below the average for mature, menopausal women. Between > 20% and < 50% ideal body weight. | n = 1908 mean age: 63.0 years mean T-score: −2.0 previous fractures: unknown | Alendronate 10 mg qd vs. placebo | No | Alendronate vs. placebo Vertebral fractures: not evaluated Nonvertebral fractures: 19/950 (2.0%) vs. 37/958 (3.9%) placebo Hip fracture: 2/950 (0.2%) vs. 3/958 (0.3%) Wrist fracture: 6/950 (0.6%) vs. 15/958 (1.6%) Ankle/lower leg fracture: 2/950 (0.2%) vs. 5/958 (0.5%) | Alendronate vs. placebo Withdrawals due to AEs: 61/950 (6.4%) vs. 54/958 (5.6%)
Pouilles et al, 1997^146^ | Double-blind, randomized PCT 2 years | 6–60 months postmenopause women aged 45–60 years, within 20% of normal BMI | n=109 mean age: 53.8 years mean T-score: −0.8 previous fractures: unknown | Cyclical etidronate 400 mg qd vs. placebo | No | Etidronate vs. placebo Vertebral fracture: 1/54 (1.9%) vs. 0/55 (0%) Nonvertebral fracture: 3/54 (5.6%) vs. 6/55 (11%) | Etidronate vs. placebo Withdrawals: 9/54 (17%) vs. 9/55 (16%) Withdrawals due to AEs: 1/54 (1.9%) vs. 0/55 (0%) Abdominal pain: 7/54 (13%) vs. 6/55 (11%) | 9/10 fractures described as traumatic (1 non-traumatic, non-vertebral fracture)
Reid et al, 2002^150^ | Double-blind, randomized PCT 1 year | Age 45–80 years, ≥5 years postmenopause, lumbar spine BMD ≤2.0 SD below the mean value for young adults; no more than one vertebral fracture at baseline | n=351 mean age: 64.2 years mean T-score: −1.2 previous fractures: excluded | Zoledronic acid 4 mg intravenous annually in 1 to 4 doses vs. placebo | Yes | Zoledronic acid 4 mg/year vs. placebo Vertebral fractures: 0/174 (0%) vs. 0/59 (0%) Nonvertebral fractures: 4/174 (2.3%) vs. 1/59 (1.7%) | Zoledronic acid (any dose) vs. placebo Withdrawals: 35/351 (9.8%) overall Withdrawals due to AEs: 13/292 (4.6%) vs. 1/59 (1.7%) Myalgia: 41/292 (14%) vs. 1/59 (1.7%) Arthralgia: 46/292 (16%) vs. 9/59 (15%) | No patients had baseline vertebral fractures
Valimaki et al, 2007^149^ | Double-blind, randomized PCT 2 years | ≥5 years postmenopause, ≥osteoporosis risk factor or the presence of hip osteopenia | n=171 mean age: 65.9 years mean T-score: −1.2 previous fractures: unknown | Risedronate 5mg qd vs. placebo | No | Risedronate vs. placebo Vertebral fracture: 0/114 (0%) vs. 0/56 (0%) Nonvertebral fracture: 2/114 (1.8%) vs. 2/53 (3.8%) Hip fracture: 0/114 (0%) vs. 0/56 (0%) Wrist fracture: 0/114 (0%) vs. 1/56 (1.8%) Ankle fracture: 0/114 (0%) vs. 1/56 (1.8%) All-cause mortality: 0/114 (0%) vs. 0/56 (0%) | Risedronate vs. placebo Withdrawals: Not reported Withdrawals due to AEs: 10/115 (8.7%) vs. 9/55 (16%) placebo

Abbreviations: AE = adverse events; BMD = bone mineral density; BMI = body mass index; CI = confidence interval; CV = cardiovascular; GI = gastrointestinal; HRT = hormone replacement therapy; LS = lumbar spine; PCT = placebo controlled trial; PTH = parathyroid hormone; RR = relative risk; SD = standard deviation.

* BMD T-scores are based on femoral neck measurements and calculated using the FRAX Patch instrument, unless otherwise stated.

Appendix Table D4 Quality Ratings of Primary Prevention Randomized Controlled Trials

Author year | Random assignment | Allocation concealed | Groups similar at baseline | Eligibility criteria specified | Blinding: patients | Blinding: providers | Blinding: outcome assessors or data analysts | Intention-to-treat analysis | Reporting of attrition, contamination, etc | Differential loss to follow-up or overall high loss to follow-up | Funding source | External validity | Quality score
Ascott-Evans et al, 2003^139^ | Yes | Don't know | Yes | Yes | Yes | Yes | Yes | Don't know | Yes | No | Merck | Aged <65 years: 84.7% Mean T-score: −2.3 | Fair
Chesnut et al,1995^140^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Merck | Mean age 63 years Mean hip T-score: −1.1 | Fair
Cummings et al, 1998^50^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Merck | Mean age 67.7 years Mean T-score: −2.2 | Good
Dursun et al, 2001^141^ | Don't know | Don't know | No | Yes | Don't know | Don't know | Don’t know | No | No | Don't know | Not reported | Mean age 61.2 years Mean T-score: −1.5 | Poor
Greenspan et al, 2007^238^ | Yes | Yes | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | No | NPS Pharmaceuticals | Mean age 64.4 years Mean T-score: −2.2 | Fair
Herd et al, 1997^144^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | Yes | Not reported | Mean age 54.8 years Mean T-score: −1.3 | Fair
Hooper et al, 2005^147^ | Yes | Don't know | Yes | Yes | Yes | Don't know | Don't know | Yes | Yes | No | Proctor & Gamble | Mean age 53 years Mean T-score: −1.3 | Fair
Hosking et al, 1998^142^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | Yes | Merck | Mean age 53.3 years Mean T-score: −0.1 | Fair
Liberman et al, 1995^47^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | No | Yes | Yes | Merck | Mean age 64 years Mean T-score: −2.2 | Fair
McClung et al, 2001^41^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | Yes | Proctor & Gamble and Aventis Pharma | Mean age 74 years Mean T-score: −3.7 | Fair
Meunier et al, 1997^145^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Don’t know | Yes | Yes | Proctor & Gamble | Mean age 52.7 years Mean T-score: −1.1 | Fair
Mortensen et al, 1998^148^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | Yes | Proctor & Gamble | Mean age 51.5 years Mean T-score: −1.1 | Fair
Orwoll et al, 2003^159^ | Yes | Yes | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | No | Eli Lilly | Mean age 59 years Mean T-score: −2.7 | Good
Pols et al, 1999^143^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | Yes | Merck | Mean age 63.0 years Mean T-score: −2.0 | Fair
Pouilles et al,1997^146^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | Yes | Novartis | Mean age 53.8 years Mean T-score: −0.8 | Fair
Reid et al, 2002^150^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | Yes | Novartis | Mean age 64.2 years Mean T-score: −1.2 | Fair
Valimaki et al, 2007^149^ | Don't know | Don't know | Yes | Yes | Yes | Yes | Don't know | Yes | Yes | Yes | Proctor & Gamble Sanofi-Aventis | Mean age 65.9 years Mean lT-score: −1.2 | Fair

Appendix Table D5 Placebo-controlled Trials of Bisphosphonates Reporting Fracture Outcomes Classified as Secondary Prevention

Trial | Reason for exclusion
Alendronate
Black et al, 1996^239^ | 100% of enrolled patients had prior vertebral fracture
Bone et al, 1997^38^ | 37% of enrolled patients had prior vertebral fracture
Greenspan et al, 1998^46^ | Baseline vertebral fracture not reported; 55% of enrolled patients had osteoporosis at baseline according to WHO femoral neck criteria
Greenspan et al, 2002^39^ | 55% of enrolled patients had prior fracture (site not specified)
Orwoll et al, 2000^165^ | 50% of enrolled patients had prior vertebral fracture
Ringe et al, 2004^166^ | 54% of enrolled patients had prior vertebral fracture
Etidronate
Ishida et al, 2004^40^ | 31% of enrolled patients had prior vertebral fracture
Lyritis et al, 1997^240^ | 100% of enrolled patients had prior vertebral fracture
Montessori et al, 1997^48^ | 36% of enrolled patients with radiologic studies (78/80 patients) had prior vertebral fracture
Pacifici et al, 1988^241^ | 100% of enrolled patients had prior vertebral fracture
Shiota et al, 2001^242^ | 60% of enrolled patients had prior vertebral fracture
Storm et al, 1990^243^ | 100% of enrolled patients had prior vertebral fracture
Watts et al, 1990^244^ | 100% of enrolled patients had prior vertebral fracture
Wimalawansa et al, 1998^245^ | 100% of enrolled patients had prior vertebral fracture
Risedronate
Clemmesen et al, 1997^246^ | 100% of enrolled patients had prior vertebral fracture
Fogelman et al, 2000^45^ | 29% of enrolled patients had prior vertebral fracture
Harris et al, 1999^247^ | 80% of enrolled patients had prior vertebral fracture
McClung et al, 2001^41^ | 41% of enrolled patients had prior vertebral fracture among patients with baseline fracture data (2799/6876; 2455/9331 baseline fracture status unknown)
Reginster et al, 2000^248^ | 100% of enrolled patients had prior vertebral fracture
Ibandronate
Chesnut et al, 2005^167^ | 100% of enrolled patients had prior vertebral fracture
Recker et al, 2004^168^ | 54% of enrolled patients had prior vertebral fracture
Zoledronic acid
Black et al, 2007^174^ | 63% of enrolled patients had prior vertebral fracture
Lyles et al, 2007^175^ | 100% of enrolled patients had prior hip fracture

Appendix Table D6 Fracture Rates in Bisphosphonate Trials Only Included In Sensitivity Analyses

Trial | Intervention Duration Baseline BMD Baseline fracture | Radiologically confirmed fracture incidence? | [underlined: Vertebral fracture] | [underlined: Nonvertebral fracture] | [underlined: Hip fracture]
Trial | Intervention Duration Baseline BMD Baseline fracture | Radiologically confirmed fracture incidence? | Active treatment vs. placebo Relative risk (95% CI) | Active treatment vs. placebo Relative risk (95% CI) | Active treatment vs. placebo Relative risk (95% CI)
Bisphosphonates
Alendronate
Bone et al, 1997^38^ | Alendronate 5 mg 2 years T-score: −3.1 Previous vertebral fracture: 37% | Yes | 4/93 (4%) vs. 6/91 (7%) RR 0.65 (0.19 to 2.24) | 9/93 (10%) vs. 16/91 (18%) RR 0.55 (0.26 to 1.18) | NR
Greenspan et al, 1998^46^ | Alendronate 5–10 mg 2.5 years T-score: −4.3 Unknown prior fracture | No | Not assessed | 3/60 (5%) vs. 1/60 (2%) RR 3.00 (0.32 to 28) | 0/60 (0%) vs. 1/60 (2%) RR 0.33 (0.01 to 8.02)
Liberman et al, 1995^47^ | Alendronate 5 or 10 mg for 3 years, or 20 mg for two years and 5 mg for 1 year T-score: −3.1 Previous vertebral fracture: 21% | Yes | 17/526 (3%) vs. 22/355 (6%) RR 0.52 (0.28 to 0.97) | 45/597 (8%) vs. 38/397 (10%) RR 0.79 (0.52 to 1.19) | 1/597 (0.2%) vs. 3/397 (1%) RR 0.22 (0.02 to 2.12)
Etidronate
Ishida et al, 2004^40^ | Cyclical etidronate 200 mg/day 2 years T-score: −1.9 Previous vertebral fracture: 31% | Yes | 8/66 (12%) vs. 17/66 (26%) RR 0.47 (0.22 to 1.01) | 1/66 (2%) vs. 3/66 (5%) RR 0.33 (0.04 to 3.12) | 0/66 (0%) vs. 1/66 (2%) RR 0.33 (0.01 to 8.04)
Montessori et al, 1997^48^ | Cyclical etidronate 400 mg/day 3 years T-score: −3.4 Previous vertebral fracture: 36% | Yes | 0/37 (0%) vs. 3/34 (9%) RR 0.13 (0.01 to 2.46) | NR | 0/39 (0%) vs. 0/39 (0%) RR not estimable
Risedronate
Fogelman et al, 2000^45^ | Risedronate 5 mg/day 2 years T-score: −2.9 Previous vertebral fracture: 30% | Yes | 8/112 (7.1%) vs. 17/125 (14%)^*^ RR 0.53 (0.24 to 1.17) | 7/140 (5%) vs. 13/144 (9%)^*^ RR 0.55 (0.23 to 1.35) | Not reported

Abbreviations: BMD = bone mineral density; CI = confidence interval; NR = not reported; RR = relative risk.

* Intention-to-treat results not reported (sample sizes 180 for risedronate and 177 for placebo).

Appendix Table D7 Treatment Systematic Reviews

Study, Year | | Aims | Databases searched; Literature search dates; Other data sources | Eligibility criteria | Patients/trials | Characteristics of identified articles: study designs | Characteristics of identified articles: populations | Characteristics of identified articles: interventions | Main efficacy outcome | Main efficacy results | Harms results | Conclusion | Quality Score | Comments
Cranney et al, 2002^176^ | | To review the effect of calcitonin on bone density and fractures in postmenopausal women | MEDLINE, EMBASE 1966–2000; conference abstracts, FDA proceedings | RCTs ≥1 year duration enrolling post-menopausal women, comparing calcitonin to placebo or calcium/vitamin D with fracture or BMD outcomes | 30 trials; total n=3,993 Chesnut 2000 (n=1,255); Flicker 1997 (n=62); Grigoriou 1997 (n=45); Gurlek 1997 (n=20); Kapetanos 1997 (n=46); Ellerington 1996 (n=117); Hizmetli 1996 (n=107); Melis 1996 (n=102); Perez-Jaraiz 1996 (n=52); Thamsborg 1996 (n=72); Perez 1995 (n=73); Reginster 1995 (n=251); Reginster 1995 (n=150); Rico 1995 (n=72); Campodarve 1994 (n=236); Kollerup 1994 (n=54); Overgaard 1994 (n=134); Reginster 1994 (n=287); Meschia 1993 (n=46); Fioretti 1992 (n=60); Gennari 1992 (n=21); Overgaard 1992 (n=84); Perrone 1992 (n=85); Stevenson 1992 (n=86); Thamsborg 1991 (n=40); Meunier 1990 (n=109); Tremollieres 1990 (n=1990); Overgaard 1989 (n=52); Overgaard 1989 (n=40); Gennari 1985 (n=82) | RCTs; 16 treatment trials, 13 prevention trials, 1 combination treatment/prevention; 15 blinded; 16 concealed treatment allocation | Mean age 50–70 years 27 trials, <50 years in 3 trials Mean baseline T-score −0.6 to − 2.9 in 15 trials; not reported in 15 trials | Calcitonin 50–400 IU qd placebo calcium/vitamin D | Fracture incidence (also change in BMD) | Vertebral fracture (4 trials): RR 0.46 (CI 0.25–0.87; p=0.02) Non-vertebral fracture (3 trials): RR 0.52 (CI 0.22 to 1.23; p-0.14) | Described as poorly reported across the trials; loss to follow-up was similar in calcitonin and control groups | Calcitonin reduces the incidence of vertebral fracture, but the magnitude of effect is unclear due to small sample sizes in the trials used to calculate relative risks and the use of random-effects modeling which may place undue weight on smaller studies | Fair
Harris et al, 2008^173^ | | To assess the ability of ibandronate to reduce fracture risk relative to placebo | Not applicable | Not applicable | 4 trials: total n=8,710 Chesnut 2005 - BONE trial (n=2,928 ); Recker 2004 - IV Fracture Prevention trial (n=2,860 ); Reginster 2006 and Miller 2005 - MOBILE trial (n=1,566); Eisman 2006 and Delmas 2006 - DIVA trial (n=1,356 ) | Double-blind RCTs reporting fracture outcomes | Age 66–69 years Baseline lumbar spine T-score − 2.81 to − 3.28 | Ibandronate, varying doses, dosing schemes and methods of administration (IV and oral) placebo | Nonvertebral fracture incidence (also clinical fracture incidence) | Non-vertebral fractures High-dose ibandronate: adjusted HR 0.70 (CI 0.50 to 0.99; p=0.41) Mid-dose ibandronate: adjusted HR 1.04 (CI 0.83 to 1.30; p=0.72) Any clinical fracture: High-dose ibandronate: adjusted HR 0.73 (CI 0.56 to 0.95; p=0.19) Mid-dose ibandronate: adjusted HR 0.92 (CI 0.77 to 1.09; p=0.33) | NR | High-dose ibandronate was associated with demonstrable reductions in risk of nonvertebral and clinical fracture | Not quality assessed | Results were stratified according to accumulated exposure; High-dose includes FDA-approved 150mg/month oral and 3 mg/3 months IV; Mid-dose includes FDA- approved 2.5mg qd
MacLean et al, 2008^187^ | | To compare the benefits in fracture reduction and the harms from adverse events of various therapies for osteoporosis | CCRCT, MEDLINE, ACP Journal Club 1966–2006 | Efficacy: systematic reviews, meta-analyses, RCTs of low bone density treatments vs. placebo reporting fracture outcomes Safety: systematic reviews, RCTs and case-control or cohort studies with >1000 patients | Efficacy: 24 meta-analyses, 76 RCTs Safety: 417 RCTs, 25 controlled clinical trials, 42 observational studies, 9 case reports/case series on osteonecrosis; total number of patients not calculated | Efficacy: 24 meta-analyses, 76 RCTs Safety: 417 RCTs, 25 controlled clinical trials, 42 observational studies, 9 case reports/case series on osteonecrosis | Men or women with primary or secondary osteoporosis or low bone density | Alendronate, etidronate, ibandronate, pamidronate risedronate, zoledronic acid calcitonin, estrogen, teriparatide, raloxifene, tamoxifen, testosterone, vitamin D, calcium | Fracture reduction | -- | -- | Data are insufficient to determine relative efficacy or safety of included therapeutic agents | Fair
Vestergaard et al, 2007^185^ | | To examine the effects of parathyroid hormone (PTH) either alone or in combination with antiresorptive therapy on bone mineral density and fracture risk | CCRCT (1990–2005); MEDLINE (1951–2005); EMBASE (1974–2005); Science Citation Index (1945–2005); conference abstracts; reference lists | RCTs of PTH ≥6 months duration with fracture occurrence and/or BMD outcomes | 13 trials; total n=5,455 Greenspan 2005 (n=2,531); Lane 1998 (n=51); Body 2002 (n=146); Cosman 2001 (n=126); Neer 2001 (n=1,326); Orwoll 2003 (n=437); Finkelstein 1998 (n=43); Finkelstein 2003 (n=73); Kurland 2000 (n=23); McClung 2005 (n=203); Black 2003 (n=238); Hodsman 2003 (n=206) | RCTs; no further details on design provided Quality of included trials ranged from 2–4 pts (Jadad) | Men or women age ≥18 years with primary or secondary (i.e. corticosteroid-induced) osteoporosis | Parathyroid hormone I-34 or I-84 20–100ug qd, alone or in combination with hormone replacement therapy (2 studies), bisphosphonates (5 studies) or nafarelin (1 study) | Fracture incidence (also change in BMD) | PTH alone results (results for PTH in combination with other treatments were similar with overlapping CIs) Vertebral fracture (4 studies): RR 0.37 (CI 0.28 to 0.48; p<0.01) Non-vertebral fracture (2 studies): RR 0.62 (CI 0.46–0.82; p<0.01) | Back pain (5 studies): OR 0.68 (CI 0.53 to 0.87; p=0.09) | PTH - alone and in combination - reduced incidence of vertebral fracture and, to a lesser extent, non- vertebral fracture | Good | Results not pooled due to study heterogeneity
Wells et al, 2008^162^ Alendronate | | To assess the efficacy of alendronate in the primary and secondary prevention of osteoporotic fractures in postmenopausal women | CCRCT, MEDLINE, EMBASE 1966–2007 | RCTs at least 1 year in duration enrolling postmenopausal women comparing alendronate to placebo or calcium/vitamin D | 11 trials; total n=12,068 Ascott Evans 2003 (n=144); Cummings 1998 (n=4,432); Hosking 1998 (n=120) Black 1996 (n=2027); Bone 1997 (n=359); Chesnut 1995 (n=188); Durson 2001 (n=101); Greenspan 1998 (n=120); Greenspan 2002 (n=327); Liberman 1995 (n=994); Pols 1999 (n=1908) | 10/11 double-blind RCTs; 1/11 RCT, blinding unclear | Post-menopausal women; age 53–78 years; baseline T-score −1.0 to −4.3 | Alendronate 5–20mg qd calcium ≤500mg qd vitamin D 125–400 IU qd placebo | Fracture incidence | [underlined: Primary prevention] Vertebral fracture: RR 0.55 (CI 0.38 to 0.80; p=0.002) Non-vertebral fracture: RR 0.89 (CI 0.76 to 1.04; p=0.14) Hip fracture: RR 0.79 (CI 0.44 to 1.44; p=0.4) 5-year fracture risk (based on FRACTURE Index scores) Score 1–2: ARR 0.5%; NNT 200 Score 3–4: ARR 1.1%; NNT 91 Score 5: ARR 2.4%; NNT 42 Score 6–7: ARR 3.2%; NNT 31 Score 8–13: ARR 5/0%; NNT 20 [underlined: Secondary prevention] Vertebral fracture: RR 0.55 (CI 0.43 to 0.69; p<0.001) Non-vertebral fracture: RR 0.77 (CI 0.64 to 0.92; p=0.005) Hip fracture: RR 0.47 (CI 0.26 to 0.85; p=0.01) | No difference in tolerability or withdrawals due to AEs between alendronate and placebo/control groups with the exception of increased incidence of GI events (RR 1.03; CI 0.98 to 1.08) and esophageal ulcer (RR 1.16; CI 0.39 to 3.45) in the alendronate group; no reports of osteonecrosis | For primary prevention, clinically important reduction in vertebral fractures but not other types of fractures; secondary prevention clinically and statistically significant reduction in vertebral, non- vertebral, hip and wrist fracture | Good
Wells et al, 2008^163^ Etidronate | | To assess the efficacy of etidronate in the primary and secondary prevention of osteoporotic fractures in postmenopausal women | CCRCT, MEDLINE, EMBASE 1966–2007 | RCTs at least 1 year in duration enrolling postmenopausal women comparing oral etidronate to placebo or calcium/vitamin D | 11 RCTs; total n=1,248 Primary prevention: Herd 1997 (n=152); Meunier 1997 (n=54); Pouilles 1997 (n=109) Secondary prevention: Ishida 2004 (n=132); Lyritis 1997 (n=100); Montessori 1997 (n=80); Pacifici 1988 (n=57); Shiota 2001 (n=40); Storm 1990 (n=66); Watts 1990 (n=423); Wimalawansa 1998 (n=35) | 5/11 double blind | Postmenopausal women age 53–72 years; baseline T-score −0.8 to −4.3 | Etidronate 200–400 mg qd calcium (dose not consistently reported across included trials) placebo | Fracture incidence | [underlined: Primary prevention] Vertebral fracture: RR 3.03 (CI 0.32 to 28.44; p=0.3) Non-vertebral fracture: RR 0.56 (CI 0.20 to 1.61; p=0.3) Hip fracture: no evidence available [underlined: Secondary prevention] Vertebral fracture: RR 0.53 (CI 0.32 to 0.87; p=0.01) Non-vertebral fracture: RR 1.07 (CI 0.72 to 1.60; p=0.7) Hip fracture: RR 1.20 (CI 0.37 to 3.88; p=0.8) | Withdrawals: RR 0.91 (CI 0.71 to 1.26) Withdrawals due to AEs: RR 0.61 (CI 0.25 to 1.49) No statistically significant difference in AEs | No clinically or statistically significant reduction in fracture incidence was found with etidronate use with the exception of reducing vertebral fracture in a secondary prevention population | Good
Wells et al, 2008^161^ Risedronate | | To assess the efficacy of risedronate in the primary and secondary prevention of osteoporotic fractures in postmenopausal women | CCRCT, MEDLINE, EMBASE 1966–2007 | RCTs at least 1 year in duration enrolling postmenopausal women comparing risedronate to placebo or calcium/vitamin D | 7 RCTs; total n=14,049 Hooper 2005 (n=381); Mortensen 1998 (n=111); Clemmesen 1997 (n=132; trial excluded from analysis due to study design); Fogelman 2000 (n=541); Harris 1999 (n=2,458); McClung 2001 (n=9,331); Reginster 2000 (n=1,222) | All double-blind studies | Postmenopausal women, age 51–78 years; baseline T-score −0.4 to 3.7 | Risedronate 2.5; 5 mg qd cyclical risedronate 2.5; 5 mg qd calcium 1000 mg qd vitamin D 500 IU qd placebo | Fracture incidence | [underlined: Primary prevention] Vertebral fracture: RR 0.97 (CI 0.42 to 2.25; p=0.94) Non-vertebral fracture: RR 0.81 (CI 0.25 to 2.58; p=0.72) Hip fracture: inadequate evidence [underlined: Secondary prevention] Vertebral fracture: RR 0.61 (CI 0.5 to 0.76; p<0.001) Non-vertebral fracture: RR 0.80 (CI 0.72 to 0.90; p=0.0002) Hip fracture: RR 0.75 (CI 0.59 to 0.94; p=0.01) | Withdrawals (5 trials): RR 0.96 (CI 0.91 to 1.00) Withdrawals due to AEs (5 trials): RR 0.96 (CI 0.88 to 1.05) Adverse events - any upper GI event: RR 1.01 (CI 0.94 to 1.09) Other specific AEs not pooled, reported as generally no difference between risedronate and placebo | [underlined: Primary prevention] Vertebral fracture: RR 0.97 (CI 0.42 to 2.25; p=0.94) Non-vertebral fracture: RR 0.81 (CI 0.25 to 2.58; p=0.72) Hip fracture: inadequate evidence [underlined: Secondary prevention] Vertebral fracture: RR 0.61 (CI 0.5 to 0.76; p<0.001) Non-vertebral fracture: RR 0.80 (CI 0.72 to 0.90; p=0.0002) Hip fracture: RR 0.75 (CI 0.59 to 0.94; p=0.01) | Withdrawals (5 trials): RR 0.96 (CI 0.91 to 1.00) Withdrawals due to AEs (5 trials): RR 0.96 (CI 0.88 to 1.05) Adverse events - any upper GI event: RR 1.01 (CI 0.94 to 1.09) Other specific AEs not pooled, reported as generally no difference between risedronate and placebo | [underlined: Primary prevention] Vertebral fracture: RR 0.97 (CI 0.42 to 2.25; p=0.94) Non-vertebral fracture: RR 0.81 (CI 0.25 to 2.58; p=0.72) Hip fracture: inadequate evidence [underlined: Secondary prevention] Vertebral fracture: RR 0.61 (CI 0.5 to 0.76; p<0.001) Non-vertebral fracture: RR 0.80 (CI 0.72 to 0.90; p=0.0002) Hip fracture: RR 0.75 (CI 0.59 to 0.94; p=0.01)
Men
Sawka et al, 2005^164^ | To systematically review the anti-fracture efficacy of alendronate in men with low bone mass or with a history of prevalent fracture and incorporate prior knowledge of alendronate efficacy in women in the analysis | | CCRCT (through 2004), MEDLINE (1966–2004), EMBASE (1996–2004) | RCTs of alendronate with men comprising at least half of the study population with ≤1 year follow-up reporting fracture outcomes | 2 trials; total n=375 Orwoll 2000 (n=241); Ringe 2004 (n=134) | RCTs; one double-blind (Orwoll), one open-label (Ringe) | Mean age 63 years Baseline T-score −1.0 to −2.0 | Alendronate 10 mg qd calcium/vitamin D alfacalcidiol | Fracture incidence | Vertebral fracture: OR 0.36 (CI 0.17 to 0.77) Non-vertebral fracture: OR 0.73 (CI 0.32 to 1.67) Bayesian random effects model (incorporating data from women) Vertebral fracture: OR 0.44 (CRI 0.23 to 0.83) Nonvertebral fracture: OR 0.60 (CRI 0.29 to 1.44) | NR | Vertebral fracture: OR 0.36 (CI 0.17 to 0.77) Non-vertebral fracture: OR 0.73 (CI 0.32 to 1.67) Bayesian random effects model (incorporating data from women) Vertebral fracture: OR 0.44 (CRI 0.23 to 0.83) Nonvertebral fracture: OR 0.60 (CRI 0.29 to 1.44) | NR | Vertebral fracture: OR 0.36 (CI 0.17 to 0.77) Non-vertebral fracture: OR 0.73 (CI 0.32 to 1.67) Bayesian random effects model (incorporating data from women) Vertebral fracture: OR 0.44 (CRI 0.23 to 0.83) Nonvertebral fracture: OR 0.60 (CRI 0.29 to 1.44)
Tracz et al, 2006^186^ | To estimate the effect of testosterone use on bone health outcomes | | CCRCT (through 2005), MEDLINE (1966–2005), EMBASE (1988–2005), reference lists, content expert files | RCTs of testosterone versus placebo reporting fractures as or BMD as an outcome | 8 trials; total n=388 Amory 2004 (n=48); Crawford 2003 (n=34); Fairfield 2001 (n=50); Hall 1996 (n=30); Kenny 2001 (n=67); Reid 1996 (n=16); Snyder 1999 (n=108) | RCTs; 7/8 studies blinded (know or presumed); 1 crossover study | Mean age 60–75 years in 6 trials; <60 years in 2 trials | Testosterone 200–250mg qd or 2.5mg patch placebo | Fracture incidence (and change in BMD) | No studies reported on fracture outcomes | NR | No studies reported on fracture outcomes | NR | No studies reported on fracture outcomes

Abbreviations: AE = adverse effects; ARR = absolute risk reduction; BMD = bone mineral density; CI = confidence interval; CRI = corresponding credibility interval; GI = gastro-intestinal; HR = heart rate; NNT = number needed to treat; NR = not reported; OR = odds ratio; PTH = parathyroid hormone; RR = relative risk; RCT = randomized controlled trial.

Appendix Table D8 Quality Ratings of Systematic Reviews

Study, Year | Search dates | Search methods reported | Comprehensive search | Inclusion criteria reported | Selection bias avoided | Validity criteria reported | Validity assessed appropriately | Methods used to combine studies reported | Findings combined appropriately | Conclusions supported by data | Quality score
Cranney et al, 2002^176^ | MEDLINE, EMBASE 1966–2000; conference abstracts, FDA proceedings | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
MacLean et al, 2008^187^ | CCRCT, MEDLINE, ACP Journal Club 1966–2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Partial | Partial | Fair
Vestergaard et al, 2007^185^ | CCRCT (1990–2005); MEDLINE (1951–2005); EMBASE (1974–2005); Science Citation Index (1945–2005); conference abstracts; reference lists | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Wells et al, 2008^162^ | CCRCT, MEDLINE, EMBASE 1966–2007 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Alendronate
Wells et al, 2008^163^ | CCRCT, MEDLINE, EMBASE 1966–2007 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Etidronate
Wells et al, 2007^161^ | CCRCT, MEDLINE, EMBASE 1966–2007 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Risedronate
Men
Sawka et al, 2005^164^ | CCRCT (through 2004), MEDLINE (1966–2004), EMBASE (1996–2004) | Yes | Yes | Yes | Yes | No | Can't tell | Yes | Yes | Yes | Fair
Tracz et al, 2006^186^ | CCRCT (through 2005), MEDLINE (1966–2005), EMBASE (1988–2005), reference lists, content expert files | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

Note: Harris et al, 2008 is a meta-analysis of individual patient data, and therefore is not assessed for quality.