# Appendix Figures

Appendix Figure C1 Vertebral Fractures: Primary Prevention Trials of Bisphosphonate vs. Placebo

Appendix Figure C2 Total Nonvertebral Fractures: Primary Prevention Trials of Bisphosphonate vs. Placebo

Appendix Figure C3 Total Fracture: Primary Prevention Trials of Bisphosphonate vs. Placebo

Appendix Figure C4 Hip Fractures: Primary Prevention Trials

Appendix Figure C5 Wrist Fractures: Primary Prevention Trials of Bisphosphonate vs. Placebo

Appendix Figure C6 Ankle Fractures: Primary Prevention Trials of Bisphosphonate vs. Placebo

Appendix Figure C7 Vertebral Fractures: Sensitivity Analysis Including Additional Primary Prevention Trials of Bisphosphonate vs. Placebo

Appendix Figure C8 Hip Fracture: Sensitivity Analysis Including Additional Primary Prevention Trials of Bisphosphonate vs. Placebo

Appendix Figure C9 Total Nonvertebral Fractures: Sensitivity Analysis Including Additional Primary Prevention Trials of Bisphosphonate vs. Placebo

Appendix Figure C10 Vertebral Fracture: Bisphosphonate vs. Placebo, Stratified by Baseline BMD

Appendix Figure C11 Nonvertebral Fracture: Bisphosphonate vs. Placebo, Stratified by Baseline BMD

Appendix Figure C12 Vertebral Fractures: Primary and Secondary Trials of Alendronate vs. Placebo in Men

Appendix Figure C13 Total Nonvertebral Fractures: Primary and Secondary Prevention Trials of Alendronate vs. Placebo in Men

Appendix Figure C14 Vertebral Fractures: Primary and Secondary Prevention Trials of Parathyroid Hormone vs. Placebo in Women

Appendix Figure C15 Total Nonvertebral Fractures: Primary and Secondary Prevention Trials of Parathyroid Hormone vs. Placebo in Women