# Detailed Methods

## Appendix B1 Search Strategies

### Screening

Database: Ovid MEDLINE; Cochrane Central Register of Controlled Trials

1 | exp Osteoporosis/di, ra, ri, us
2 | exp Osteoporosis/
3 | exp Mass Screening/
4 | screen$.mp.
5 | 2 and 3
6 | 1 and 5
7 | 5 or 6
8 | Bone Density/
9 | 8 and (3 or 4)
10 | 7 or 9
11 | exp Fractures, Bone/
12 | fractur$.mp.
13 | exp “Bone and Bones”/
14 | 12 and 13
15 | 11 or 14
16 | 10 and 15
17 | limit 16 to English language
18 | limit 16 to abstracts
19 | 17 or 18

Database: Cochrane Database of Systematic Reviews

1 | osteoporo$.mp. or bone densit$.ti,ab.
2 | screen$.ti,ab.
3 | 1 and 2

### Screening Interval

Database: Ovid MEDLINE; Cochrane Central Register of Controlled Trials

1 | exp Osteoporosis, Postmenopausal/or exp Osteoporosis/or osteoporosis.mp.
2 | bone density.mp. or exp Bone Density/
3 | densit$.mp.
4 | (low adj2 bone).mp.
5 | 3 and 4
6 | osteopeni$.mp.
7 | 1 or 2 or 5 or 6
8 | screen$.mp. or exp Mass Screening/
9 | test$.mp.
10 | 8 or 9
11 | 7 and 10
12 | interval.mp.
13 | 11 and 12
14 | limit 13 to (“middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”)

### Risk

Database: Ovid MEDLINE; Cochrane Central Register of Controlled Trials

1 | exp Osteoporosis/
2 | exp Bone Density/
3 | 1 or 2
4 | exp risk/
5 | 3 and 4
6 | exp Cohort Studies/
7 | exp Meta-Analysis/
8 | exp case-control studies/
9 | exp “Sensitivity and Specificity”/
10 | Evidence-Based Medicine/
11 | 6 or 7 or 8 or 9 or 10
12 | 5 and 11
13 | limit 12 to humans
14 | limit 13 to English language
15 | limit 13 to abstracts
16 | 14 or 15

Database: Cochrane Database of Systematic Reviews

1 | osteoporo$.mp.
2 | bone densit$.mp.
3 | osteopeni$.mp.
4 | 1 or 2 or 3
5 | risk$.mp.
6 | 4 and 5
7 | (woman or women$ or female).mp.
8 | (man or men$ or male).mp.
9 | 7 or 8
10 | 6 and 9
11 | (child$ or adolescen$).
12 | 10 not 11

### Testing

Database: Ovid MEDLINE; Cochrane Central Register of Controlled Trials

1 | exp Osteoporosis/
2 | exp Calcaneus/us
3 | exp Bone Density/
4 | 1 or 2 or 3
5 | exp Ultrasonography/
6 | dxa.mp.
7 | dexa.mp.
8 | sxa.mp.
9 | bua.mp.
10 | qct.mp.
11 | exp Tomography, X-Ray Computed/
12 | quantitat$.mp.
13 | 11 and 12
14 | densitometry/or absorptiometry, photon/
15 | qus.mp.
16 | mxa.mp.
17 | mrx.mp.
18 | ra.mp.
19 | dip.mp.
20 | sos.mp.
21 | ubps.mp.
22 | spa.mp.
23 | dpa.mp.
24 | or/5–10
25 | or/13–23
26 | 24 or 25
27 | 4 and 26
28 | limit 27 to humans
29 | limit 28 to english language
30 | limit 28 to abstracts
31 | 29 or 30
32 | meta-analysis.mp. or exp Meta-Analysis/
33 | (cochrane or medline).tw.
34 | search$.tw.
35 | 32 or 33 or 34
36 | “Review Literature as Topic”/or systematic review.mp.
37 | 35 or 36
38 | 31 and 37
39 | randomized controlled trial.mp. or exp Randomized Controlled Trial/
40 | randomized controlled trial.pt.
41 | controlled clinical trial.mp. or exp Controlled Clinical Trial/
42 | controlled clinical trial.pt.
43 | clinical trial.mp. or exp Clinical Trial/
44 | clinical trial.pt.
45 | or/39–44
46 | limit 45 to humans
47 | 31 and 46
48 | 38 or 47

Database: Cochrane Database of Systematic Reviews

1 | dxa.mp.
2 | dexa.mp.
3 | sxa.mp.
4 | bua.mp.
5 | qct.mp.
6 | qus.mp.
7 | mxa.mp.
8 | mrx.mp.
9 | ra.mp.
10 | dip.mp.
11 | sos.mp.
12 | ubps.mp.
13 | spa.mp.
14 | dpa.mp.
15 | osteoporo$.mp.
16 | bone densit$.mp.
17 | calcaneus.mp.
18 | ultrasonograph$.mp.
19 | ultrasound.mp.
20 | tomograph$.mp.
21 | quantitativ$.mp.
22 | 20 and 21
23 | or/1–14
24 | or/17–19
25 | or/22–24
26 | 15 or 16
27 | 25 and 26

### Testing in Men

Database: Ovid MEDLINE; Cochrane Central Register of Controlled Trials

1 | exp Osteoporosis/
2 | exp Calcaneus/us
3 | exp Bone Density/
4 | 1 or 2 or 3
5 | exp Ultrasonography/
6 | dxa.mp.
7 | dexa.mp.
8 | sxa.mp.
9 | bua.mp.
10 | qct.mp.
11 | exp Tomography, X-Ray Computed/
12 | quantitat$.mp.
13 | 11 and 12
14 | densitometry/or absorptiometry, photon/
15 | qus.mp.
16 | mxa.mp.
17 | mrx.mp.
18 | ra.mp.
19 | dip.mp.
20 | sos.mp.
21 | ubps.mp.
22 | spa.mp.
23 | dpa.mp.
24 | or/5–10
25 | or/13–23
26 | 24 or 25
27 | 4 and 26
28 | limit 27 to humans
29 | limit 28 to English language
30 | limit 28 to abstracts
31 | 29 or 30
32 | (men or male).ti.
33 | 31 and 32
34 | (female or woman or women).mp.
35 | 33 not 34
36 | from 35 keep 1–305

### Treatment

Bisphosphonates

Database: Ovid MEDLINE (Systematic Reviews)

1 | meta-analysis.mp. or exp Meta-Analysis/
2 | (cochrane or medline).tw.
3 | search$.tw.
4 | 1 or 2 or 3
5 | “Review Literature as Topic”/or systematic review.mp.
6 | 4 or 5
7 | exp Diphosphonates/
8 | (alendronate or risedronate or etidronate or ibandronate or pamidronate or zoledronic acid).mp.
9 | 7 or 8
10 | exp Osteoporosis/
11 | exp Bone Density/
12 | 10 or 11
13 | 9 and 12
14 | limit 13 to humans
15 | limit 14 to English language
16 | limit 14 to abstracts
17 | 15 or 16
18 | 6 and 17

Database: Ovid MEDLINE (Trials); Cochrane Central Register of Controlled Trials

1 | exp Diphosphonates/
2 | (alendronate or risedronate or etidronate or ibandronate or pamidronate or zoledronic acid).mp.
3 | 1 or 2
4 | exp Osteoporosis/
5 | exp Bone Density/
6 | 4 or 5
7 | 3 and 6
8 | limit 7 to humans
9 | limit 8 to english language
10 | limit 8 to abstracts
11 | 9 or 10
12 | randomized controlled trial.mp. or exp Randomized Controlled Trial/
13 | randomized controlled trial.pt.
14 | controlled clinical trial.mp. or exp Controlled Clinical Trial/
15 | controlled clinical trial.pt.
16 | clinical trial.mp. or exp Clinical Trial/
17 | clinical trial.pt.
18 | or/12–17
19 | limit 18 to humans
20 | 11 and 19

Database: Cochrane Database of Systematic Reviews

1 | bisphosphonates.mp.
2 | diphosphonates.mp.
3 | (alendronate or risedronate or etidronate or pamidronate or zoledronic acid).mp.
4 | 1 or 2 or 3
5 | osteoporo$.mp.
6 | osteopen$.mp.
7 | bone densit$.mp.
8 | 5 or 6 or 7
9 | 4 and 8

### Bisphosphonates – Adverse Effects

Database: Ovid MEDLINE

1 | osteoporosis.mp.
2 | bone densit$.mp.
3 | 1 or 2
4 | (alendronate or risendronate or etidronate or ibandronate or pamidronate or zoledronic acid).mp.
5 | diphosphonate$.mp.
6 | bisphosphonate$.mp.
7 | or/4–6
8 | (harm$ or safety or adverse).mp.
9 | 7 and 8
10 | 3 and 9

### Calcitonin

Database: Ovid MEDLINE (systematic reviews)

1 | meta-analysis.mp. or exp Meta-Analysis/
2 | (cochrane or medline).tw.
3 | search$.tw.
4 | 1 or 2 or 3
5 | “Review Literature as Topic”/or systematic review.mp.
6 | 4 or 5
7 | exp Calcitonin/ad, ae, ct, tu, to
8 | exp Osteoporosis/
9 | exp Bone Density/
10 | 7 and (8 or 9)
11 | limit 10 to humans
12 | limit 11 to English language
13 | limit 11 to abstracts
14 | 6 and 13
15 | meta-analysis.mp. or exp Meta-Analysis/
16 | (cochrane or medline).tw.
17 | search$.tw.
18 | 15 or 16 or 17

Database: Ovid MEDLINE (Trials); Cochrane Central Register of Controlled Trials

1 | exp Calcitonin/ad, ae, ct, tu, to
2 | exp Osteoporosis/
3 | exp Bone Density/
4 | 1 and (2 or 3)
5 | limit 4 to humans
6 | limit 5 to english language
7 | limit 5 to abstracts
8 | randomized controlled trial.mp. or exp Randomized Controlled Trial/
9 | randomized controlled trial.pt.
10 | controlled clinical trial.mp. or exp Controlled Clinical Trial/
11 | controlled clinical trial.pt.
12 | clinical trial.mp. or exp Clinical Trial/
13 | clinical trial.pt.
14 | or/8–13
15 | limit 14 to humans
16 | 7 and 15

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 | calcitonin.mp.
2 | osteoporo$.mp.
3 | osteopen$.mp.
4 | bone densit$.mp.
5 | 2 or 3 or 4
6 | 1 and 5

### Estrogen

Database: Ovid MEDLINE (systematic reviews)

1 | meta-analysis.mp. or exp Meta-Analysis/
2 | (cochrane or medline).tw.
3 | search$.tw.
4 | 1 or 2 or 3
5 | “Review Literature as Topic”/or systematic review.mp.
6 | 4 or 5
7 | exp Hormone Replacement Therapy/
8 | exp Estrogens/ad, ae, ct, tu, to
9 | exp Estradiol Congeners/ad, ae, ct, tu, to
10 | (replac$ adj5 (estrogen$ or hormon$)).mp.
11 | 7 or 8 or 9 or 10
12 | exp Osteoporosis/
13 | exp Bone Density/
14 | exp Fractures, Bone/
15 | fractur$.mp.
16 | 12 or 13 or 14 or 15
17 | 11 and 16
18 | limit 17 to humans
19 | limit 18 to English language
20 | limit 18 to abstracts
21 | 19 or 20
22 | 6 and 21

Database: Ovid MEDLINE (Trials); Cochrane Central Register of Controlled Trials

1 | exp Hormone Replacement Therapy/
2 | exp Estrogens/ad, ae, ct, tu, to
3 | exp Estradiol Congeners/ad, ae, ct, tu, to
4 | (replac$ adj5 (estrogen$ or hormon$)).mp.
5 | 1 or 2 or 3 or 4
6 | exp Osteoporosis/
7 | exp Bone Density/
8 | exp Fractures, Bone/
9 | fractur$.mp.
10 | 6 or 7 or 8 or 9
11 | 5 and 10
12 | limit 11 to humans
13 | limit 12 to english language
14 | limit 12 to abstracts
15 | 13 or 14
16 | randomized controlled trial.mp. or exp Randomized Controlled Trial/
17 | randomized controlled trial.pt.
18 | controlled clinical trial.mp. or exp Controlled Clinical Trial/
19 | controlled clinical trial.pt.
20 | clinical trial.mp. or exp Clinical Trial/
21 | clinical trial.pt.
22 | or/16–21
23 | limit 22 to humans
24 | 15 and 23

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 | hormone replacement therapy.mp.
2 | estradiol.mp.
3 | estrogen$.mp.
4 | (replac$ adj5 (estrogen$ or hormon$)).mp.
5 | 1 or 2 or 3 or 4
6 | osteoporo$.mp.
7 | osteopen$.mp.
8 | bone densit$.mp.
9 | 6 or 7 or 8
10 | 5 and 9

### Parathyroid Hormone

Database: Ovid MEDLINE (systematic reviews)

1 | meta-analysis.mp. or exp Meta-Analysis/
2 | (cochrane or medline).tw.
3 | search$.tw.
4 | 1 or 2 or 3
5 | “Review Literature as Topic”/or systematic review.mp.
6 | 4 or 5
7 | exp Parathyroid Hormone/ad, ae, tu, to
8 | exp Osteoporosis/
9 | exp Bone Density/
10 | 7 and (8 or 9)
11 | limit 10 to humans
12 | limit 11 to English language
13 | limit 11 to abstracts
14 | 12 or 13
15 | 6 and 14

Database: Ovid MEDLINE (Trials); Cochrane Central Register of Controlled Trials

1 | exp Parathyroid Hormone/ad, ae, tu, to
2 | exp Osteoporosis/
3 | exp Bone Density/
4 | 1 and (2 or 3)
5 | limit 4 to humans
6 | limit 5 to english language
7 | limit 5 to abstracts
8 | 6 or 7
9 | randomized controlled trial.mp. or exp Randomized Controlled Trial/
10 | randomized controlled trial.pt.
11 | controlled clinical trial.mp. or exp Controlled Clinical Trial/
12 | controlled clinical trial.pt.
13 | clinical trial.mp. or exp Clinical Trial/
14 | clinical trial.pt.
15 | or/9–14
16 | limit 15 to humans
17 | 8 and 16

Database: Cochrane Database of Systematic Reviews

1 | parathyroid$.mp.
2 | hormon$.mp.
3 | pth.mp.
4 | (1 and 2) or 3
5 | osteoporo$.mp.
6 | osteopen$.mp.
7 | bone densit$.mp.
8 | 5 or 6 or 7
9 | 4 and 8
10 | from 9 keep 1–14
11 | limit 10 to recently updated reviews
12 | limit 10 to new reviews
13 | 11 or 12

### SERMs

Database: Ovid MEDLINE

1 | tamoxifen.mp. or exp Tamoxifen/
2 | raloxifene.mp. or exp Raloxifene/
3 | 1 or 2
4 | bone density.mp. or exp Bone Density/
5 | exp Osteoporosis/or osteoporosis.mp.
6 | fractur$.mp.
7 | exp Fractures, Bone/
8 | exp Hormone Replacement Therapy/
9 | (replac$ adj5 (hormon$ or estrogen$)).mp.
10 | 4 or 5 or 6 or 7 or 8 or 9
11 | 3 and 10
12 | exp breast neoplasms/
13 | 11 not 12
14 | limit 13 to humans
15 | limit 14 to English language
16 | limit 14 to abstracts
17 | 15 or 16

### Testosterone

Database: Ovid MEDLINE (systematic reviews)

1 | meta-analysis.mp. or exp Meta-Analysis/
2 | (cochrane or medline).tw.
3 | search$.tw.
4 | 1 or 2 or 3
5 | “Review Literature as Topic”/or systematic review.mp.
6 | 4 or 5
7 | exp Osteoporosis/
8 | exp Bone Density/
9 | 7 or 8
10 | exp Testosterone/ad, ae, ct, tu, to
11 | 9 and 10
12 | exp Testosterone Congeners/ad, ae, tu, ct, to
13 | 9 and 12
14 | 11 or 13
15 | limit 14 to humans
16 | limit 15 to English language
17 | limit 15 to abstracts
18 | 16 or 17
19 | 6 and 18
20 | from 19 keep 1–5

Database: Ovid MEDLINE (Trials); Cochrane Central Register of Controlled Trials

1 | exp Osteoporosis/
2 | exp Bone Density/
3 | 1 or 2
4 | exp Testosterone/ad, ae, ct, tu, to
5 | 3 and 4
6 | exp Testosterone Congeners/ad, ae, tu, ct, to
7 | 3 and 6
8 | 5 or 7
9 | limit 8 to humans
10 | limit 9 to english language
11 | limit 9 to abstracts
12 | 10 or 11
13 | randomized controlled trial.mp. or exp Randomized Controlled Trial/
14 | randomized controlled trial.pt.
15 | controlled clinical trial.mp. or exp Controlled Clinical Trial/
16 | controlled clinical trial.pt.
17 | clinical trial.mp. or exp Clinical Trial/
18 | clinical trial.pt.
19 | or/13–18
20 | limit 19 to humans
21 | 12 and 20

Database: Cochrane Database of Systematic Reviews

1 | testosterone.mp.
2 | osteoporo$.mp.
3 | osteopen$.mp.
4 | bone densit$.mp.
5 | 2 or 3 or 4
6 | 1 and 5

## Appendix B2 Inclusion and Exclusion Criteria for Each Key Question

### Key Question 1 Screening

Include

Paper addresses Key Question 1 and

- includes osteoporosis and low bone density
- limited to fracture outcomes

Exclude

Reason: | Details:
Paper may be relevant to background and context, but does not meet inclusion criteria
Wrong population | Premenopausal women, men <50, not applicable to U.S. population, have secondary causes of osteoporosis, already on treatment medications
Wrong intervention | Screening with technology not used in the U.S., screening with risk factors not applicable to the U.S.
Wrong outcomes | Not validated fractures, fracture-related morbidity, or fracture-related mortality
Wrong study design | Not randomized controlled trial or nonrandomized comparison
Wrong publication type | Review article, letter, editorial, results reported elsewhere, no original data
Non-English language
Not human population
Methodological issues not included in other exclusion criteria
Systematic review before the year 2002

### Key Question 2 Risk

Include

Paper addresses Key Question 2 and

- limited to risk assessment instruments

Exclude

Reason: | Details:
Paper may be relevant to background and context, but does not meet inclusion criteria
Wrong population | Not comparable or applicable to U.S. adult population
Wrong intervention | Not an evaluation of a risk assessment tool
Wrong outcomes | Evaluation of single risk factor
Wrong study design | For example, assessment of risk factors by regression analysis of a population
Wrong publication type | Review article, letter, editorial, results reported elsewhere, no original data
Non-English language
Not human population
Methodological issue not included in other exclusion criteria
Systematic review before the year 2002

### Key Question 3 Testing

Include

Paper addresses Key Question 3 and

- must be applicable to U.S. technologies (e.g., DXA or peripheral bone measurement tests)

Exclude

Reason: | Details:
Paper may be relevant to background and context, but does not meet inclusion criteria
Wrong population | KQ3a: women or men <50, not applicable to U.S. population, have secondary causes of osteoporosis, already on treatment medications KQ3b and KQ3c: premenopausal women, men <50, not applicable to U.S. population, have secondary causes of osteoporosis, already on treatment medications
Wrong intervention | Screening with technology not used in the U.S.
Wrong outcomes | KQ3a and KQ3b: not validated fractures
Wrong study design | Not diagnostic test study
Wrong publication type | Review article, letter, editorial, results reported elsewhere, no original data
Non-English language
Not human population
Methodological issue not included in other exclusion criteria
Systematic review before the year 2002

### Key Question 4 Harms of Screening

Include

Paper addresses Key Question 4 and

- any study design

Exclude

Reason: | Details:
Paper may be relevant to background and context, but does not meet inclusion criteria
Wrong population
Wrong intervention
Wrong outcomes
Wrong study design
Wrong publication type | Review article, letter, editorial, results reported elsewhere, no original data
Non-English language but otherwise relevant
Not human population
Methodological issue not included in other exclusion criteria
Systematic review before the year 2002

### Key Question 5 Treatment

Include

Paper addresses Key Question 5 and

- limited to systematic evidence reviews of RCTs
- limited to RCTs of drug therapies

Exclude

Reason: | Details:
Paper may be relevant to background and context, but does not meet inclusion criteria
Wrong population
Wrong intervention | Drug not currently in use in the U.S.
Wrong outcomes | Not fracture or fracture-related morbidity or mortality
Wrong study design | Not randomized controlled trial or systematic review of randomized controlled trials
Wrong publication type | Review article, letter, editorial, results reported elsewhere, no original data
Non-English language but otherwise relevant
Not human population
Methodological issue not included in other exclusion criteria
Systematic review before the year 2002

### Key Question 6 Harms of Treatment

Include

Paper addresses Key Question 6 and

- any study design
- limited to drug therapies

Exclude

Reason: | Details:
Paper may be relevant to background and context, but does not meet inclusion criteria
Wrong population
Wrong intervention
Wrong outcomes
Wrong study design
Wrong publication type | Review article, letter, editorial, results reported elsewhere, no original data
Non-English language but otherwise relevant
Not human population
Methodological issue not included in other exclusion criteria
Systematic review before the year 2002

## Appendix B3 Article Flow by Key Question

Abbreviations: AUC = area under the curve; MA = meta-analysis; ROC = receiver operating characteristic; SR = systematic review.

*Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

†Identified from reference lists, suggested by experts, etc.

‡ Some articles were included for more than one key question.

§Subset of 64 total articles describing risk assessment instruments.

## Appendix B4 Excluded Studies

### Wrong population

1 Chan SP, Teo CC, Ng SA, Goh N, Tan C, Deurenberg-Yap M. Validation of various osteoporosis risk indices in elderly Chinese females in Singapore. Osteoporos Int. 2006;17(8):1182-1188. [pmid: 16699739].
2 Chesnut CH, Silverman S, Andriano K, et al. A randomized trial of nasal spray salmon calcitonin in postmenopausal women with established osteoporosis: the Prevent Recurrence of Osteoporotic Fractures Study. Am J Med. 2000;109(4):267-276. [pmid: 10996576].
3 Coco M, Glicklich D, Faugere MC, et al. Prevention of bone loss in renal transplant recipients: a prospective, randomized trial of intravenous pamidronate. J Am Soc Nephrol. 2003;14(10):2669-2676. [pmid: 14514747].
4 Delmas P, Recker R, Chesnut C, et al. Daily and intermittent oral ibandronate normalize bone turnover and provide significant reduction in vertevral fracture risk: results from the BONE Study. Osteoporos Int. 2004;15:792-798. [pmid: 15071723].
5 Gafni RI, Baron JM. Overdiagnosis of osteoporosis in children due to misinterpretation of dual-energy x-ray absorptionmetry (DXA). J Pediat. 2004;144(2):253-257. [pmid: 14760271].
6 Gallagher JC, Genant HK, Crans GG, Vargas SJ, Krege JH. Teriparatide reduces the Fracture Risk Associated with Increasing Number and Severity of Osteoporotic Fractures. J Clin Endocrinol Metab. 2005;90(3):1583-1587. [pmid: 15613428].
7 Koh LK, Sedrine WB, Torralba TP, et al. A simple tool to identify Asian women at increased risk of osteoporosis. Osteoporos Int. 2001;12(8):699-705. [pmid: 11580084].
8 Kung AW, Ho AY, Ross PD, Reginster JY. Development of a clinical assessment tool in identifying Asian men with low bone mineral density and comparison of its usefulness to quantitative bone ultrasound. Osteoporos Int. 2005;16(7):849-855. [pmid: 15611839].
9 Lerttrakul S, Soontrapa S. Modified OSTA index for referring women for DEXA measurement. J Med Assoc Thai. 2005;88(Suppl 5):S80-83. [pmid: 16871660].
10 Lynn HS, Lau EM, Wong SY, Hong AW. An osteoporosis screening tool for Chinese men. Osteoporos Int. 2005;16(7):829-834. [pmid: 15536535].
11 Mackey DC, Lui L-Y, Cawthon PM, et al. High-trauma fractures and low bone mineral density in older women and men. JAMA. 2007;298(20):2381-2388. [pmid: 18042915].
12 Martin A, Bojinc M, Milicescu M, et al. A Romanian instrument to facilitate bone density measurement indication in postmenopausal women. Rom J Intern Med. 2004;42(4):695-708. [pmid: 16366141].
13 Ninkovic M, Love S, Tom BDM, Bearcroft PWP, Alexander GJM, Compston JE. Lack of effect of intravenous pamidronate on fracture incidence and bone mineral density after orthotopic liver transplantation. Journal of Hepatology. 2002;37(1):93-100. [pmid: 12076867].
14 Papaioannou A, Parkinson W, Ferko N, et al. Prevalence of vertebral fractures among patients with chronic obstructive pulmonary disease in Canada. Osteoporos Int. 2003;14(11):913-917. [pmid: 14551675].
15 Park HM, Sedrine WB, Reginster JY, Ross PD. Korean experience with the OSTA risk index for osteoporosis: a validation study. J Clin Densitom. 2003;6(3):247-250. [pmid: 14514994].
16 Pongchaiyakul C, Nguyen ND, Eisman JA, Nguyen TV. Clinical risk indices, prediction of osteoporosis, and prevention of fractures: diagnostic consequences and costs. Osteoporos Int. 2005;16(11):1444-1450. [pmid: 16170443].
17 Pongchaiyakul C, Wanothayaroj E. Performance of the Khon Kaen Osteoporosis Study (KKOS) score for identifying osteoporosis in men. J Med Assoc Thai. 2007;90(8):1518-1523. [pmid: 17926979].
18 Quandt SA, Thompson D, Schneider DL, Nevitt M, Black D. Effect of Alendronate on vertebral fracture risk in women with bone mineral density T-scores of −1.6 to −2.5 at the femoral neck: The Fracture Intervention Trial. Mayo Clin Proc. 2005;80(3):343-349. [pmid: 15757015].
19 Sen SS, Rives VP, Messina OD, et al. A risk assessment tool (OsteoRisk) for identifying Latin American women with osteoporosis. J Gen Intern Med. 2005;20(3):245-250. [pmid: 15836528].
20 Sorensen OH, Crawford GM, Mulder H, et al. Long-term efficacy of risedronate: a 5-year placebo-controlled clinical experience. Bone. 2003;32(2):120-126. [pmid: 12633783].
21 Kung AWC, Pasion EG, Sofiyan M, et al. A comparison of teriparatide and calcitonin therapy in postmenopausal Asian women with osteoporosis: a 6-month study. Curr Med Res Opin. 2006;22:929-937. [pmid: 16709314].
22 Watts NB, Chines A, Olszynski WP, et al. Fracture risk remains reduced one year after discontinuation of risedronate. Osteoporos Int. 2008;19(3):365-372. [pmid: 17938986].

### Wrong intervention

1 Bachman DM, Crewson PE, Lewis RS. Comparison of heel ultrasound and finger DXA to central DXA in the detection of osteoporosis: Implications for patient management. J Clin Densitom. 2002;5(2):131-141. [pmid: 12110756].
2 Bach-Mortensen P, Hyldstrup L, Appleyard M, Hindso K, Gebuhr P, Sonne-Holm S. Digital x-ray radiogrammetry identifies women at risk of osteoporotic fracture: results from a prospective study. Calcif Tissue Int. 2006;79(1):1-6. [pmid: 16868669].
3 Farrugia MC, Summerlin DJ, Krowiak E, et al. Osteonecrosis of the mandible or maxilla associated with the use of new generation bisphosphonates. Laryngoscope. 2006;116(1):115-120. [pmid: 16481822].
4 Gill TM, Baker DI, Gottschalk M, Peduzzi PN, Allore H, Byers A. A program to prevent functional decline in physically frail, elderly persons who live at home. New Engl J Med. 2002;347(14):1068-1074. [pmid: 12362007].
5 Hill JA, Goldin JG, Gjertson D, et al. Progression of coronary artery calcification in patients taking alendronate for osteoporosis. Acad Radiol. 2002;9(10):1148-1152. [pmid: 12385509].
6 Leibson CL, Tosteson ANA, Gabriel SE, Ransom JE, Melton LJ. Mortality, disability, and nursing home use for persons with and without hip fracture: a population-based study. J Am Geriatr Soc. 2002;50(10):1644-1650. [pmid: 12366617].
7 Ofluoglu D, Gunduz OH, Bekirolu N, Kul-Panza E, Akyuz G. A method for determining the grade of osteoporosis based on risk factors in postmenopausal women. Clin Rheumatol. 2005;24(6):606-611. [pmid: 16010446].
8 Papadimitropoulos E, Wells G, Shea B, et al. VIII: Meta-analysis of the efficacy of vitamin D treatment in preventing osteoporosis in postmenopausal women. Endocr Rev. 2002;23(4):560-569. [pmid: 12202471].
9 Richy F, Schacht E, Bruyere O, Ethgen O, Gourlay M, Reginster JY. Vitamin D analogs versus native vitamin D in preventing bone loss and osteoporosis-related fractures: A comparative meta-analysis. Calcif Tissue Int. 2005;76(3):176-186. [pmid: 15692726].

### Wrong outcome

1 Link between osteoporosis drugs, jaw infection reported. J Am Dent Assoc. 2008;139(7):894. [pmid: 18594074].
2 Ardawi MSM, Maimany AA, Bahksh TM, Nasrat HAN, Milaat WA, Al-Raddadi RM. Bone mineral density of the spine and femur in healthy Saudis. Osteoporos Int. 2005;16(1):43-55. [pmid: 15167986].
3 Astrand J, Thorngren KG, Tagil M. One fracture is enough! Experience with a prospective and consecutive osteoporosis screening program with 239 fracture patients. Acta Orthop. 2006;77(1):3-8. [pmid: 16534695].
4 Barr RJ, Stewart A, Torgerson DJ, Seymour DG, Reid DM. Screening elderly women for risk of future fractures--participation rates and impact on incidence of falls and fractures. Calcif Tissue Int. 2005;76(4):243-248. [pmid: 15812582].
5 Blivik J, Karlsson MK, Moller M. Screening for low bone mineral density with quantitative ultrasound within the primary health care system. Scand J Prim Health Care. 2004;22(2):78-82. [pmid: 15255485].
6 Brownbill RA, Ilich JZ. Validation of the use of the hand for estimating bone mineral density in other skeletal sites by DXA in healthy and osteoarthritic women. J Clin Densitom. 2002;5(3):273-282. [pmid: 12357065].
7 Buist DSM, LaCroix AZ, Brenneman SK, Abbott T. A population-based osteoporosis screening program: who does not participate, and what are the consequences?. J Am Geriatr Soc. 2004;52(7):1130-1137. [pmid: 15209651].
8 Cauley J, Zmuda J, Wisniewski S, et al. Bone mineral density and prevalent vertebral fractures in men and women. Osteoporos Int. 2004;15(1):32-37. [pmid: 14628107].
9 Center JR, Nguyen TV, Pocock NA, Eisman JA. Volumetric bone density at the femoral neck as a common measure of hip fracture risk for men and women. J Clin Endocrinol Metab. 2004;89(6):2776-2782. [pmid: 15181057].
10 Chang KP, Center JR, Nguyen TV, Eisman JA. Incidence of hip and other osteoporotic fractures in elderly men and women: Dubbo Osteoporosis Epidemiology Study. J Bone Miner Res. 2004;19(4):532-536. [pmid: 15005838].
11 Cody DD, Divine GW, Nahigian K, Kleerekoper M. Bone density distribution and gender dominate femoral neck fracture risk predictors. Skeletal Radiol. 2000;29(3):151-161. [pmid: 10794552].
12 Cortet B, Dubois P, Boutry N, Palos G, Cotten A, Marchandise X. Computed tomography image analysis of the calcaneus in male osteoporosis. Osteoporos Int. 2002;13(1):33-41. [pmid: 11878453].
13 Crabtree NJ, Kroger H, Martin A, et al. Improving risk assessment: hip geometry, bone mineral distribution and bone strength in hip fracture cases and controls. Osteoporos Int. 2002;13(1):48-54. [pmid: 11883408].
14 Cram P, Schlechte J, Christensen A. A randomized trial to assess the impact of direct reporting of DXA scan results to patients on quality of osteoporosis care. J Clin Densitom. 2006;9(4):393-398. [pmid: 17097523].
15 Damilakis J, Papadokostakis G, Perisinakis K, Maris TG, Karantanas AH. Hip fracture discrimination by the Achilles Insight QUS imaging device. Eur J Radiol. 2007;63(1):59-62. [pmid: 17478068].
16 Dargent-Molina P, Piault S, Breart G. group Es. A triage strategy based on clinical risk factors for selecting elderly women for treatment or bone densitometry: the EPIDOS prospective study. Osteoporos Int. 2005;16(8):898-906. [pmid: 15570415].
17 De Laet C, Kanis J, Oden A, et al. Body mass index as a predictor of fracture risk: a meta-analysis. Osteoporos Int. 2005;16(11):1330-1338. [pmid: 15928804].
18 Dincel VE, Sengelen M, Sepici V, Cavusoglu T, Sepici B. The association of proximal femur geometry with hip fracture risk. Clin Anat. 2008;21(6):575-580. [pmid: 18661572].
19 Donescu OS, Battie MC, Videman T. The influence of magnetic resonance imaging findings of degenerative disease on dual-energy X-ray absorptiometry measurements in middle-aged men. Acta Radiol. 2007;48(2):193-199. [pmid: 17354141].
20 Ekman A, Michaelsson K, Petren-Mallmin M, Ljunghall S, Mallmin H. Dual X-ray absorptiometry of hip, heel ultrasound, and densitometry of fingers can discriminate male patients with hip fracture from control subjects: a comparison of four different methods. J Clin Densitom. 2002;5(1):79-85. [pmid: 11940732].
21 Emkey R, Koltun W, Beusterien K, et al. Patient preference for once-monthly ibandronate versus once-weekly alendronate in a randomized, open-label, cross-over trial: the Boniva Alendronate Trial in Osteoporosis (BALTO). Curr Med Res Opin. 2005;21(12):1895-1903. [pmid: 16368038].
22 Ettinger B, Kenemans P, Johnson SR, et al. Endometrial effects of tibolone in elderly, osteoporotic women. Obstet Gynecol. 2008;112(3):653-659. [pmid: 18757665].
23 Fordham JN, Chinn DJ, Bates J, Pitcher O, Bell L. Identification of men with reduced bone density at the lumbar spine and femoral neck using BMD of the os calcis. J Clin Densitom. 2004;7(2):134-142. [pmid: 15181257].
24 Gerber V, Krieg M, Cornuz J, Guigoz Y, Burckhardt P. Nutritional status using the Mini Nutritional Assessment questionnaire and its relationship with bone quality in a population of institutionalized elderly women. J Nutr Health Aging. 2003;7(3):140-145. [pmid: 12766790].
25 Gnudi S, Malavolta N. Comparison between T-score-based diagnosis of osteoporosis and specific skeletal site measurements: prognostic value for predicting fracture risk. J Clin Densitom. 2003;6(3):267-273. [pmid: 14514997].
26 Goemaere S, Zmierczak H, Van Pottelbergh I, Kaufman JM. Ability of peripheral bone assessments to predict area l bone mineral density at hip in community-dwelling elderly men. J Clin Densitom. 2002;5(3):219-228. [pmid: 12357059].
27 Guven Z, Karadag-Saygi E, Unlu-Ozkan F, Akyuz G. The effects of daily alendronate, daily calcitonin and alendronate every other day on bone mineral density in osteoporotic men. Aging Male. 2007;10(4):197-201. [pmid: 18033629].
28 Halling A, Persson GR, Berglund J, Johansson O, Renvert S. Comparison between the Klemetti index and heel DXA BMD measurements in the diagnosis of reduced skeletal bone mineral density in the elderly. Osteoporos Int. 2005;16(8):999-1003. [pmid: 15605191].
29 Hans D, Hartl F, Krieg MA. Device-specific weighted T-score for two quantitative ultrasounds: operational propositions for the management of osteoporosis for 65 years and older women in Switzerland. Osteoporos Int. 2003;14(3):251-258. [pmid: 12730788].
30 Kern LM, Powe NR, Levine MA, et al. Association between screening for osteoporosis and the incidence of hip fracture. Ann Intern Med. 2005;142(3):173-181. [pmid: 15684205].
31 Knopp JA, Diner BM, Blitz M, Lyritis GP, Rowe BH. Calcitonin for treating acute pain of osteoporotic vertebral compression fractures: a systematic review of randomized, controlled trials. Osteoporos Int. 2005;16(10):1281-1290. [pmid: 15614441].
32 Krieg MA, Cornuz J, Ruffieux C, et al. Comparison of three bone ultrasounds for the discrimination of subjects with and without osteoporotic fractures among 7562 elderly women. J Bone Miner Res. 2003;18(7):1261-1266. [pmid: 12854836].
33 Lindsay R, Silverman SL, Cooper C, et al. Risk of new vertebral fracture in the year following a fracture. JAMA. 2001;285(3):320-323. [pmid: 11176842].
34 Liu-Ambrose T, Eng JJ, Khan KM, Carter ND, McKay HA. Older women with osteoporosis have increased postural sway and weaker quadriceps strength than counterparts with normal bone mass: overlooked determinants of fracture risk?. J Gerontol A Biol Sci Med Sci. 2003;58(9):M862-866. [pmid: 14528046].
35 MacLaughlin EJ, MacLaughlin AA, Snella KA, Winston TS, Fike DS, Raehl CR. Osteoporosis screening and education in community pharmacies using a team approach. Pharmacotherapy. 2005;25(3):379-386. [pmid: 15843285].
36 Nguyen ND, Pongchaiyakul C, Center JR, Eisman JA, Nguyen TV. Abdominal fat and hip fracture risk in the elderly: the Dubbo Osteoporosis Epidemiology Study. BMC Musculoskelet Disord. 2005;6:11. [pmid: 15727686].
37 Okabe S, Morimoto Y, Ansai T, et al. Assessment of the relationship between the mandibular cortex on panoramic radiographs and the risk of bone fracture and vascular disease in 80-year-olds. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2008;106(3):433-442. [pmid: 18299222].
38 Prouteau S, Ducher G, Nanyan P, Lemineur G, Benhamou L, Courteix D. Fractal analysis of bone texture: a screening tool for stress fracture risk?. Eur J Clin Invest. 2004;34(2):137-142. [pmid: 14764077].
39 Reid DM, Hosking D, Kendler D, et al. Alendronic acid produces greater effects than risedronic acid on bone density and turnover in postmenopausal women with osteoporosis: results of FACTS -international. Clin Drug Investig. 2006;26(2):63-74.
40 Ryder KM, Shorr RI, Tylavsky FA, et al. Correlates of use of antifracture therapy in older women with low bone mineral density. J Gen Intern Med. 2006;21(6):636-641. [pmid: 16808749].
41 Sah AP, Thornhill TS, Leboff MS, Glowacki J. Correlation of plain radiographic indices of the hip with quantitative bone mineral density. Osteoporos Int. 2007;18(8):1119-1126. [pmid: 17340218].
42 Sato Y, Asoh T, Kondo I, Satoh K. Vitamin D deficiency and risk of hip fractures among disabled elderly stroke patients. Stroke. 2001;32(7):1673-1677. [pmid: 11441218].
43 Sawka AM, Thabane L, Papaioannou A, Gafni A, Hanley DA, Adachi JD. A systematic review of the effect of alendronate on bone mineral density in men. J Clin Densitom. 2005;8(1):7-13. [pmid: 15722581].
44 Schonberg MA, York M, Basu N, Olveczky D, Marcantonio ER. Preventive health care among older women in an academic primary care practice. Womens Health Issues. 2008;18(4):249-256. [pmid: 18329897].
45 Siminoski K, Jiang G, Adachi JD, et al. Accuracy of height loss during prospective monitoring for detection of incident vertebral fractures. Osteoporos Int. 2005;16(4):403-410. [pmid: 15309381].
46 Siris E, Brenneman S, Barrett-Connor E, et al. The effect of age and bone mineral density on the absolute, excess, and relative risk of fracture in postmenopausal women aged 50–99: results from the National Osteoporosis Risk Assessment (NORA). Osteoporos Int. 2006;17(4):565-574. [pmid: 16392027].
47 Sirola J, Rikkonen T, Tuppurainen M, Jurvelin JS, Alhava E, Kroger H. Grip strength may facilitate fracture prediction in perimenopausal women with normal BMD: a 15-year population-based study. Calcif Tissue Int. 2008;83(2):93-100. [pmid: 18641912].
48 Stenson WFMD, Newberry RMD, Lorenz RMDP, Baldus CRNBSN, Civitelli RMD. Increased Prevalence of Celiac Disease and Need for Routine Screening Among Patients With Osteoporosis. Arch Intern Med. 2005;165(4):393-399. [pmid: 15738367].
49 Taylor BC, Schreiner PJ, Stone KL, et al. Long-Term Prediction of Incident Hip Fracture Risk in Elderly White Women: Study of Osteoporotic Fractures. J Am Geriatr Soc. 2004;52(9):1479-1486. [pmid: 15341549].

### Wrong study design

1 Osteodensitometry in healthy postmenopausal women. Prescrire Int. 2008;17(94):68-72. [pmid: 18536138].
2 Abrahamsen B, Madsen JS, Tofteng CL, et al. A common methylenetetrahydrofolate reductase (C677T) polymorphism is associated with low bone mineral density and increased fracture incidence after menopause: longitudinal data from the Danish osteoporosis prevention study. J Bone Miner Res. 2003;18(4):723-729. [pmid: 12674333].
3 Adami S, Isaia G, Luisetto G, et al. Fracture incidence and characterization in patients on osteoporosis treatment: the ICARO study. J Bone Miner Res. 2006;21(10):1565-1570. [pmid: 16995811].
4 Ahlborg HG, Nguyen ND, Nguyen TV, Center JR, Eisman JA. Contribution of hip strength indices to hip fracture risk in elderly men and women. J Bone Miner Res. 2005;20(10):1820-1827. [pmid: 16160739].
5 Akkus Z, Camdeviren H, Celik F, Gur A, Nas K. Determination of osteoporosis risk factors using a multiple logistic regression model in postmenopausal Turkish women. Saudi Med J. 2005;26(9):1351-1359. [pmid: 16155647].
6 Asikainen TM, Kukkonen-Harjula K, Miilunpalo S. Exercise for health for early postmenopausal women: a systematic review of randomised controlled trials. Sports Med. 2004;34(11):753-778. [pmid: 15456348].
7 Barrera BA, Wilton L, Harris S, Shakir SA. Prescription-event monitoring study on 13,164 patients prescribed risedronate in primary care in England. Osteoporos Int. 2005;16(12):1989-1998. [pmid: 16133643].
8 Barrett-Connor E, Siris ES, Wehren LE, et al. Osteoporosis and fracture risk in women of different ethnic groups. J Bone Miner Res. 2005;20(2):185-194. [pmid: 15647811].
9 Biswas PN, Wilton LV, Shakir SA. Pharmacovigilance study of alendronate in England. Osteoporos Int. 2003;14(6):507-514. [pmid: 12730757].
10 Bock O, Boerst H, Thomasius FE, et al. Common musculoskeletal adverse effects of oral treatment with once weekly alendronate and risedronate in patients with osteoporosis and ways for their prevention. J Musculoskelet Neuronal Interact. 2007;7(2):144-148. [pmid: 17627083].
11 Boonen S, Nijs J, Borghs H, Peeters H, Vanderschueren D, Luyten FP. Identifying postmenopausal women with osteoporosis by calcaneal ultrasound, metacarpal digital X-ray radiogrammetry and phalangeal radiographic absorptiometry: a comparative study. Osteoporos Int. 2005;16(1):93-100. [pmid: 15197540].
12 Boyd JL, Holcomb JP, Rothenberg RJ. Physician treatment of osteoporosis in response to heel ultrasound bone mineral density reports. J Clin Densitom. 2002;5(4):375-381. [pmid: 12665638].
13 Briot K, Roux C. What is the role of DXA, QUS and bone markers in fracture prediction, treatment allocation and monitoring?. Baillieres Best Pract Res Clin Rheumatol. 2005;19(6):951-964.
14 Brookhart MA, Avorn J, Katz JN, et al. Gaps in treatment among users of osteoporosis medications: the dynamics of noncompliance. Am J Med. 2007;120(3):251-256. [pmid: 17349448].
15 Burge R, Dawson-Hughes B, Solomon DH, Wong JB, King A, Tosteson A. Incidence and economic burden of osteoporosis-related fractures in the United States, 2005 2025. J Bone Miner Res. 2007;22(3):465-475. [pmid: 17144789].
16 Cauley JA, Lui LY, Ensrud KE, et al. Bone mineral density and the risk of incident nonspinal fractures in black and white women. JAMA. 2005;293(17):2102-2108. [pmid: 15870413].
17 Center JR, Nguyen TV, Schneider D, Sambrook PN, Eisman JA. Mortality after all major types of osteoporotic fracture in men and women: an observational study. Lancet. 1999;353(9156):878-882. [pmid: 10093980].
18 Cummings SR, Melton LJ. Epidemiology and outcomes of osteoporotic fractures. Lancet. 2002;359(9319):1761-1767. [pmid: 12049882].
19 Dargent-Molina P, Piault S, Breart G. Identification of women at increased risk of osteoporosis: no need to use different screening tools at different ages. Maturitas. 2006;54(1):55-64. [pmid: 16202546].
20 DeMichele A, Troxel AB, Berlin JA, et al. Impact of raloxifene or tamoxifen use on endometrial cancer risk: a population-based case-control study. J Clin Oncol. 2008;26(25):4151-4159. [pmid: 18757329].
21 Durosier C, Hans D, Krieg MA, Schott AM. Prediction and discrimination of osteoporotic hip fracture in postmenopausal women. J Clin Densitom. 2006;9(4):475-495. [pmid: 17097535].
22 Ensrud KE, Stock JL, Barrett-Connor E, et al. Effects of raloxifene on fracture risk in postmenopausal women: the Raloxifene Use for the Heart Trial. J Bone Miner Res. 2008;23(1):112-120. [pmid: 17892376].
23 Finigan J, Greenfield DM, Blumsohn A, et al. Risk factors for vertebral and nonvertebral fracture over 10 years: a population-based study in women. J Bone Miner Res. 2008;23(1):75-85. [pmid: 17784843].
24 Fink K, Clark B. Screening for osteoporosis in postmenopausal women. Am Fam Physician. 2004;69(1):139-140. [pmid: 14727831].
25 Geater S, Leelawattana R, Geater A. Validation of the OSTA index for discriminating between high and low probability of femoral neck and lumbar spine osteoporosis among Thai postmenopausal women. J Med Assoc Thai. 2004;87(11):1286-1292. [pmid: 15825701].
26 Gruenewald DA, Matsumoto AM. Testosterone supplementation therapy for older men: potential benefits and risks. J Am Geriatr Soc. 2003;51(1):101-115. [pmid: 12534854].
27 Hodson J, Marsh J. Quantitative ultrasound and risk factor enquiry as predictors of postmenopausal osteoporosis: comparative study in primary care. BMJ. 2003;326(7401):1250-1251. [pmid: 12791742].
28 Kanis JA. Assessment of fracture risk and its application to screening for post-menopausal osteoporosis. Osteoporos Int. 1994;4:368-381. [pmid: 7696835].
29 Kanis JA, Johnell O, Oden A, De Laet C, Jonsson B, Dawson A. Ten-year risk of osteoporotic fracture and the effect of risk factors on screening strategies. Bone. 2002;30(1):251-258. [pmid: 11792594].
30 Khosla S. Surrogates for fracture endpoints in clinical trials. J Bone Miner Res. 2003;18(6):1146-1149. [pmid: 12817773].
31 Kimura M, Kawada A, Murayama Y, Murayama M. Drug eruption due to alendronate sodium hydrate. Contact Dermatitis. 2003;48(2):116. [pmid: 12694218].
32 Kudlacek S, Schneider B, Peterlik M, et al. Normative data of bone mineral density in an unselected adult Austrian population. Eur J Clin Invest. 2003;33(4):332-339. [pmid: 12662164].
33 Kung AW, Ho AY, Sedrine WB, Reginster JY, Ross PD. Comparison of a simple clinical risk index and quantitative bone ultrasound for identifying women at increased risk of osteoporosis. Osteoporos Int. 2003;14(9):716-721. [pmid: 12897978].
34 Kung AW, Lee KK, Ho AY, Tang G, Luk KD. Ten-year risk of osteoporotic fractures in postmenopausal Chinese women according to clinical risk factors and BMD T-scores: a prospective study. J Bone Miner Res. 2007;22(7):1080-1087. [pmid: 17371165].
35 Lamy O, Sandini L, Pache I, Fatio S, Burnand J, Burckhardt P. Intravenous ibandronate in men with osteoporosis: an open pilot study over 2 years. J Endocrinol Invest. 2003;26(8):728-732. [pmid: 14669826].
36 Lau EM, Leung PC, Kwok T, et al. The determinants of bone mineral density in Chinese men--results from Mr. Osteoporos Int. 2006;17(2):297-303. [pmid: 16175311].
37 Leslie WD, Tsang JF, Caetano PA, Lix LM. Manitoba Bone Density Program. Number of osteoporotic sites and fracture risk assessment: a cohort study from the Manitoba Bone Density Program. J Bone Miner Res. 2007;22(3):476-483. [pmid: 17144788].
38 Levine JP. Effective strategies to identify postmenopausal women at risk for osteoporosis. Geriatrics. 2007;62(11):22-30. [pmid: 17999567].
39 Li-Yu JT, Llamado LJ, Torralba TP. Validation of OSTA among Filipinos. Osteoporos Int. 2005;16(12):1789-1793. [pmid: 16027957].
40 Looker AC, Wahner HW, Dunn WL, et al. Updated Data on Proximal Femur Bone Mineral Levels of US Adults. Osteoporos Int. 1998;8(5):468-490. [pmid: 9850356].
41 Majima T, Shimatsu A, Komatsu Y, et al. Efficacy of risedronate in Japanese male patients with primary osteoporosis. Intern Med. 2008;47(8):717-723. [pmid: 18421187].
42 Marx RE, Sawatari Y, Fortin M, Broumand V. Bisphosphonate-induced exposed bone (osteonecrosis/osteopetrosis) of the jaws: risk factors, recognition, prevention, and treatment. J Oral Maxillofac Surg. 2005;63(11):1567-1575. [pmid: 16243172].
43 McClung MR. Clinical risk factors and evaluation of the risk of osteoporosis in clinical practice. Ann Med Interne (Paris). 2000;151(5):392-398. [pmid: 11033474].
44 McClung MR, Wasnich RD, Hosking DJ, et al. Prevention of postmenopausal bone loss: Six-year results from the Early Postmenopausal Intervention Cohort Study. J Clin Endocrinol Metab. 2004;89(10):4879-4885. [pmid: 15472179].
45 Merigo E, Manfredi M, Meleti M, et al. Bone necrosis of the jaws associated with bisphosphonate treatment: a report of twenty-nine cases. Acta Biomed Ateneo Parmense. 2006;77(2):109-117.
46 Miller PD, Roux C, Boonen S, Barton IP, Dunlap LE, Burgio DE. Safety and efficacy of risedronate in patients with age-related reduced renal function as estimated by the Cockcroft and Gault method: a pooled analysis of nine clinical trials. J Bone Miner Res. 2005;20(12):2105-2115. [pmid: 16294264].
47 Morrison LS, Tobias JH. Effect of a case-finding strategy for osteoporosis on bisphosphonate prescribing in primary care. Osteoporos Int. 2005;16(1):71-77. [pmid: 15175847].
48 Nakai Y, Noth R, Wexler J, Volpp B, Tsodikov A, Swislocki A. Computer-based screening of chest X-rays for vertebral compression fractures as an osteoporosis index in men. Bone. 2008;42(6):1214-1218. [pmid: 18395504].
49 Nevitt MC, Chen P, Dore RK, et al. Reduced risk of back pain following teriparatide treatment: a meta-analysis. Osteoporos Int. 2006;17(2):273-280. [pmid: 16142502].
50 Newman ED, Ayoub WT, Starkey RH, Diehl JM, Wood GC. Osteoporosis disease management in a rural health care population: hip fracture reduction and reduce costs in postmenopausal women after 5 years. Osteoporos Int. 2003;14:146-151. [pmid: 12730773].
51 Pothiwala P, Evans EM, Chapman-Novakofski KM. Ethnic variation in risk for osteoporosis among women: a review of biological and behavioral factors. J Womens Health (Larchmt). 2006;15(6):709-719. [pmid: 16910903].
52 Schousboe JT, Ensrud KE, Nyman JA, Melton LJ, Kane RL. Universal Bone Densitometry Screening Combined with Alendronate Therapy for Those Diagnosed with Osteoporosis Is Highly Cost-Effective for Elderly Women. J Am Geriatr Soc. 2005;53(10):1697-1704. [pmid: 16181168].
53 Silman AJ. Risk factors for Colles’ fracture in men and women: results from the European Prospective Osteoporosis Study. Osteoporos Int. 2003;14(3):213-218. [pmid: 12730767].
54 Steinbuch M, D’Agostino RB, Mandel JS, et al. Assessment of mortality in patients enrolled in a risedronate clinical trial program: a retrospective cohort study. Regul Toxicol Pharmacol. 2002;35(3):320-326. [pmid: 12202047].
55 Trijoto I, Isbagio H, Setiyohadi B, Soegondo S, Kusumawidjaja K, Ariawan I. The diagnostic value of combined risk factor analysis and radiological imaging in determining osteoporosis in post-menopausal women. Acta med. 2005;37(1):26-32.
56 van Schoor NM, Ewing SK, O’Neill TW, Lunt M, Smit JH, Lips P. Impact of prevalent and incident vertebral fractures on utility: results from a patient-based and a population-based sample. Qual Life Res. 2008;17(1):159-167. [pmid: 18040883].
57 Wilkins CH, Goldfeder JS. Osteoporosis screening is unjustifiably low in older African-American women. J Natl Med Assoc. 2004;96(4):461-467. [pmid: 15101666].
58 Williams ED, Daymond TJ. Evaluation of calcaneus bone densitometry against hip and spine for diagnosis of osteoporosis. Br J Radiol. 2003;76(902):123-128. [pmid: 12642281].
59 Zingmond DS, Melton LJ, Silverman SL. Increasing hip fracture incidence in California Hispanics, 1983 to 2000. Osteoporos Int. 2004;15(8):603-610. [pmid: 15004666].
60 Eisman JA, Civitelli R, Adami S, et al. Efficacy and tolerability of intravenous ibandronate injections in postmenopausal osteoporosis: 2-year results from the DIVA study. J Rheumatol. 2008;35(3):488-497. [pmid: 18260172].

### Wrong publication type

1 Adachi J, Lynch N, Middelhoven H, Hunjan M, Cowell W. The association between compliance and persistence with bisphosphonate therapy and fracture risk: a review. BMC Musculoskelet Disord. 2007;8:97. [pmid: 17897451].
2 Adachi JD, Rizzoli R, Boonen S, Li Z, Meredith MP, Chesnut CH 3rd. Vertebral fracture risk reduction with risedronate in post-menopausal women with osteoporosis: a meta-analysis of individual patient data. Aging Clin Exp Res. 2005;17(2):150-156. [pmid: 15977464].
3 Beauchesne MF, Miller PF. Etidronate and alendronate in the treatment of postmenopausal osteoporosis. Ann Pharmacother. 1999;33(5):587-599. [pmid: 10369624].
4 Berg AO. Screening for osteoporosis in postmenopausal women: recommendations and rationale. Am J Nurs. 2003;103(1):73-80. [pmid: 12544063].
5 Bilezikian JP. Efficacy of bisphosphonates in reducing fracture risk in postmenopausal osteoporosis. Am J Med. 2009;122(2 Suppl):S14-21. [pmid: 19187808].
6 Blake GM, Fogelman I. Role of dual-energy X-ray absorptiometry in the diagnosis and treatment of osteoporosis. J Clin Densitom. 2007;10(1):102-110. [pmid: 17289532].
7 Blank RD, Bockman RS. A review of clinical trials of therapies for osteoporosis using fracture as an end point. J Clin Densitom. 1999;2(4):435-452. [pmid: 10677797].
8 Body JJ, Gaich CL, Scheele WH, et al. A randomized double-blind trial to compare the efficacy of teriparatide (recombinant human parathyroid hormone) with alendronate in postmenopausal women with osteoporosis. J Clin Endocrinol Metab. 2002;87:4528-4535. [pmid: 12364430].
9 Cappuzzo KA, Delafuente JC. Teriparatide for severe osteoporosis. Ann Pharmacother. 2004;38(2):294-302. [pmid: 14742769].
10 Cauley JA, Zmuda JM, Wisniewski SR, et al. Bone mineral density and prevalent vertebral fractures in men and women. Osteoporos Int. 2004;15(1):32-37. [pmid: 14628107].
11 Conde FA, Aronson WJ. Risk factors for male osteoporosis. Urol. 2003;21(5):380-383.
12 Cram P, Rosenthal GE, Ohsfeldt R, Wallace RB, Schlechte J, Schiff GD. Failure to recognize and act on abnormal test results: the case of screening bone densitometry. Jt Comm J Qual Patient Saf. 2005;31(2):90-97. [pmid: 15791768].
13 Cranney A, Adachi JD, Guyatt G, et al. Risedronate for the prevention and treatment of postmenopausal osteoporosis. Cochrane Database Syst Rev. 2007;4.
14 Cranney A, Guyatt G, Griffith L, et al. Meta-analyses of therapies for postmenopausal osteoporosis. Endocr Rev. 2002;23(4):570-578. [pmid: 12202472].
15 Cranney A, Robinson V, Tugwell P, et al. Alendronate for osteoporosis in postmenopausal women. Cochrane Database Syst Rev. 2007;4.
16 de Laet CE, van der Klift M, Hofman A, Pols HA. Osteoporosis in men and women: a story about bone mineral density thresholds and hip fracture risk. J Bone Miner Res. 2002;17(12):2231-2236. [pmid: 12469917].
17 Dello Russo NM, Jeffcoat MK, Marx RE, Fugazzotto P. Osteonecrosis in the jaws of patients who are using oral biphosphonates to treat osteoporosis. Int J Oral Maxillofac Implants. 2007;22(1):146-153. [pmid: 17340909].
18 Eis SR, Lewiecki EM. Peripheral bone densitometry: Clinical applications. Arq Bras Endocrinol Metabol. 2006;50(4):596-602. [pmid: 17117285].
19 Gambacciani M, de Aloysio D, Elia D, van der Mooren MJ, Hadji P, Wuster C. Quantitative ultrasound (QUS) of bone in the management of postmenopausal women. Maturitas. 2004;47(2):139-149. [pmid: 14757273].
20 Garnero P, Mulleman D, Munoz F, Sornay-Rendu E, Delmas PD. Long-term variability of markers of bone turnover in postmenopausal women and implications for their clinical use: The OFELY Study. J Bone Miner Res. 2003;18(10):1789-1794. [pmid: 14584889].
21 Gerdhem P, Magnusson H, Karlsson MK, Akesson K. Ultrasound of the phalanges is not related to a previous fracture. J Clin Densitom. 2002;5(2):159-166. [pmid: 12110759].
22 Hauselmann HJ, Rizzoli R. A comprehensive review of treatments for postmenopausal osteoporosis. Osteoporos Int. 2003;14(1):2-12. [pmid: 12577179].
23 Holder KK, Kerley SS. Alendronate for fracture prevention in postmenopause. Am Fam Physician. 2008;78(5):579-581. [pmid: 18788232].
24 Johnell O, Kanis JA, Black DM, et al. Associations between baseline risk factors and vertebral fracture risk in the Multiple Outcomes of Raloxifene Evaluation (MORE) Study. J Bone Miner Res. 2004;19(5):764-772. [pmid: 15068500].
25 Johnson JF, Koenigsfeld C, Hughell L, Parsa RA, Bravard S. Bone health screening, education, and referral project in northwest Iowa: creating a model for community pharmacies. J Am Pharm Assoc. 2008;48(3):379-387.
26 Kanis JA, Johnell O, Oden A, De Laet C, Mellstrom D. Epidemiology of osteoporosis and fracture in men. Calcif Tissue Int. 2004;75:90-99. [pmid: 15185058].
27 Klawansky S, Komaroff E, Cavanaugh PF Jr, et al. Relationship between age, renal function and bone mineral density in the US population. Osteoporos Int. 2003;14(7):570-576. [pmid: 12844211].
28 Lewiecki EM, Laster AJ. Clinical review: Clinical applications of vertebral fracture assessment by dual-energy x-ray absorptiometry. J Clin Endocrinol Metab. 2006;91(11):4215-4222. [pmid: 16940447].
29 Lewiecki EM, Richmond B, Miller PD. Uses and misuses of quantitative ultrasonography in managing osteoporosis. Cleve Clin J Med. 2006;73(8):742-746. [pmid: 16913198].
30 Lindsay R, Pack S, Li Z. Longitudinal progression of fracture prevalence through a population of postmenopausal women with osteoporosis. Osteoporos Int. 2005;16(3):306-312. [pmid: 15455193].
31 Lippuner K. Medical treatment of vertebral osteoporosis. Eur Spine J. 2003;12(Suppl 2):S132-141. [pmid: 13680313].
32 Liu H, Paige NM, Goldzweig CL, et al. Screening for osteoporosis in men: a systematic review for an American College of Physicians guideline. [summary for patients in Ann Intern Med. 2008 May 6;148(9):I35; PMID: 18458274]. Ann Intern Med. 2008;148(9):685-701. [pmid: 18458282].
33 Malozowski S. Comparative efficacy: What we know, what we need to know, and how we can get there. Ann Intern Med. 2008;148:702-703. [pmid: 18458283].
34 Mavrokokki T, Cheng A, Stein B, Goss A. Nature and frequency of bisphosphonate-associated osteonecrosis of the jaws in Australia. J Oral Maxillofac Surg. 2007;65(3):415-423. [pmid: 17307586].
35 Miller P. Analysis of 1-year vertebral fracture risk reduction data in treatments for osteoporosis. [erratum appears in South Med J. 2003 Sep;96(9):899]. South Med J. 2003;96(5):478-485. [pmid: 12911187].
36 Morris CA, Cabral D, Cheng H, et al. Patterns of bone mineral density testing: current guidelines, testing rates, and interventions. J Gen Intern Med. 2004;19(7):783-790. [pmid: 15209594].
37 Nase JB, Suzuki JB. Osteonecrosis of the jaw and oral bisphosphonate treatment. J Am Dent Assoc. 2006;137(8):1115-1119. [pmid: 16873327].
38 Nelson HD, Helfand M, Woolf SH, Allan JD. Screening for postmenopausal osteoporosis: A review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137(6):529-541. [pmid: 12230356].
39 Nevitt MC, Cummings SR, Stone KL, et al. Risk factors for a first-incident radiographic vertebral fracture in women ≥65 years of age: The Study of Osteoporotic Fractures. J Bone Miner Res. 2005;20(1):131-140. [pmid: 15619679].
40 Pazianas M, Miller P, Blumentals WA, Bernal M, Kothawala P. A review of the literature on osteonecrosis of the jaw in patients with osteoporosis treated with oral bisphosphonates: prevalence, risk factors, and clinical characteristics. Clin Ther. 2007;29(8):1548-1558. [pmid: 17919538].
41 Peate I. A review of osteoporosis in men: implications for practice. Br J Nurs. 2004;13(6):300-306. [pmid: 15126963].
42 Pfister AK, Starcher V, Welch C. The use of calcaneal quantitative ultrasound for determining bone mass of the hip. W V Med J. 2003;99(2):71-73. [pmid: 12874917].
43 Placide J, Martens MG. Comparing screening methods for osteoporosis. Curr Womens Health Rep. 2003;3(3):207-210. [pmid: 12734031].
44 Pluskiewicz W, Drozdzowska B, Boron A. Dual X-ray absorptiometry of hip, heel ultrasound, and densitometry of fingers can discriminate male patients with hip fracture from control subjects: a comparison of four different methods. [comment]. J Clin Densitom. 2003;6(3):305. [pmid: 14571916].
45 PTF Force USPST. Screening for Osteoporosis in Postmenopausal Women: Recommendations and Rationale. Ann Intern Med. 2002;137(6):526-528. [pmid: 12230355].
46 Qaseem A, Snow V, Shekelle P, et al. Pharmacologic Treatment of Low Bone Density or Osteoporosis to Prevent Fractures: A Clinical Practice Guideline from the American College of Physicians. Ann Intern Med. 2008;149:404-415. [pmid: 18794560].
47 Qaseem A, Snow V, Shekelle P, Hopkins R, Forciea M, Owens D. Screening for osteoporosis in men: A clinical practice guideline from the American College of Physicians. Ann Intern Med. 2008;148:680-684. [pmid: 18458281].
48 Reid D, Hosking D, Brandi M, et al. A comparison of the effect of alendronate and risedronate onf bone mineral density in postmenopausal women with osteoporosis: 24-month results from FACTS-Internationa. Int J Clin Pract. 2008;62(4):575-584. [pmid: 18324951].
49 Richy F, Ethgen O, Bruyere O, Reginster J-Y. Efficacy of alphacalcidol and calcitriol in primary and corticosteroid-induced osteoporosis: a meta-analysis of their effects on bone mineral density and fracture rate. Osteoporos Int. 2004;15(4):301-310. [pmid: 14740153].
50 Rothenberg RJ, Boyd JL, Holcomb JP. Quantitative ultrasound of the calcaneus as a screening tool to detect osteoporosis: different reference ranges for Caucasian women, African American women, and Caucasian men. J Clin Densitom. 2004;7(1):101-110. [pmid: 14742894].
51 Rud B, Hilden J, Hyldstrup L, Hrobjartsson A. Performance of the Osteoporosis Self-Assessment Tool in ruling out low bone mineral density in postmenopausal women: a systematic review. Osteoporos Int. 2007;18(9):1177-1187. [pmid: 17361324].
52 Sawka AM, Papaioannou A, Josse RG, et al. What is the number of older Canadians needed to screen by measurement of bone density to detect an undiagnosed case of osteoporosis? A population-based study from CaMos. J Clin Densitom. 2006;9(4):413-418. [pmid: 17097526].
53 Schwartz EN, Steinberg DM. Prescreening tools to determine who needs DXA. Curr Osteoporos Rep. 2006;4(4):148-152. [pmid: 17112425].
54 Seeman E, Crans G, Diez-Perez A, Pinette K, Delmas P. Anti-vertebral fracture efficacy of raloxifene: a meta-analysis. Osteoporos Int. 2006;17(2):313-316. [pmid: 16217588].
55 Shenker NG, Jawad AS. Bisphosphonates and osteonecrosis of the jaw. Rheumatology (Oxford). 2007;46(7):1049-1051. [pmid: 17500074].
56 Shrader SP, Ragucci KR. Parathyroid hormone (1–84) and treatment of osteoporosis. Ann Pharmacother. 2005;39(9):1511-1516. [pmid: 16076911].
57 Solomon DH, Brookhart MA, Gandhi TK, et al. Adherence with osteoporosis practice guidelines: a multilevel analysis of patient, physician, and practice setting characteristics. Am J Med. 2004;117(12):919-924. [pmid: 15629730].
58 Somboonporn W, Davis S, Seif MW, Bell R. Testosterone for peri- and postmenopausal women. Cochrane Database Syst Rev. 2007;4.
59 Srinivasan D, Shetty S, Ashworth D, Grew N, Millar B. Orofacial pain - a presenting symptom of bisphosphonate associated osteonecrosis of the jaws. Br Dent J. 2007;203(2):91-92. [pmid: 17660779].
60 Stein B, Ashok S. Osteoporosis and the aging male. Med Health R I. 2002;85(5):160-162. [pmid: 12048750].
61 Stevenson M, Jones ML, De Nigris E, Brewer N, Davis S, Oakley J. A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess. 2005;9(22):1-160.
62 Strampel W, Emkey R, Civitelli R. Safety Considerations with Bisphosphonates for the Treatment of Osteoporosis. Drug Saf. 2007;30(9):755-763. [pmid: 17722968].
63 Testi D, Cappello A, Sgallari F, Rumpf M, Viceconti M. A new software for prediction of femoral neck fractures. Comput Methods Programs Biomed. 2004;75(2):141-145. [pmid: 15212856].
64 Vieillard MH, Maes JM, Penel G, et al. Thirteen cases of jaw osteonecrosis in patients on bisphosphonate therapy. Joint Bone Spine. 2008;75(1):34-40. [pmid: 17981488].
65 Wang Q, Chen DC. Ibandronate sodium for osteoporosis in postmenopausal women. Cochrane Database Syst Rev. 2007;4.
66 Watts NB, Marciani RD. Osteonecrosis of the Jaw. South Med J. 2008;101(2):160-165. [pmid: 18364618].
67 Wendlova J. Statistical methods of estimating fracture risk. Wien Med Wochenschr. 2006;156(21–22):569-573. [pmid: 17160373].
68 Whyte MP, Wenkert D, Clements KL, McAlister WH, Mumm S. Bisphosphonate-induced osteopetrosis. New Engl J Med. 2003;349(5):457-463. [pmid: 12890844].
69 Woodis CB. Once-yearly administered intravenous zoledronic acid for postmenopausal osteoporosis. Ann Pharmacother. 2008;42(7):1085-1089. [pmid: 18505912].

### Non-English language, but otherwise could be relevant

1 Arboleya LR, Morales A, Fiter J. [Effect of alendronate on bone mineral density and incidence of fractures in postmenopausal women with osteoporosis. A meta-analysis of published studies]. Med Clin (Barc). 2000;114(Suppl 2):79-84. [pmid: 10916812].

### Methodological issue

1 Abrahamsen B, Stilgren LS, Hermann AP, et al. Discordance between changes in bone mineral density measured at different skeletal sites in perimenopausal women--implications for assessment of bone loss and response to therapy: The Danish Osteoporosis Prevention Study. J Bone Miner Res. 2001;16(7):1212-1219. [pmid: 11450696].
2 Harris ST, Blumentals WA, Miller PD. Ibandronate and the risk of non-vertebral and clinical fractures in women with postmenopausal osteoporosis: results of a meta-analysis of phase III studies. Curr Med Res Opin. 2008;24(1):237-245. [pmid: 18047776].

### Covered by a systematic review, previous USPSTF report, or other included paper

1 Abrahamsen B, Vestergaard P, Rud B, et al. Ten-year absolute risk of osteoporotic fractures according to BMD T score at menopause: the Danish Osteoporosis Prevention Study. J Bone Miner Res. 2006;21(5):796-800. [pmid: 16734396].
2 Adami S, Baroni MC, Broggini M, Carratelli L, Caruso I, Gnessi L. Treatment of postmenopausal osteoporosis with continuous daily oral alendronate in comparison with either placebo or intranasal salmon cacitonin. Osteoporos Int. 1993;(Suppl 3):S21-27.
3 Adami S, Passeri M, Ortolani S, et al. Effects of oral alendronate and intranasal salmon calcitonin on bone mass and biochemical markers of bone turnover in postmenopausal women with osteoporosis. Bone. 1995;17(4):383-390. [pmid: 8573412].
4 Adler RA, Funkhouser HL, Holt CM. Utility of heel ultrasound bone density in men. J Clin Densitom. 2001;4(3):225-230. [pmid: 11740064].
5 Agren M, Karellas A, Leahey D, Marks D, Baran DT. Ultrasound attenuation of the calcaneus: a sensitive and specific discriminator of osteopenia in postmenopausal women. Calcif Tissue Int. 1991;48:240-244. [pmid: 2059875].
6 Akesson K, Gardsell P, Sernbo I, Johnell O, Obrant KJ. Earlier wrist fracture: a confounding factor in distal forearm bone screening. Osteoporos Int. 1992;2(4):201-204. [pmid: 1611226].
7 Alenfeld FE, Wüster C, Funck C, et al. Ultrasound Measurements at the Proximal Phalanges in Healthy Women and Patients with Hip Fractures. Osteoporos Int. 1998;8(5):393-398. [pmid: 9850344].
8 Altman DG. A meta-analysis of hormone replacement therapy for fracture prevention. JAMA. 2001;286(17):2096-2097. [pmid: 11694148].
9 Anonymous. Assessment of fracture risk and its application to screening for postmenopausal osteoporosis. Report of a WHO Study Group. World Health Organ Tech Rep Ser. 1994;843:1-129. [pmid: 7941614].
10 Anonymous. Bone density measurement--a systematic review. A report from SBU, the Swedish Council on Technology Assessment in Health Care. J Intern Med Suppl. 1997;739:1-60. [pmid: 9104441].
11 Ardila E, Echevery J, Sanchez R. Phytoestrogens in the treatment of postmenopausal osteoporosis. Cochrane Database Syst Rev. 2007;4.
12 Aris RM, Lester GE, Renner JB, et al. Efficacy of Pamidronate for Osteoporosis in Patients with Cystic Fibrosis following Lung Transplantation. Am. J. Respir. Crit. Care Med. 2000;162(3):941-946. [pmid: 10988110].
13 Arlot ME, Sornay-Rendu E, Garnero P, Vey-Marty B, Delmas PD. Apparent pre- and postmenopausal bone loss evaluated by DXA at different skeletal sites in women: The OFELY Cohort. J Bone Miner Res. 1997;12(4):683-690. [pmid: 9101381].
14 Augat P, Fan B, Lane NE, et al. Assessment of bone mineral at appendicular sites in females with fractures of the proximal femur. Bone. 1998;22(4):395-402. [pmid: 9556141].
15 Augat P, Fuerst T, Genant HK. Quantitative bone mineral assessment at the forearm: a review. Osteoporos Int. 1998;8(4):299-310. [pmid: 10024899].
16 Ballard PA, Purdie DW, Langton CM, Steel SA, Mussurakis S. Prevalence of osteoporosis and related risk factors in UK women in the seventh decade: Osteoporosis case finding by clinical referral criteria or predictive model?. Osteoporos Int. 1998;8(6):535-539. [pmid: 10326057].
17 Bilbrey GL, Weix J, Kaplan GD. Value of single photon absorptiometry in osteoporosis screening. Clin Nucl Med. 1988;13(1):7-12. [pmid: 3349709].
18 Black DM, Cummings SR, Genant HK, Nevitt MC, Palermo L, Browner W. Axial and appendicular bone density predict fractures in older women. J Bone Miner Res. 1992;7:633-638. [pmid: 1414481].
19 Blake GM, Glüer CC, Fogelman I. Bone densitometry: current status and future prospects. Br J Radiol. 1997;70(Spec):S177-186. [pmid: 9534732].
20 Blake GM, Fogelman I. Applications of bone densitometry for osteoporosis. Endocrinol Metab Clin North Am. 1998;27(2):267-287. [pmid: 9669138].
21 Bonnick S, Rosen C, BM. Alendronate vs. calcium for treatment of osteoporosis in postmenopausal women. Bone. 1998;23(5S):5476.
22 Boonen S, Cheng X, Nicholson PH, Verbeke G, Broos P, Dequeker J. The accuracy of peripheral skeletal assessment at the radius in estimating femoral bone density as measured by dual-energy X-ray absorptiometry: a comparative study of single-photon absorptiometry and computed tomography. J Intern Med. 1997;242(4):323-328. [pmid: 9366811].
23 Boonen S, Laan RF, Barton IP, Watts NB. Effect of osteoporosis treatments on risk of non-vertebral fractures: review and meta-analysis of intention-to-treat studies. Osteoporos Int. 2005;16(10):1291-1298. [pmid: 15986101].
24 Burger H, de Laet CEDH, Weel AEAM, Hofman A, Pols HAP. Added value of bone mineral density in hip fracture risk scores. Bone. 1999;25(3):369-374. [pmid: 10495142].
25 Campbell MK, Torgerson DJ, Thomas RE, McClure JD, Reid DM. Direct disclosure of bone density results to patients: effect on knowledge of osteoporosis risk and anxiety level. Osteoporos Int. 1998;8(6):584-590. [pmid: 10326065].
26 Cardona JM, Pastor E. Calcitonin versus etidronate for the treatment of postmenopausal osteoporosis: a meta-analysis of published clinical trials. Osteoporos Int. 1997;7(3):165-174. [pmid: 9205627].
27 Cauley JA, Thompson DE, Ensrud KC, Scott JC, Black D. Risk of mortality following clinical fractures. Osteoporos Int. 2000;11(7):556-561. [pmid: 11069188].
28 Christiansen C, Riis BJ. New methods for identifying “at risk” patients for osteoporosis. Clin Rheumatol. 1989;8(Suppl 2):52-55. [pmid: 2788064].
29 Cooper C, Shah S, Hand DJ, et al. Screening for vertebral osteoporosis using individual risk factors. The Multicentre Vertebral Fracture Study Group. Osteoporos Int. 1991;2:48-53. [pmid: 1790421].
30 Cosman F, Nieves J, Woelfert L, et al. Parathyroid hormone added to established hormone therapy: effects on vertebral fracture and maintenance of bone mass after parathyroid hormone withdrawal. J Bone Miner Res. 2001;16:925-931. [pmid: 11341338].
31 Cosman F, Nieves J, Zion M, et al. Daily and cyclic parathyroid hormone in women receiving alendronate. N Engl J Med. 2005;353:566-575. [pmid: 16093465].
32 Coyle D, Cranney A, Lee KM, Welch V, Tugwell P. Cost effectiveness of nasal calcitonin in postmenopausal women: use of Cochrane Collaboration methods for meta-analysis within economic evaluation. Pharmacoeconomics. 2001;19(5 Pt 2):565-575. [pmid: 11465301].
33 Crandall C. The role of serial bone mineral density testing for osteoporosis. J Womens Health Gend Based Med. 2001;10(9):887-895. [pmid: 11747684].
34 Crandall C. Risedronate: a clinical review. Arch Intern Med. 2001;161(3):353-360. [pmid: 11176760].
35 Crandall C. Parathyroid hormone for treatment of osteoporosis. Arch Intern Med. 2002;162(20):2297-2309. [pmid: 12418944].
36 Crandall C. Low-dose estrogen therapy for menopausal women: a review of efficacy and safety. J Womens Health (Larchmt). 2003;12(8):723-747. [pmid: 14588124].
37 Cranney A, Wells G, Willan A, et al. Meta-analysis of alendronate for the treatment of postmenopausal women. Endocr Rev. 2002;23:517-523. [pmid: 12202466].
38 Cranney A, Adachi JD, Griffith L, et al. Etidronate for treating and preventing postmenopausal osteoporosis. Cochrane Database Syst Rev. 2007;4.
39 Cranney A, Guyatt G, Krolicki N, et al. A meta-analysis of etidronate for the treatment of postmenopausal osteoporosis. Osteoporos Int. 2001;12(2):140-151. [pmid: 11303715].
40 Cranney A, Papaioannou A, Zytaruk N, et al. Parathyroid hormone for the treatment of osteoporosis: a systematic review. CMAJ. 2006;175(1):52-59. [pmid: 16818910].
41 Cranney A, Tugwell P, Adachi J, et al. Meta-analyses of therapies for postmenopausal osteoporosis. III. Meta-analysis of risedronate for the treatment of postmenopausal osteoporosis. Endocr Rev. 2002;23(4):517-523. [pmid: 12202466].
42 Cranney A, Welch V, Adachi JD, et al. Calcitonin for the treatment and prevention of corticosteroid-induced osteoporosis. Cochrane Database Syst Rev. 2000;(2):CD00. 1983.
43 Cranney A, Wells G, Willan A, et al. Meta-analyses of therapies for postmenopausal osteoporosis. II. Meta-analysis of alendronate for the treatment of postmenopausal women. Endocr Rev. 2002;23(4):508-516. [pmid: 12202465].
44 Cummings SR, Black DM, Nevitt MC, Browner W. Bone density at various sites for prediction of hip fractures. Lancet. 1993;341:72-75. [pmid: 8093403].
45 Cummings SR, Nevitt MC, Browner WS, Stone K, Fox KM, Ensrud KE. Risk factors for hip fracture in white women. Study of Osteoporotic Fractures Research Group. New Engl J Med. 1995;332(12):767-773. [pmid: 7862179].
46 Cunningham JL, Fordham JN, Hewitt TA, CAS. Ultrasound velocity and attenuation at different skeletal sites compared with bone mineral density measured using dual energy X-ray absorptiometry. Br J Radiol. 1996;69:25-32. [pmid: 8785618].
47 Delmas PD, Adami S, Strugala C, et al. Intravenous ibandronate injections in postmenopausal women with osteoporosis: one-year restuls from the Dosing IntraVenous Administration study. Arthritis Rheum. 2006;54:1838-1846. [pmid: 16729277].
48 Djulbegovic B, Lacevic M, Cantor A, et al. The uncertainty principle and industry-sponsored research. Lancet. 2000;356(9230):635-638. [pmid: 10968436].
49 Doren M. An assessment of hormone replacement therapy to prevent postmenopausal osteoporosis. Osteoporos Int. 1999;9(Suppl 2):S53-61. [pmid: 10525727].
50 Doren M, Nilsson JA, Johnell O. Effects of specific post-menopausal hormone therapies on bone mineral density in post-menopausal women: a meta-analysis. Hum Reprod. 2003;18(8):1737-1746. [pmid: 12871893].
51 Duboeuf F, Hans D, Schott AM, et al. Different morphometric and densitometric parameters predict cervical and trochanteric hip fracture: The EPIDOS Study. J Bone Miner Res. 1997;12(11):1895-1902. [pmid: 9383694].
52 Eichner SF, Lloyd KB, Timpe EM. Comparing therapies for postmenopausal osteoporosis prevention and treatment. Ann Pharmacother. 2003;37(5):711-724. [pmid: 12708951].
53 Eisman JA, Garcia-Hernandez PA, Ortiz-Luna G, et al. Intermittent intravenous ibandronate injections are an effective treatment option in postmenopausal osteoporosis: 2-year restuls from DIVA. Osteoporos Int. 2006;17:S212.
54 Elliot JR, Gilchrist NL, Wells JE, Ayling E, Turner J, RS. Historical assessment of risk factors in screening for osteopenia in a normal Caucasian population. Aust NZ J Med. 1993;23:458-462.
55 Espallargues M, Sampietro-Colom L, Estrada MD, et al. Identifying bone-mass-related risk factors for fracture to guide bone densitometry measurements: A systematic review of the literature. Osteoporos Int. 2001;12(10):811-822. [pmid: 11716183].
56 Ettinger B, Pressman A, Schein JR. Clinic visits and hospitals admissions for care of acid-related upper gastrointestinal disorders in women using alendronate for osteoporosis. Am J Manag Care. 1998;4:1377-1382. [pmid: 10338731].
57 Falch JA, Sandvik L, Van Beresteijn EC. Development and evaluation of an index to predict early postmenopausal bone loss. Bone. 1992;13:337-341. [pmid: 1389575].
58 Farquhar CM, Marjoribanks J, Lethaby A, Lamberts Q, Suckling JA. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2007;4.
59 Farquhar CM, Marjoribanks J, Lethaby A, Lamberts Q, Suckling JA, Cochrane HTSG. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2005;(3):CD004143.
60 Faulkner KG, McClung MR, Coleman LJ, Kingston-Sandahl E. Quantitative ultrasound of the heel: correlation with densitometric measurements at different skeletal sites. Osteoporos Int. 1994;4:42-47. [pmid: 8148571].
61 Faulkner KG, von Stetten E, Miller P. Discordance in patient classification using T-scores. J Clin Densitom. 1999;2(3):343-350. [pmid: 10548828].
62 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: Report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J. Natl. Cancer Inst. 1998;90(18):1371-1388. [pmid: 9747868].
63 Fleurence R, Torgerson DJ, Reid DM. Cost-effectiveness of hormone replacement therapy for fracture prevention in young postmenopausal women: an economic analysis based on a prospective cohort study. Osteoporos Int. 2002;13(8):637-643. [pmid: 12181622].
64 Fordham JN, Chinn DJ, Kumar N. Identification of women with reduced bone density at the lumbar spine and femoral neck using BMD at the os calcis. Osteoporos Int. 2000;11(9):797-802. [pmid: 11148807].
65 Formica CA, Nieves JW, Cosman F, Garrett P, Lindsay R. Comparative assessment of bone mineral measurements using dual X-ray absorptiometry and peripheral quantitative computed tomography. Osteoporos Int. 1998;8(5):460-467. [pmid: 9850355].
66 Fujiwara S, Kasagi F, Yamada M, Kodama K. Risk factors for hip fracture in a Japanese cohort. J Bone Miner Res. 1997;12(7):998-1004. [pmid: 9199997].
67 Gardsell P, Johnell O, Nilsson BE, Gullberg B. Predicting various fragility fractures in women by forearm bone densitometry: a follow-up study. Calcif Tissue Int. 1993;52(5):348-353. [pmid: 8504371].
68 Garnero P, Dargent-Molina P, Hans D, et al. Do markers of bone resorption add to bone mineral density and ultrasonographic heel measurement for the prediction of hip fracture in elderly women? The EPIDOS Prospective Study. Osteoporos Int. 1998;8(6):563-569. [pmid: 10326062].
69 Genant HK, Engelke K, Fuerst T, et al. Noninvasive assessment of bone mineral and structure: state of the art. J Bone Miner Res. 1996;11:707-730. [pmid: 8725168].
70 Gennari C, Chierichetti SM, Bigazzi S, et al. Comparative effects on bone mineral content of calcium plus salmon calcitonin given in two different regimens in postmenopausal osteoporosis. Curr Ther Res. 1985;38:455-462.
71 Gluer CC, Eastell R, Reid DM, et al. Association of five quantitative ultrasound devices and bone densitometry with osteoporotic vertebral fractures in a population-based sample: the OPUS Study. J Bone Miner Res. 2004;19(5):782-793. [pmid: 15068502].
72 Gnudi S, Malavolta N, Ripamonti C, Caudarella R. Ultrasound in the evaluation of osteoporosis: a comparison with bone mineral density at distal radius. Br J Radiol. 1995;68(809):476-480. [pmid: 7788232].
73 Goemaere S, Zegels B, Toye K, et al. Limited clinical utility of a self-evaluating risk assessment scale for postmenopausal osteoporosis: Lack of predictive value of lifestyle-related factors. Calcif Tissue Int. 1999;65(5):354-358. [pmid: 10541759].
74 Graafmans WC, Lingen Av, Ooms ME, Bezemer PD, Lips P. Ultrasound measurements in the calcaneus: Precision and its relation with bone mineral density of the heel, hip, and lumbar spine. Bone. 1996;19(2):97-100. [pmid: 8853851].
75 Grampp S, Henk CB, Fuerst TP, et al. Diagnostic agreement of quantitative sonography of the calcaneus with dual X-ray absorptiometry of the spine and femur. Am. J. Roentgenol. 1999;173(2):329-334. [pmid: 10430129].
76 Grampp S, Jergas M, Lang P, et al. Quantitative CT assessment of the lumbar spine and radius in patients with osteoporosis. Am. J. Roentgenol. 1996;167(1):133-140. [pmid: 8659357].
77 Greenspan SL, Bouxsein ML, Melton ME, et al. Precision and discriminatory ability of calcaneal bone assessment technologies. J Bone Miner Res. 1997;12(8):1303-1313. [pmid: 9258762].
78 Greenspan SL, Maitland-Ramsey L, Myers E. Classification of osteoporosis in the elderly is dependent on site-specific analysis. Calcif Tissue Int. 1996;58:409-414. [pmid: 8661481].
79 Greenspan SL, Resnick NM, Parker RA. Early changes in biochemical markers of bone turnover are associated with long-term changes in bone mineral density in elderly women on Alendronate, hormone replacement therapy, or combination therapy: A three-year, double-blind, placebo-controlled, randomized clinical trial. J Clin Endocrinol Metab. 2005;90(5):2762-2767. [pmid: 15713726].
80 Grotz W, Nagel C, Poeschel D, et al. Effect of ibandronate on bone loss and renal function after kidney transplantation. J Am Soc Nephrology. 2001;12:1530-1537.
81 Grubb SA, Jacobson PC, Awbrey BJ, McCartney WH, Vincent LM, Talmage RV. Bone density in osteopenic women: a modified distal radius density measurement procedure to develop an "at risk" value for use in screening women. J Orthop Res. 1984;2(4):322-327. [pmid: 6527157].
82 Haddad JG. Osteoporosis in men. Rev Rhum Engl Ed. 1997;64(6 Suppl):81S-83S. [pmid: 9273945].
83 Haguenauer D, Welch V, Shea B, Tugwell P, Adachi JD, Wells G. Fluoride for the treatment of postmenopausal osteoporotic fractures: a meta-analysis. Osteoporos Int. 2000;11(9):727-738. [pmid: 11148800].
84 Hizmetli S, Elden H, Kaptanoglu E, Nacitarhan V, Kocagli S. The effect of different doses of calcitonin on bone mineral density and fracture risk in postmenopausal women. Int J Clin Pract. 1996;52:453-455. [pmid: 10622084].
85 Isidori AM, Giannetta E, Greco EA, et al. Effects of testosterone on body composition, bone metabolism and serum lipid profile in middle-aged men: a meta-analysis. Clin Endocrinol (Oxf). 2005;63(3):280-293. [pmid: 16117815].
86 Jergas M, Genant HK. Spinal and femoral DXA for the assessment of spinal osteoporosis. Calcif Tissue Int. 1997;61(5):351-357. [pmid: 9351874].
87 Johansen HK, Gotzsche PC. Problems in the design and reporting of trials of antifungal agents encountered during meta-analysis. JAMA. 1999;282(18):1752-1759. [pmid: 10568648].
88 Johnell O, Gullberg B, Kanis JA, et al. Risk factors for hip fracture in European women: the MEDOS Study. J Bone Miner Res. 1995;10:1802-1815. [pmid: 8592959].
89 Kanis JA, Johnell O, Oden A, Dawson A, De Laet C, Jonsson B. Ten-year probabilities of osteoporotic fractures according to BMD and diagnostic thresholds. Osteoporos Int. 2001;12(12):989-995. [pmid: 11846333].
90 Karpf DB, Shapiro DR, Seeman E, et al. Prevention of nonvertebral fractures by alendronate. A meta-analysis. JAMA. 1997;277(14):1159-1164. [pmid: 9087473].
91 Khovidhunkit W, Shoback DM. Clinical effects of raloxifene hydrochloride in women. Ann Intern Med. 1999;130(5):431-439. [pmid: 10068418].
92 Kothawala P, Badamgarav E, Ryu S, Miller RM, Halbert RJ. Systematic review and meta-analysis of real-world adherence to drug therapy for osteoporosis. Mayo Clin Proc. 2007;82(12):1493-1501. [pmid: 18053457].
93 Kröger H, Lunt M, Reeve J, et al. Bone density reduction in various measurement sites in men and women with osteoporotic fractures of spine and hip: The European Quantitation of Osteoporosis Study. Calcif Tissue Int. 1999;64(3):191-199. [pmid: 10024374].
94 Kurland ES, Cosman F, McMahon DJ, et al. Parathyroid hormone as therapy for idiopathic osteoporosis in men: effects on bone mineral density and bone markers. J Clin Endocrinol Metab. 2000;85:3069-3076. [pmid: 10999788].
95 Lane NE, Sanchez S, Modin G. Parathyroid hormone treatment can reverse corticosteroid-induced osteoporosis: results of a randomized controlled clinical trial. J Clin Invest. 1998;102:1627-1633. [pmid: 9788977].
96 Langton C, Ballard PA, Bennett DK, Purdie DW. A comparison of the sensitivity and specificity of calcaneal ultrasound measurements with clinical criteria for bone densitometry (DEXA) referral. Clin Rheumatol. 1997;16(1):117-118. [pmid: 9132320].
97 Liu H, Paige N, Goldzweig C, et al. Screening for osteoporosis in men: A systematic review for an American College of Physicians guideline. Ann Intern Med. 2008;148:685-701. [pmid: 18458282].
98 Liu PY, Swerdloff RS, Veldhuis JD. Clinical review 171: The rationale, efficacy and safety of androgen therapy in older men: future research and current practice recommendations. J Clin Endocrinol Metab. 2004;89(10):4789-4796. [pmid: 15472164].
99 Liu SL, Lebrun CM. Effect of oral contraceptives and hormone replacement therapy on bone mineral density in premenopausal and perimenopausal women: a systematic review. BJSM online. 2006;40(1):11-24.
100 Lyles KW, Gold DT, Shipp KM, Pieper CF, Martinez S, Mulhausen PL. Association of osteoporotic vertebral compression fractures with impaired functional status. Am J Med. 1993;94(6):595-601. [pmid: 8506884].
101 Macedo JM, Macedo CR, Elkis H, De Oliveira IR. Meta-analysis about efficacy of anti-resorptive drugs in post-menopausal osteoporosis. J Clin Pharm Ther. 1998;23(5):345-352. [pmid: 9875682].
102 Marshall D, Johnell O, Wedel H. Meta-analysis of how well measures of bone mineral density predict occurrence of osteoporotic fractures. BMJ. 1996;312(7041):1254-1259. [pmid: 8634613].
103 Martin JC, DMR. Appendicular measurements in screening women for low axial bone mineral density. Br J Radiol. 1996;69:234-240. [pmid: 8800867].
104 Massie A, Reid DM, Porter RW. Screening for osteoporosis: comparison between dual energy X-ray absorptiometry and broadband ultrasound attenuation in 1000 perimenopausal women. Osteoporos Int. 1993;3(2):107-110. [pmid: 8453190].
105 McClung M, Clemmesen B, Daifotis A, et al. Alendronate prevents postmenopausal bone loss in women without osteoporosis: A double-blind, randomized, controlled trial. Ann Intern Med. 1998;128(4):253-261. [pmid: 9471927].
106 Melton LJ 3rd, Atkinson EJ, O’Fallon WM, Wahner HW, Riggs BL. Long-term fracture prediction by bone mineral assessed at different skeletal sites. J Bone Miner Res. 1993;8:1227-1233. [pmid: 8256660].
107 Melton LJ 3rd, Chrischilles EA, Cooper C, Lane AW, Riggs BL. Perspective. How many women have osteoporosis?. J Bone Miner Res. 1992;7:1005-1010. [pmid: 1414493].
108 Miller PD, McClung MR, Macovei L, et al. Monthly oral ibandronate therapy in postmenopausal osteoporosis: 1-year results from the MOBILE study. J Bone Miner Res. 2005;20:1315-1322. [pmid: 16007327].
109 Naganathan V, March L, Hunter D, Pocock NA, Markovey J, Sambrook PN. Quantitative heel ultrasound as a predictor for osteoporosis. Med J Aust. 1999;171:297-300. [pmid: 10560444].
110 Nelson HD, Helfand M. Screening for postmenopausal osteoporosis. Systematic evidence review No 17. (Prepared by the Oregon Evidence-based Practice Center for the Agency for Heathcare Research and Quality). Rockville, MD. September. 2002.
111 Nelson HD, Humphrey LL, Nygren P, Teutsch SM, Allan JD. Postmenopausal hormone replacement therapy: scientific review. JAMA. 2002;288(7):872-881. [pmid: 12186605].
112 Nelson HD, Morris CD, Kraemer DF, et al. Osteoporosis in postmenopausal women: diagnosis and monitoring Evidence Report: Technology Assessment No 28 (Prepared by the Oregon Evidence-based Practice Center for the Agency for Healthcare Research and Quality). Rockville, MD. 2001.
113 Nguyen ND, Eisman JA, Nguyen TV. Anti-hip fracture efficacy of biophosphonates: a Bayesian analysis of clinical trials. J Bone Miner Res. 2006;21(2):340-349. [pmid: 16526127].
114 O’Connell D, Robertson J, Henry D, Gillespie W. A systematic review of the skeletal effects of estrogen therapy in postmenopausal women. II. An assessment of treatment effects. Climacteric. 1998;1(2):112-123. [pmid: 11907914].
115 Ohishi T, Kushida K, Yamazaki K, Naitoh KN, Nagano A. Ultrasound measurement using CUBA clinical system can discriminate between women with and without vertebral fractures. J Clin Densitom. 2000;3(3):227-231. [pmid: 11090229].
116 Overgaard K, Hansen MA, Jensen SB, Christiansen C. Effect of salcalcitonin given intranasally on bone mass and fracture rates in established osteoporosis: a dose-response study. BMJ. 1992;305:556-561. [pmid: 1393035].
117 Palmer S, McGregor DO, Strippoli GF. Interventions for preventing bone disease in kidney transplant recipients. [update in Cochrane Database Syst Rev. 2007;(3):CD005015; PMID: 17636784]. Cochrane Database Syst Rev. 2005;(2):CD005015.
118 Papapoulos SE, Quandt SA, Liberman UA, Hochberg MC, Thompson DE. Meta-analysis of the efficacy of alendronate for the prevention of hip fractures in postmenopausal women. Osteoporos Int. 2005;16(5):468-474. [pmid: 15448985].
119 Pluijm SM, Graafmans WC, Bouter LM, Lips P. Ultrasound measurements for the prediction of osteoporotic fractures in elderly people. Osteoporos Int. 1999;9:550-556. [pmid: 10624464].
120 Pluskiewicz W, Drozdzowska B. Ultrasound measurements at the calcaneus in men: differences between healthy and fractured persons and the influence of age and anthropometric features on ultrasound parameters. Osteoporos Int. 1999;10(1):47-51. [pmid: 10501779].
121 Pocock NA, Culton NL, Harris ND. The potential effect on hip fracture incidence of mass screening for osteoporosis. Med J Aust. 1999;170(10):486-488. [pmid: 10376026].
122 Pocock NA, Noakes KA, Howard GM, et al. Screening for osteoporosis: what is the role of heel ultrasound?. Med J Aust. 1996;164(6):367-370. [pmid: 8606664].
123 Prostko M. Meta-analysis of prevention of nonvertebral fractures by alendronate. JAMA. 1997;278(8):631. [pmid: 9272886].
124 Ravn P, Clemmesen B, Riis BJ, C C. The effect on bone mass and bone markers of different doses of ibandronate: A new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: A 1-year, randomized, double-blind, placebo-controlled dose-finding study. Bone. 1996;19(5):527-533. [pmid: 8922653].
125 Reginster JY, Adami S, Lakatos P, et al. Efficacy and tolerability of once-monthly oral ibandronate in postmenopausal osteoporosis: 2-year results from the MOBILE study. Ann Rheum Dis. 2006;65:654-661. [pmid: 16339289].
126 Reginster JY, Sedrein WB, Viethel P, Micheletti MC, Chevallier T, Audran M. Validation of OSIRIS®, a prescreening tool for the identification of women with an increased risk of osteoporosis. Gynecol Endrcrinol. 2004;18:3-8.
127 Reid IR, Wattie DJ, Evans MC, Gamble GD, Stapleton JP, Cornish J. Continuous therapy with pamidronate, a potent bisphosphonate, in postmenopausal osteoporosis. J Clin Endocrinol Metab. 1994;79(6):1595-1599. [pmid: 7989461].
128 Rico H, Revilla M, Hernandez E, Villa LF, Alverex de Buergo M. Total and regional bone mineral content and fracture rate in postmenopausal osteoporosis treated with salmon calcitonin: a prospective study. Calcif Tissue Int. 1995;56:181-185. [pmid: 7750020].
129 Rimes KA, Salkovskis PM, Shipman AJ. Psychological and behavioural effects of bone density screening for osteoporosis. Psychol Health. 1999;14(4):585.
130 Rosenthall L, Tenenhouse A, Caminis J. A correlative study of ultrasound calcaneal and dual-energy X-ray absorptiometry bone measurements of the lumbar spine and femur in 1000 women. Eur J Nucl Med. 1995;22:402-406. [pmid: 7641747].
131 Ross SD. Meta-analysis of prevention of nonvertebral fractures by alendronate. JAMA. 1997;278(8):631. [pmid: 9272885].
132 Rowan JP, Simon JA, Speroff L, Ellman H. Effects of low-dose norethindrone acetate plus ethinyl estradiol (0.5 mg/2.5 microg) in women with postmenopausal symptoms: updated analysis of three randomized, controlled trials. Clin Ther. 2006;28(6):921-932. [pmid: 16860174].
133 Rubin SM, Cummings SR. Results of bone densitometry affect women’s decisions about taking measures to prevent fractures. Ann Intern Med. 1992;116(12 Pt 1):990-995. [pmid: 1586110].
134 Schott AM, Weill-Engerer S, Hans D, Duboeuf F, Delmas PD, PJM. Ultrasound discriminates patients with hip fracture equally well as dual energy X-ray absorptiometry and independently of bone mineral density. J Bone Miner Res. 1995;10:243-249. [pmid: 7754803].
135 Siris E, Miller P, Barrett-Connor E. Identification and fracture outcomes of undiagnosed low bone mineral density in postmenopausal women: Results from the national osteoporosis risk assessment. JAMA. 2001;286:2815-2822. [pmid: 11735756].
136 Snelling AM, Crespo CJ, Schaeffer M, Smith S, Walbourn L. Modifiable and nonmodifiable factors associated with osteoporosis in postmenopausal women: Results from the Third National Health and Nutrition Examination Survey, 1988–1994. J Womens Health Gend Based Med. 2001;10(1):57-65. [pmid: 11224945].
137 Stewart A, Torgerson DJ, Reid DM. Prediction of fractures in perimenopausal women: a comparison of dual energy x ray absorptiometry and broadband ultrasound attenuation. Ann Rheum Dis. 1996;55(2):140-142. [pmid: 8712866].
138 Tinetti ME, Doucette J, E C, Marottoli R. Risk factors for serious injury during falls by oler persons in the community. J Am Geriatr Soc. 1995;43(11):1214-1221. [pmid: 7594154].
139 Tinetti ME, Inouye SK, Gill TM, Doucette JT. Shared risk factors for falls, incontinence, and functional dependence: Unifying the approach to geriatric syndromes. JAMA. 1995;273(17):1348-1353. [pmid: 7715059].
140 Torgerson D, Bell-Syer S. Hormone replacement therapy and prevention of vertebral fractures: a meta-analysis of randomised trials. BMC Musculoskelel Disord. 2001;2(1):7.
141 Torgerson DJ, Bell-Syer SE. Hormone replacement therapy and prevention of nonvertebral fractures: a meta-analysis of randomized trials. JAMA. 2001;285(22):2891-2897. [pmid: 11401611].
142 Tromp AM, Smit JH, Deeg DJH, Lips P. Quantitative ultrasound measurements of the tibia and calcaneus in comparison with DXA measurements at various skeletal sites. Osteoporos Int. 1999;9(3):230-235. [pmid: 10450412].
143 van Hemert AM, Vandenbroucke JP, Birkenhäger JC, Valkenburg HA. Prediction of osteoporotic fractures in the general population by a fracture risk score. A 9-year follow-up among middle-aged women. Am J Epidemiol. 1990;132:123-135. [pmid: 2192546].
144 van Staa TP, Leufkens H, Abenhaim L, Cooper C. Postmarketing surveillance of the safety of cyclic etidronate. Pharmacotherapy. 1998;18(5):1121-1128. [pmid: 9758324].
145 Varney LF, Parker RA, Vincelette A, Greenspan SL. Classification of osteoporosis and osteopenia in postmenopausal women is dependent on site-specific analysis. J Clin Densitom. 1999;2(3):275-283. [pmid: 10548823].
146 Verhaar H, Koele J, Neijzen T, Dessens J, Duursma S. Are arm span measurements useful in the prediction of osteoporosis in postmenopausal women?. Osteoporos Int. 1998;8(2):174-176. [pmid: 9666942].
147 Weinstein LM, Ullery B, Bourguignon CR. A simple system to determine who needs osteoporosis screening. Obstet Gynecol. 1999;183:547-549.
148 Wells G, Tugwell P, Shea B, et al. Meta-analyses of therapies for postmenopausal osteoporosis. V. Meta-analysis of the efficacy of hormone replacement therapy in treating and preventing osteoporosis in postmenopausal women. Endocr Rev. 2002;23(4):529-539. [pmid: 12202468].
149 Wolinsky FD, JFF. The risk of hip fracture among noninstitutionalized older adults. J Gerontol. 1994;49:S165-175. [pmid: 8014400].
150 Woodson G. Dual X-ray absorptiometry T-score concordance and discordance between the hip and spine measurement sites. J Clin Densitom. 2000;3(4):319-324. [pmid: 11175911].
151 Young H, Howey S, DWP. Broadband ultrasound attenuation compared with dual-energy X-ray absorptiometry in screening for postmenopausal low bone density. Osteoporosis Int. 1993;3:160-164.
152 Zmuda JM, Cauley JA, Glynn NW, Finkelstein JS. Posterior-anterior and lateral dual-energy x-ray absorptiometry for the assessment of vertebral osteoporosis and bone loss among older men. J Bone Miner Res. 2000;15(7):1417-1424. [pmid: 10893693].

### Did not meet definition of primary prevention

1 Black DM, Cummings SR, Karpf DB, et al. Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Lancet. 1996;348(9041):1535-1541. [pmid: 8950879].
2 Bone HG, Downs RW Jr, Tucci JR, et al. Dose-response relationships for alendronate treatment in osteoporotic elderly women. J Clin Endocrinol Metab. 1997;82(1):265-274. [pmid: 8989272].
3 Clemmesen B, Ravn P, Zegels B, Taquet AN, Christiansen C, Reginster JY. A 2-year phase II study with 1-year of follow-up of risendronate (NE-58095) in postmenopausal osteoporosis. Osteoporos Int. 1997;7:488-495. [pmid: 9425508].
4 Fogelman I, Ribot C, Smith R, Ethgen D, Sod E, Reginster J-Y. Risedronate reverses bone loss in postmenoopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. J Clin Endocrinol Metab. 2000;85:1895-1900. [pmid: 10843171].
5 Greenspan SL, Parker RA, Ferguson L, Rosen HN, Maitland-Ramsey L, Karpf DB. Early changes in biochemical markers of bone turnover predict the long-term response to alendronate therapy in representative elderly women: a randomized clinical trial. J Bone Miner Res. 1998;13:1431-1438. [pmid: 9738515].
6 Greenspan SL, Schneider DL, McClung MR, et al. Alendronate improves bone mineral density in elderly women with osteoporosis residing in long-term care facilities. Ann Intern Med. 2002;136:742-746. [pmid: 12020142].
7 Harris ST, Watts NB, Genant HK, et al. Effects of risedronate treatment on vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: a randomized controlled trial. Vertebral Efficacy With Risedronate Therapy (VERT) Study Group. JAMA. 1999;282(14):1344-1352. [pmid: 10527181].
8 Ishida Y, Kawai S. Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: The Yamaguchi Osteoporosis Prevention Study. Am J Med. 2004;117(8):549-555. [pmid: 15465502].
9 Lyritis GP, Tsakalakos N, Paspati I, Skarantavos G, Galanos A, Androulakis C. The effect of a modified etidronate cyclical regimen on postmenopausal osteoporosis: a four-year study. Clin Rheumatol. 1997;16(4):354-360. [pmid: 9259248].
10 Montessori ML, Scheele WH, Netelenbos JC, Kerkhoff JF, Bakker K. The use of etidronate and calcium versus calcium alone in the treatment of postmenopausal osteopenia: results of three years of treatment. Osteoporos Int. 1997;7(1):52-58. [pmid: 9102064].
11 Pacifici R, McMurtry C, Vered I, Rupich R, Avioli L. Coherence therapy does not prevent axial bone loss in osteoporotic women: A preliminary comparative study. J Clin Endocrinol Metab. 1988;66(4):747-753. [pmid: 3126214].
12 Reginster JY, Minne HW, Sorensen OH, et al. Randomized trial of the effects of risedronate on vertebral fractures in women with established postmenopausal osteoporosis. Osteoporos Int. 2000;11(1):83-91. [pmid: 10663363].
13 Shiota E, Tsuchiya K, Yamaoka K, Kawano O. Effect of intermittent cyclical treatment with etidronate disodium (HEBP) and calcium plus alphacalcidol in postmenopausal osteoporosis. J Orthop Sci. 2001;6:133-136. [pmid: 11484098].
14 Storm T, Thamsborg G, TS. Effect of intermittent cyclical etidronate therapy on bone mass and fracture rate in women with postmenopausal osteoporosis. New Engl J Med. 1990;322(18):1265-1271. [pmid: 2109197].
15 Watts N, Harris S, Harry M, et al. Intermittent cyclical etidronate treatment of postmenopausal osteoporosis. New Engl J Med. 1990;323(2):73-79. [pmid: 2113611].
16 Wimalawansa SJ. A four-year randomized controlled trial of hormone replacement and bisphosphonate, alone or in combination, in women with postmenopausal osteoporosis. Am J Med. 1998;104:219-226. [pmid: 9552083].

## Appendix B5 U.S. Preventive Services Task Force Quality Rating Criteria for RCTs and Observational Studies

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test
- Random or consecutive selection of patients
- Screening cutoff pre-determined
- All patients undergo the reference standard

Definition of ratings based on above criteria:

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease; study attempts to enroll a random or consecutive sample of patients who meet inclusion criteria; screening cutoffs pre-stated.
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients (i.e. applicable to most screening settings).
Poor: | Has important limitation such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

### Randomized Controlled Trials (RCTs) and Cohort Studies

Criteria:

- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of ratings based on above criteria:

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Case Control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

Definition of ratings based on criteria above:

Good: | Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
Fair: | Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.
Poor: | Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

Reference: Harris et al, 2001^33^

## Appendix B6 Quality Assessment for Osteoporosis Risk Assessment Papers

1. Is the risk assessment tool appropriate for a primary care screening tool?
2. Does the study evaluate diagnostic test performance in a population other than the one used to derive the instrument?
3. Does the study evaluate a consecutive clinical series of patients or a random subset?
4. Does the study adequately describe the population in which the risk instrument was tested (BMD reported)?
5. Does the study adequately describe the instrument evaluated?
6. Does the study include appropriate criteria in the instrument (must include age and some measure of body weight or size)?
7. Does the study adequately describe the method used to calculate the risk index?
8. Does the study use appropriate criteria to assess the risk factors (uses either a validated questionnaire or other corroborated method)?
9. Does the study evaluate outcomes or the reference standard in all patients enrolled (up to 10% loss considered acceptable)?
10. Was the reference standard (BMD or fracture assessment) performed consistently without regard for the results of the risk assessment?
11. Does the study evaluate outcomes blinded to results of the screening instrument?

Reference: Adapted from Harris et al, 2001^33^

## Appendix B7 Quality Rating Criteria for Systematic Reviews

Overall quality rating for each systematic review is based on the below questions. Ratings are summarized as: Good, Fair, or Poor:

Criteria:

- Search dates reported?
- Search methods reported?
- Comprehensive search?
- Inclusion criteria reported?
- Selection bias avoided?
- Validity criteria reported?
- Validity assessed appropriately?
- Methods used to combine studies reported?
- Findings combined appropriately?
- Conclusions supported by data?

Definitions of ratings based on above criteria:

Good: | Meets all criteria: reports comprehensive and reproducible search methods and results; reports pre-defined criteria to select studies and reports reasons for excluding potentially relevant studies; adequately evaluates quality of included studies and incorporates assessments of quality when synthesizing data; reports methods for synthesizing data and uses appropriate methods to combine data qualitatively or quantitatively; conclusions supported by the evidence reviewed.
Fair: | Studies will be graded fair if they fail to meet one or more of the above criteria, but the limitations are not judged as being major.
Poor: | Studies will be graded poor if they have a major limitation in one or more of the above criteria.

Created from the following publications: Harris et al, 2001^33^; National Institute for Health and Clinical Excellence, 2006^236^; and Oxman and Guyatt, 1991^237^

## Appendix B8 Expert Reviewers

- Robert A. Adler, MD
- Professor of Internal Medicine and of Epidemiology and Community Health
- Virginia Commonwealth University

- Douglas C. Bauer, MD
- Director, Division of General Internal Medicine Research Program
- Director, Clinical and Translational Resident Research Training Program
- Co-Director, Clinical and Translational Science Pathways to Discovery
- University of California at San Francisco

- Stephen R. Cummings, MD, FACP
- Principal Investigator, Study of Osteoporotic Fractures and Fracture Intervention Trial
- Professor of Medicine and of Epidemiology, Associate Chair of Medicine for Clinical Research
- Director, Coordinating Center
- University of California at San Francisco

- Leila Kahwati, MD, MPH
- Deputy Chief Consultant for Preventive Medicine, Department of Veterans Affairs, Veterans
- Health Administration, Office of Patient Care Services, National Center for Health Promotion and Disease Prevention

- Theresa Kehoe, MD
- Medical Officer, Division of Metabolic and Endocrine Drug Products, Center for Drug
- Evaluation and Research, U.S. Food and Drug Administration

- Linda Kinsinger, MD, MPH
- Director, VA National Center for Health Promotion and Disease Prevention Patient Care Services

- Eric Orwoll, MD
- Associate Dean, Department of Medicine: Endocrinology, Diabetes, and Clinical Nutrition
- Oregon Health and Science University

- Anna Tosteson, ScD
- Professor of Medicine and Community and Family Medicine
- The Dartmouth Institute for Health Policy and Clinical Practice
- Dartmouth Medical School