# Abbreviations

ABONE: age, body size, no estrogen
aCI: adjusted confidence interval
ADL: activities of daily living
AE: adverse events
AHRQ: Agency for Healthcare Research and Quality
AUC: area under the curve
AUROC: area under the receiver operating characteristic
BMD: bone mineral density
BMI: body mass index
BUA: broadband ultrasound attenuation
BW: body weight
CaMOS: Canadian Multicentre Osteoporosis Study
Cat K: Cathepsin K
CEE: conjugated equine estrogen
CHD: coronary heart disease
CI: confidence interval
COPD: chronic obstructive pulmonary disease
C-stress: compressive stress
DOES: Dubbo Osteoporosis Epidemiology Study
DXA: dual-energy x-ray absorptiometry
EPESE: Established Population for Epidemiology Studies of the Elderly Study
FDA: U.S. Food and Drug Administration
FIT: Fracture Intervention Trial
FN: femoral neck
GI: gastrointestinal
HAL: hip axis length
HAS: hip strength analysis
HMO: health maintenance organization
HORIZON: Health Outcomes and Reduced Incidence with Zoledronic Acid Once Yearly Trial
HR: hazard ratio
HR: heart rate
HRT: hormone replacement therapy
IBIS: International Breast Cancer Intervention Study
LASA: Longitudinal Aging Study Amsterdam
LIFT: Long-Term Intervention on Fractures with Tibolone Study
LS: lumbar spine
MORES: Multiple Outcomes of Raloxifene Study
MPA: medroxyprogesterone acetate
MrOS: Osteoporotic Fractures in Men Study
nCI: nominal confidence interval
NHANES: National Health and Nutrition Examination Survey
NNS: number needed to screen
NNT: number needed to treat
NOF: National Osteoporosis Foundation
NORA: National Osteoporosis Risk Assessment Tool
NPV: negative predictive value
NR: not reported
NSABP: National Surgical Adjuvant Breast Cancer Prevention Study
OPERA: Osteoporosis Prescreening Risk Assessment
OPG: osteoprotegerin
OPRA: Osteoporosis Prospective Risk Assessment
OR: odds ratio
ORACLE: Osteoporosis Risk Assessment by Composite Linear Estimate Study
ORAI: Osteoporosis Risk Assessment Instrument
OSIRIS: Osteoporosis Index of Risk
OST: Osteoporosis Self-assessment Screening Tool
PCT: placebo-controlled trial
PIXI: Peripheral Instantaneous X-ray Imager
PPV: positive predictive value
PROOF: Prevent Recurrence of Osteoporotic Fractures Study
PTH: parathyroid hormone
QUI: quantitative ultrasound index
QUS: quantitative ultrasound
RA: rheumatoid arthritis
RCT: randomized, controlled trial
RH: relative hazard
ROC: receiver operating characteristic
RR: relative risk
RR: risk ratio
RUTH: Raloxifene Use for the Heart Trial
SCORE: Simple Calculated Osteoporosis Risk Estimation Study
SD: standard deviation
SE: standard error
SEMOF: Swiss Evaluation of the Methods of Measurement of Osteoporotic Fracture Risk
SOF: Study of Osteoporotic Fractures Study
SOFSURF: Study of Osteoporosis Fractures—Study Utilizing Risk Factors
SOS: speed of sound
TH: total hip
UBPI: ultrasound bone profile index
VA: U.S. Department of Veterans Affairs
VOS: velocity of sound
WHI: Women's Health Initiative
WHO: World Health Organization