# Appendices

Appendix A Abbreviations

Appendix B Detailed Methods

Appendix C Appendix Figures

Appendix D Appendix Tables