# References

1 US Preventive Services Task Force. Screening and interventions for overweight in children and adolescents: recommendation statement. Pediatrics. 2005;116:205-209. [pmid: 15995054].
2 Whitlock EP, Williams SB, Gold R, Smith PR, Shipman SA. Screening and Interventions for Childhood Overweight. Evidence Synthesis No 36 AHRQ Publication No 05-0582-B-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2005.
3 Whitlock EP, O’Connor E, Williams SB, Beil TL, Lutz KW. Effectiveness of Weight Management in Children and Adolescents. Evidence Report/Technology Assessment No. 170. AHRQ Publication No. 08–E014. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
4 Fayter D, Nixon J, Hartley S, et al. A systematic review of the routine monitoring of growth in children of primary school age to identify growth-related conditions. Health Technol Assess. xi. 2007;11:iii-iii. 163. [pmid: 17580001].
5 Hall DM, Cole TJ. What use is the BMI?. Arch Dis Child. 2006;91:283-286. [pmid: 16551784].
6 Westwood M, Fayter D, Hartley S, et al. Childhood obesity: should primary school children be routinely screened? A systematic review and discussion of the evidence. Arch Dis Child. 2007;92:416-422. [pmid: 17449522].
7 Summerbell CD, Waters E, Edmunds LD, Kelly S, Brown T, Campbell KJ. Interventions for preventing obesity in children. Cochrane Database Syst Rev. 2005:CD001871.
8 Davis MM, Gance-Cleveland B, Hassink S, Johnson R, Paradis G, Resnicow K. Recommendations for prevention of childhood obesity. Pediatrics. 2007;120:S229-S253. [pmid: 18055653].
9 National Institute for Health and Clinical Excellence. Obesity: Guidance on the Prevention, Identification, Assessment and Management of Overweight and Obesity in Adults and Children. London. National Institute for Health and Clinical Excellence. 2006.
10 Summerbell CD, Ashton V, Campbell KJ, Edmunds L, Kelly S, Waters E. Interventions for treating obesity in children. Cochrane Database Syst Rev. 2009:CD001872.
11 Barlow SE. Expert Committee. Expert committee recommendations regarding the prevention, assessment, and treatment of child and adolescent overweight and obesity: summary report. Pediatrics. 2007;120:S164-S192. [pmid: 18055651].
12 Institute of Medicine. Preventing Childhood Obesity: Health in the Balance. Washington, DC. National Academies Press. 2005.
13 Institute of Medicine. Progress in Preventing Childhood Obesity: Focus on Industry. Washington, DC. National Academies Press. 2006.
14 Center for Disease Control and Prevention. 2000. CDC Growth Charts: United States. www.cdc.gov/growthcharts.
15 Cole TJ, Faith MS, Pietrobelli A, Heo M. What is the best measure of adiposity change in growing children: BMI, BMI %, BMI z-score or BMI centile?. Eur J Clin Nutr. 2005;59:419-425. [pmid: 15674315].
16 Mei Z, Grummer-Strawn LM, Pietrobelli A, Goulding A, Goran MI, Dietz WH. Validity of body mass index compared with other body-composition screening indexes for the assessment of body fatness in children and adolescents. Am J Clin Nutr. 2002;75:978-985. [pmid: 12036802].
17 Reilly JJ, Methven E, McDowell ZC, et al. Health consequences of obesity. Arch Dis Child. 2003;88:748-752. [pmid: 12937090].
18 Must A, Jacques PF, Dallal GE, Bajema CJ, Dietz WH. Long-term morbidity and mortality of overweight adolescents. A follow-up of the Harvard Growth Study of 1922 to 1935. N Engl J Med. 1992;327:1350-1355. [pmid: 1406836].
19 Must A, Strauss RS. Risks and consequences of childhood and adolescent obesity. Int J Obes Relat Metab Disord. 1999;23(Suppl 2):S2-11. [pmid: 10340798].
20 Viner RM, Cole TJ. Adult socioeconomic, educational, social, and psychological outcomes of childhood obesity: a national birth cohort study. BMJ. 2005;330:1354. [pmid: 15901644].
21 Kuczmarski RJ, Ogden CL, Guo SS, et al. CDC. Growth Charts for the United States: methods and development. Vital Health Stat. 2002. 2000;11:1-190.
22 Freedman DS, Mei Z, Srinivasan SR, Berenson GS, Dietz WH. Cardiovascular risk factors and excess adiposity among overweight children and adolescents: the Bogalusa Heart Study. J Pediatr. 2007;150:12-17. [pmid: 17188605].
23 Wang Y, Beydoun MA. The obesity epidemic in the United States—gender, age, socioeconomic, racial/ethnic, and geographic characteristics: a systematic review and meta-regression analysis. Epidemiol Rev. 2007;29:6-28. [pmid: 17510091].
24 Ogden CL, Carroll MD, Flegal KM. High body mass index for age among US children and adolescents, 2003–2006. JAMA. 2008;299:2401-2405. [pmid: 18505949].
25 Ogden CL, Carroll MD, Curtin LR, McDowell MA, Tabak CJ, Flegal KM. Prevalence of overweight and obesity in the United States, 1999–2004. JAMA. 2006;295:1549-1555. [pmid: 16595758].
26 Hedley AA, Ogden CL, Johnson CL, Carroll MD, Curtin LR, Flegal KM. Prevalence of overweight and obesity among U.S. children, adolescents, and adults, 1999–2002. JAMA. 2004;291:2847-2850. [pmid: 15199035].
27 Harris KM, Gordon-Larsen P, Chantala K, Udry JR. Longitudinal trends in race/ethnic disparities in leading health indicators from adolescence to young adulthood. Arch Ped Adolesc Med. 2006;160:74-81.
28 Freedman DS, Khan LK, Serdula MK, Dietz WH, Srinivasan SR, Berenson GS. Racial differences in the tracking of childhood BMI to adulthood. Obes Res. 2005;13:928-935. [pmid: 15919847].
29 Freedman DS, Ogden CL, Flegal KM, Khan LK, Serdula MK, Dietz WH. Childhood overweight and family income. Med Gen Med. 2007;9:26.
30 Davison KK, Birch LL. Child and parent characteristics as predictors of change in girls’ body mass index. Int J Obes Relat Metab Disord. 2001;25:1834-1842. [pmid: 11781765].
31 Garn SM, Clark DC. Trends in fatness and the origins of obesity: Ad Hoc Committee to Review the Ten-State Nutrition Survey. Pediatrics. 1976;57:443-456. [pmid: 1264536].
32 Gordon-Larsen P, Adair LS, Suchindran CM. Maternal obesity is associated with younger age at obesity onset in U.S. adolescent offspring followed into adulthood. Obesity. 2007;15:2790-2796. [pmid: 18070770].
33 Kipping RR, Jago R, Lawlor DA. Obesity in children, I: epidemiology, measurement, risk factors, and screening. BMJ. 2008;337:a1824. [pmid: 18922835].
34 Hawkins SS, Law C. A review of risk factors for overweight in preschool children: a policy perspective. Int J Pediatr Obesity. 2006;1:195-209.
35 Moreno LA, Rodriguez G. Dietary risk factors for development of childhood obesity. Curr Opin Clin Nutr Metab Care. 2007;10:336-341. [pmid: 17414504].
36 Reilly JJ, Armstrong J, Dorosty AR, et al. Early life risk factors for obesity in childhood: cohort study. BMJ. 2005;330:1357. [pmid: 15908441].
37 Tait AR, Voepel-Lewis T, Burke C, Kostrzewa A, Lewis I. Incidence and risk factors for perioperative adverse respiratory events in children who are obese. Anesthesiology. 2008;108:375-380. [pmid: 18292674].
38 Erermis S, Cetin N, Tamar M, Bukusoglu N, Akdeniz F, Goksen D. Is obesity a risk factor for psychopathology among adolescents?. Pediatr Int. 2004;46:296-301. [pmid: 15151546].
39 Strauss RS. Childhood obesity and self-esteem. Pediatrics. 2000;105:e15. [pmid: 10617752].
40 Spear BA, Barlow SE, Ervin C, et al. Recommendations for treatment of child and adolescent overweight and obesity. Pediatrics. 2007;120:S254-S288. [pmid: 18055654].
41 Schwimmer JB, Burwinkle TM, Varni JW. Health-related quality of life of severely obese children and adolescents. JAMA. 2003;289:1813-1819. [pmid: 12684360].
42 Skinner AC, Mayer ML, Flower K, Weinberger M. Health status and health care expenditures in a nationally representative sample: how do overweight and healthy-weight children compare?. Pediatrics. 2008;121:e269-e277. [pmid: 18195001].
43 Freedman DS, Khan LK, Serdula MK, Dietz WH, Srinivasan SR, Berenson GS. The relation of childhood BMI to adult adiposity: the Bogalusa Heart Study. Pediatrics. 2005;115:22-27. [pmid: 15629977].
44 Reeves GK, Pirie K, Beral V, Green J, Spencer E, Bull D. Cancer incidence and mortality in relation to body mass index in the Million Women Study: cohort study. BMJ. 2007;335:1134. [pmid: 17986716].
45 Renehan AG, Tyson M, Egger M, Heller RF, Zwahlen M. Body-mass index and incidence of cancer: a systematic review and meta-analysis of prospective observational studies. Lancet. 2008;371:569-578. [pmid: 18280327].
46 Flegal KM, Graubard BI, Williamson DF, Gail MH. Cause-specific excess deaths associated with underweight, overweight, and obesity. JAMA. 2007;298:2028-2037. [pmid: 17986696].
47 Krebs NF, Himes JH, Jacobson D, Nicklas TA, Guilday P, Styne D. Assessment of child and adolescent overweight and obesity. Pediatrics. 2007;120(Suppl 4):S193-S228. [pmid: 18055652].
48 American Dietetic Association. Position of the American Dietetic Association: individual-, family-, school-, and community-based interventions for pediatric overweight. J Am Diet Assoc. 2006;106:925-945. [pmid: 16812927].
49 U.S. Food and Drug Administration. Xenical approval letter. Accessed at www.fda.gov/cder/foi/appletter/2003/20766se5018ltr.pdf.
50 U.S. Food and Drug Administration. Orlistat OTC Information. www.fda.gov/cder/drug/infopage/orlistat_otc/index.htm.
51 U.S. Food and Drug Administration. Drugs@FDA. www.accessdata.fda.gov/scripts/cder/drugsatfda/index.cfm.
52 Bray GA. Medical therapy for obesity—current status and future hopes. Med Clin North Am. 2007;91:1225-1253. [pmid: 17964918].
53 Colman E. Anorectics on trial: a half century of federal regulation of prescription appetite suppressants. Ann Intern Med. 2005;143:380-385. [pmid: 16144896].
54 Shekelle PG, Morton SC, Maglione M, et al. Pharmacological and Surgical Treatment of Obesity. Evidence Report/Technology Assessment No. 103. AHRQ Publication No. 04-E028-1. Rockville, MD. Agency for Healthcare Research and Quality. 2004.
55 Caballero B. The global epidemic of obesity: an overview. Epidemiol Rev. 2007;29:1-5. [pmid: 17569676].
56 Keith SW, Redden DT, Katzmarzyk PT, et al. Putative contributors to the secular increase in obesity: exploring the roads less traveled. Int J Obes. 2006;30:1585-1594.
57 Viner RM, Cole TJ. Who changes body mass between adolescence and adulthood? Factors predicting change in BMI between 16 year and 30 years in the 1970 British Birth Cohort. Int J Obesity. 2006;30:1368-1374.
58 Neumark-Sztainer D, Wall M, Guo J, Story M, Haines J, Eisenberg M. Obesity, disordered eating, and eating disorders in a longitudinal study of adolescents: how do dieters fare 5 years later?. J Am Diet Assoc. 2006;106:559-568. [pmid: 16567152].
59 Woodard E. Media in the Home 2000: The Fifth Annual Survey of Parents and Children. Philadelphia. Anneberg Public Policy Center. 2000.
60 Stettler N, Signer TM, Suter PM. Electronic games and environmental factors associated with childhood obesity in Switzerland. Obes Res. 2004;12:896-903. [pmid: 15229327].
61 Crespo CJ, Smit E, Troiano RP, Bartlett SJ, Macera CA, Andersen RE. Television watching, energy intake, and obesity in U.S. children: results from the third National Health and Nutrition Examination Survey, 1988–1994. Arch Pediatr Adolesc Med. 2001;155:360-365. [pmid: 11231802].
62 Robinson TN. Reducing children’s television viewing to prevent obesity: a randomized controlled trial. JAMA. 1999;282:1561-1567. [pmid: 10546696].
63 Center for Disease Control and Prevention. Kids Walk to School. www.cdc.gov/nccdphp/dnpa/kidswalk/then_and_now.htm.
64 Participation in high school physical education—United States, 1991–2003. MMWR Morb Mortal Wkly Rep. 2004;53:844-847. [pmid: 15371967].
65 Berkey CS, Rockett HR, Gillman MW, Colditz GA. One-year changes in activity and in inactivity among 10- to 15-year-old boys and girls: relationship to change in body mass index. Pediatrics. 2003;111:836-843. [pmid: 12671121].
66 Striegel-Moore RH, Thompson D, Affenito SG, et al. Correlates of beverage intake in adolescent girls: the National Heart, Lung, and Blood Institute Growth and Health Study. J Pediatr. 2006;148:183-187. [pmid: 16492426].
67 Dietz WH. Sugar-sweetened beverages, milk intake, and obesity in children and adolescents. J Pediatr. 2006;148:152-154. [pmid: 16492420].
68 Briefel RR, Johnson CL. Secular trends in dietary intake in the United States. Ann Rev Nutr. 2004;24:401-431. [pmid: 15189126].
69 Ludwig DS, Peterson KE, Gortmaker SL. Relation between consumption of sugar-sweetened drinks and childhood obesity: a prospective, observational analysis. Lancet. 2001;357:505-508. [pmid: 11229668].
70 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
71 Flynn MA, McNeil DA, Maloff B, et al. Reducing obesity and related chronic disease risk in children and youth: a synthesis of evidence with “best practice” recommendations. Obes Rev. 2006;7:7-66. [pmid: 16371076].
72 Collins CE, Warren J, Neve M, McCoy P, Stokes BJ. Measuring effectiveness of dietetic interventions in child obesity: a systematic review of randomized trials. Arch Pediatr Adolesc Med. 2006;160:906-922. [pmid: 16953014].
73 Connelly JB, Duaso MJ, Butler G. A systematic review of controlled trials of interventions to prevent childhood obesity and overweight: a realistic synthesis of the evidence. Public Health. 2007;121:510-517. [pmid: 17467752].
74 Kitzmann KM, Beech BM. Family-based interventions for pediatric obesity: methodological and conceptual challenges from family psychology. J Fam Psychol. 2006;20:175-189. [pmid: 16756393].
75 Center for Disease Control and Prevention. BMI Calculator for Child and Teen: English Version. http://apps.nccd.cdc.gov/dnpabmi/Calculator.aspx.
76 Center for Disease Control and Prevention. Adult BMI Calculator. www.cdc.gov/nccdphp/dnpa/bmi/adult_BMI/english_bmi_calculator/bmi_calculator.htm.
77 Savoye M, Shaw M, Dziura J, et al. Effects of a weight management program on body composition and metabolic parameters in overweight children: a randomized controlled trial. JAMA. 2007;297:2697-2704. [pmid: 17595270].
78 Gillis D, Brauner M, Granot E. A community-based behavior modification intervention for childhood obesity. J Pediatr Endocrinol. 2007;20:197-203.
79 Reinehr T, de Sousa G, Toschke AM, Andler W. Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. Am J Clin Nutr. 2006;84:490-496. [pmid: 16960161].
80 Golley RK, Magarey AM, Baur LA, Steinbeck KS, Daniels LA. Twelve-month effectiveness of a parent-led, family-focused weight-management program for prepubertal children: a randomized, controlled trial. Pediatrics. 2007;119:517-525. [pmid: 17332205].
81 McCallum Z, Wake M, Gerner B, et al. Outcome data from the LEAP (Live, Eat and Play) trial: a randomized controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes. 2007;31:630-636.
82 Rooney BL, Gritt LR, Havens SJ, Mathiason MA, Clough EA. Growing healthy families: family use of pedometers to increase physical activity and slow the rate of obesity. WMJ. 2005;104:54-60. [pmid: 16138517].
83 Saelens BE, Sallis JF, Wilfley DE, Patrick K, Cella JA, Buchta R. Behavioral weight control for overweight adolescents initiated in primary care. Obesity Research. 2002;10:22-32. [pmid: 11786598].
84 Senediak C, Spence SH. Rapid versus gradual scheduling of therapeutic contact in a family based behavioural weight control programme for children. Behav Psychother. 1985;13:265-287.
85 Nemet D, Barkan S, Epstein Y, Friedland O, Kowen G, Eliakim A. Short- and long-term beneficial effects of a combined dietary-behavioral-physical activity intervention for the treatment of childhood obesity. Pediatrics. 2005;115:E443-E449. [pmid: 15805347].
86 Doyle AC, Goldschmidt A, Huang C, Winzelberg AJ, Taylor CB, Wilfley DE. Reduction of overweight and eating disorder symptoms via the internet in adolescents: a randomized controlled trial. J Adolesc Health. 2008;43:172-179. [pmid: 18639791].
87 Epstein LH, Roemmich JN, Robinson JL, et al. A randomized trial of the effects of reducing television viewing and computer use on body mass index in young children. Arch Pediatr Adolesc Med. 2008;162:239-245. [pmid: 18316661].
88 Celio AA. Early intervention of eating- and weight-related problems via the internet in overweight adolescents: a randomized controlled trial. Dissert Abstr Int. 2005;66:2299.
89 Reinehr T, Temmesfeld M, Kersting M, de SG, Toschke AM. Four-year follow-up of children and adolescents participating in an obesity intervention program. Int J Obes. 2007;31:1074-1077.
90 McCallum Z, Wake M, Gerner B, et al. Can Australian general practitioners tackle childhood overweight/obesity? Methods and processes from the LEAP (Live, Eat and Play) randomized controlled trial. J Paediatr Child Health. 2005;41:488-494. [pmid: 16150065].
91 Berkowitz RI, Wadden TA, Tershakovec AM, Cronquist JL. Behavior therapy and sibutramine for the treatment of adolescent obesity: a randomized controlled trial. JAMA. 2003;289:1805-1812. [pmid: 12684359].
92 Berkowitz RI, Fujioka K, Daniels SR, et al. Effects of sibutramine treatment in obese adolescents: a randomized trial. Ann Intern Med. 2006;145:81-90. [pmid: 16847290].
93 Chanoine JP, Hampl S, Jensen C, Boldrin M, Hauptman J. Effect of orlistat on weight and body composition in obese adolescents: a randomized controlled trial. JAMA. 2005;293:2873-2883. [pmid: 15956632].
94 Garcia-Morales LM, Berber A, Ias-Lara CC, Lucio-Ortiz C, Del-Rio-Navarro BE, Dorantes-Alvarez LM. Use of sibutramine in obese Mexican adolescents: a 6-month, randomized, double-blind, placebo-controlled, parallel-group trial. Clin Ther. 2006;28:770-782. [pmid: 16861099].
95 Godoy-Matos A, Carraro L, Vieira A, et al. Treatment of obese adolescents with sibutramine: a randomized, double-blind, controlled study. J Clin Endocrinol Metab. 2005;90:1460-1465. [pmid: 15613431].
96 Maahs D, de Serna DG, Kolotkin RL, et al. Randomized, double-blind, placebo-controlled trial of orlistat for weight loss in adolescents. Endocrin Pract. 2006;12:18-28.
97 Van Mil EG, Westerterp KR, Kester AD, Delemarre-van de Waal HA, Gerver WJ, Saris WH. The effect of sibutramine on energy expenditure and body composition in obese adolescents. J Clin Endocrinol Metab. 2007;92:1409-1414. [pmid: 17264187].
98 Freemark M, Bursey D. The effects of metformin on body mass index and glucose tolerance in obese adolescents with fasting hyperinsulinemia and a family history of type 2 diabetes. Pediatrics. 2001;107:E55. [pmid: 11335776].
99 Srinivasan S, Ambler GR, Baur LA, et al. Randomized, controlled trial of metformin for obesity and insulin resistance in children and adolescents: improvement in body composition and fasting insulin. J Clin Endocrinol Metab. 2006;91:2074-2080. [pmid: 16595599].
100 Love-Osborne K, Sheeder J, Zeitler P. Addition of metformin to a lifestyle modification program in adolescents with insulin resistance. J Pediatr. 2008;152:817-822. [pmid: 18492523].
101 Budd GM, Hayman LL, Crump E, et al. Weight loss in obese African American and Caucasian adolescents: secondary analysis of a randomized clinical trial of behavioral therapy plus sibutramine. J Cardiovasc Nurs. 2007;22:288-296. [pmid: 17589281].
102 Daniels SR, Long B, Crow S, et al. Cardiovascular effects of sibutramine in the treatment of obese adolescents: results of a randomized, double-blind, placebo-controlled study. Pediatrics. 2007;120:e147-e157. [pmid: 17576783].
103 Flodmark CE, Ohlsson T, Ryden O, Sveger T. Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Pediatrics. 1993;91:880-884. [pmid: 8474806].
104 Mellin LM, Slinkard LA, Irwin CE Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program. J Am Diet Assoc. 1987;87:333-338. [pmid: 3819254].
105 Ainsworth BE, Macera CA, Jones DA, et al. Comparison of the 2001 BRFSS and the IPAQ Physical Activity Questionnaires. Med Sci Sports Exercise. 2006;38:1584-1592.
106 Davis CL, Tkacz J, Gregoski M, Boyle CA, Lovrekovic G. Aerobic exercise and snoring in overweight children: a randomized controlled trial. Obesity. 2006;14:1985-1991. [pmid: 17135615].
107 Sung RY, Yu CW, Chang SK, Mo SW, Woo KS, Lam CW. Effects of dietary intervention and strength training on blood lipid level in obese children. Arch Dis Child. 2002;86:407-410. [pmid: 12023168].
108 Epstein LH, Valoski A, McCurley J. Effect of weight loss by obese children on long-term growth. Am J Dis Child. 1993;147:1076-1080. [pmid: 8213679].
109 DuBose KD, Eisenmann JC, Donnelly JE. Aerobic fitness attenuates the metabolic syndrome score in normal-weight, at-risk-for-overweight, and overweight children. Pediatrics. 2007;120:e1262-e1268. [pmid: 17974719].
110 Valdimarsson O, Linden C, Johnell O, Gardsell P, Karlsson MK. Daily physical education in the school curriculum in prepubertal girls during 1 year is followed by an increase in bone mineral accrual and bone width—data from the prospective controlled Malmö pediatric osteoporosis prevention study. Calcif Tissue Int. 2006;78:65-71. [pmid: 16467972].
111 Epstein LH, Valoski A, Wing RR, McCurley J. Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol. 1994;13:373-383. [pmid: 7805631].
112 Dietz W, Lee J, Wechsler H, Malepati S, Sherry B. Health plans’ role in preventing overweight in children and adolescents. Health Aff (Millwood). 2007;26:430-440. [pmid: 17339670].
113 Robert Wood Johnson Foundation. Program Areas Childhood Obesity. www.rwjf.org/programareas/programarea.jsp?pid=1138.
114 U.S. National Institutes on Health. ClinicalTrials.gov. www.clinicaltrials.gov.
115 Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults—the evidence report. National Institutes of Health. Obes Res. 1998;6(Suppl 2):51S-209S. [pmid: 9813653].
116 Gastrointestinal surgery for severe obesity. Proceedings of a National Institutes of Health Consensus Development Conference. Am J Clin Nutr. 1992;55:487S-619S. [pmid: 1733116].
117 Flynn MA, McNeil DA, Maloff B, et al. Reducing obesity and related chronic disease risk in children and youth: a synthesis of evidence with “best practice” recommendations. Obes Rev. 2006;7:7-66. [pmid: 16371076].
118 Collins CE, Warren J, Neve M, McCoy P, Stokes BJ. Measuring effectiveness of dietetic interventions in child obesity: a systematic review of randomized trials. Arch Pediatr Adolesc Med. 2006;160:906-922. [pmid: 16953014].
119 American Dietetic Association. Position of the American Dietetic Association: individual-, family-, school-, and community-based interventions for pediatric overweight. J Am Diet Assoc. 2006;106:925-945. [pmid: 16812927].
120 Schwartz RP, Hamre R, Dietz WH, et al. Office-based motivational interviewing to prevent childhood obesity: a feasibility study. Arch Pediatr Adolesc Med. 2007;161:495-501. [pmid: 17485627].
121 Reybrouck T, Vinckx J, Van den BG, Vanderschueren-Lodeweyckx M. Exercise therapy and hypocaloric diet in the treatment of obese children and adolescents. Acta Paediatr Scand. 1990;79:84-89. [pmid: 2316366].
122 Reybrouck T, Weymans M, Vinckx J, Stijns H, Vanderschueren-Lodeweyckx M. Cardiorespiratory function during exercise in obese children. Acta Paediatr Scand. 1987;76:342-348. [pmid: 3591302].
123 Reinehr T, Kersting M, Alexy U, Andler W. Long-term follow-up of overweight children: after training, after a single consultation session, and without treatment. J Pediatr Gastroenterol Nutr. 2003;37:72-74. [pmid: 12827009].
124 Meyer AA, Kundt G, Lenschow U, Schuff-Werner P, Kienast W. Improvement of early vascular changes and cardiovascular risk factors in obese children after a six-month exercise program. J Am Coll Cardiol. 2006;48:1865-1870. [pmid: 17084264].
125 Edwards B. Childhood obesity: a school-based approach to increase nutritional knowledge and activity levels. Nurs Clin North Am. 2005;40:661-6i. x. [pmid: 16324939].
126 Duffy G, Spence SH. The effectiveness of cognitive self-management as an adjunct to a behavioural intervention for childhood obesity: a research note. J Child Psychol Psychiatry. 1993;34:1043-1050. [pmid: 8408368].
127 Alexy U, Reinehr T, Sichert-Hellert W, Wollenhaupt A, Kersting M, Andler W. Positive changes of dietary habits after an outpatient training program for overweight children. Nutrition Research. 2006;26:202-208.
128 Kay JP, Alemzadeh R, Langley G, D’Angelo L, Smith P, Holshouser S. Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism. 2001;50:1457-1461. [pmid: 11735093].
129 Cole TJ. The LMS method for constructing normalized growth standards. Eur J Clin Nutr. 1990;44:45-60. [pmid: 2354692].
130 Center for Disease Control and Prevention. A SAS Program for CDC Growth Charts. www.cdc.gov/nccdphp/dnpa/growthcharts/resources/sas.htm.
131 Graf C, Koch B, Bjarnason-Wehrens B, et al. Who benefits from intervention in, as opposed to screening of, overweight and obese children?. Cardiol Young. 2006;16:474-480. [pmid: 16984699].
132 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
133 Bryant MJ, Lucove JC, Evenson KR, Marshall S. Measurement of television viewing in children and adolescents: a systematic review. Obesity Reviews. 2007;8:197-209. [pmid: 17444962].