# Discussion

## Summary of Review Findings

We evaluated 13 behavioral intervention trials conducted in 1258 overweight or obese children and adolescents aged 4 to 18 years. We also evaluated seven trials that combined pharmacological treatments (sibutramine or orlistat) with behavioral interventions in a total of 1294 very obese adolescents aged 12 to 18 years (plus an additional three trials of metformin in 145 very obese adolescents at increased risk for diabetes) (See Summary of Evidence Table 9). With the exception of four behavioral intervention trials83,84,103,104 and one pharmacological trial each for sibutramine91 and metformin,98 all of the trials reviewed for this report were newly available since our previous USPSTF review. Given the increased volume of new, relevant trials, we were able to focus on trials addressing the USPSTF’s primary question about whether there are treatments accessible by primary care that are effective (i.e., work better than no or minimal treatment). As such, we did not re-address the comparative effectiveness trials considered in the previous report. These comparative effectiveness trials provided little data that would elucidate the absolute effectiveness of obesity treatment programs since they largely compared unique intervention components that were not repeated by other studies.2

### Behavioral Interventions

Our report found that comprehensive medium- to high-intensity behavioral interventions for obese children and adolescents aged 6 years and older can effectively produce short-term improvements in weight and perhaps in adiposity. The amount of absolute or relative weight change associated with these interventions is generally modest (1.9 to 3.3 kg/m^2^ difference in mean BMI change 6 to 12 months after starting treatment, compared with controls). For an 8-year-old boy or girl, the largest BMI difference (3.3 kg/m^2^) would translate to about 13 pounds (based on 50^th^ percentile for height for ages 8 and 9, approximately 2 inches of growth). For a 12-year-old boy or girl, this would translate to 17 to 18 pounds difference under the similar growth assumptions (50^th^ percentile for height at ages 12 and 13). In girls aged 16 years this BMI difference would translate to about 19 pounds, while for boys aged 16 years the difference would be between 22 and 23 pounds using the growth assumptions based on the 50^th^ percentile for ages 16 and 17. Very limited evidence suggests that these improvements can be maintained over the 12 months following treatment. The intervention effects possible with behavioral interventions, particularly medium- to high-intensity comprehensive interventions, appear adequate to improve adiposity. Limited evidence suggests that reductions in cardiovascular risk factors (e.g., blood pressure, lipids, blood glucose, or insulin resistance) do not routinely occur, but are possible particularly for insulin resistance measures in the setting of medium- to high-intensity comprehensive interventions. Firm conclusions are difficult to draw since these outcomes were not consistently reported in the behavioral intervention literature, with no more than four studies reporting any one risk factor. Since children and adolescents included in behavioral interventions tended to be less obese than those in pharmacological treatment trials, they might also be less likely to have elevated cardiovascular or diabetes risk factors, and thus these difference would be difficult to detect.

Medium-to-high interventions were conducted in specialty health care (such as pediatric obesity referral clinics) or similar settings. While the interventions would likely not be feasible for implementation in a primary care setting, they would are feasible for a health plan to offer, thus making them potentially available for referral from primary care. Lower intensity comprehensive (or focused) interventions that might be feasible for primary care had a more modest, less consistent benefit on BMI. Further research on these less intensive, more feasible interventions is greatly needed.

Behavioral weight management interventions also have few harms. Based on limited study reporting, we found no evidence of adverse effects on growth, eating disorder pathology, or mental health. These findings are consistent with data from several noncomparative studies, including one that followed 158 children for 10 years and found that weight loss was not related to growth in height in a multivariate model controlling for child age, sex, baseline height, baseline percent overweight, and midparental height.108 We also found little risk of exercise-induced injuries from behavioral interventions. Although these findings are reassuring, they are limited by incomplete reporting, given that fewer than half of the behavioral intervention trials specifically reported on any potential adverse effects.

While available trials did allow us to judge the effects of these interventions had on weight loss, it is still unclear what the important elements of effective behavioral weight management programs are, beyond the apparent benefit of more intensive interventions that had more hours of participant contact. Most treatment programs focused on supporting healthy lifestyle. While some trials in adolescents had the explicit goal of weight reduction, most trials generally aimed at reducing participants’ relative level of overweight through limiting weight gain as the child grew. Many trials utilized behavioral management techniques such as teaching parents and/or children about goal-setting, problem-solving, relapse prevention, and managing their environment to encourage healthy lifestyle.

Physical activity is clearly an important factor in altering the balance between caloric intake and expenditure, and therefore has in important role to play in weight loss interventions. All but three of the interventions included exercise sessions or instruction in behavioral management principles targeting exercise. It appears that organized exercise sessions increase the likelihood of treatment success, but this could not be determined conclusively since programs with organized exercise also tended to be more intensive programs with more hours of contact. Regardless of whether children and adolescents exercise under the supervision of interventionists or on their own time, improved physical fitness is likely beneficial even if it does not increase weight loss.109,110

All programs targeting younger children involved their parents or guardians, since adults usually control most of younger children’s food intake. Since all of the trials in younger children included responsible adults, however, we have no empirical basis for quantifying the importance of parental involvement in this age group. The one trial in adolescents that included parental involvement was effective. Since these interventions included many components, however, it was impossible to isolate the specific effect of parental involvement in interventions targeting adolescents.

### Combined Pharmacological and Behavioral Interventions

Pharmacological adjuncts to behavioral interventions have been studied only in obese adolescents aged 12 to 18 years who meet adult criteria for class II obesity (mean BMI of 35 to 40 kg/m^2^ at trial entry). These trials study the additional effect of the pharmacological agent to behavioral therapy alone, in contrast to the purely behavioral trials that compare the effects of behavioral interventions to outcomes among untreated or minimally treated controls. Treatments with pharmacological agents (sibutramine and orlistat) delivered in combination with behavioral interventions over 6 to 12 months have been studied, but longer term results after treatment discontinuation were not available for any of the pharmacological treatment trials. This is an important limitation in our overall knowledge about their beneficial effects. Three small trials in a small number of very obese adolescents (n=145) at high risk for type 2 diabetes mellitus examined the impact of metformin on glucose tolerance, insulin sensitivity, and BMI. These results are preliminary, however, and are not directly applicable to the general population of obese adolescents.

Combined pharmacological (sibutramine or orlistat) and behavioral interventions significantly reduced BMI (compared with placebo combined with the same behavioral interventions) with limited data suggested greater impact with longer treatment (6 vs. 12 months). Additionally, these trials found a greater impact from sibutramine compared with orlistat. In the largest single study, orlistat treatment appeared to primarily attenuate weight gain, but this could be due to the behavioral intervention component of the orlistat trial being ineffective. In this multi-center trial, all 32 centers had the freedom to use their own approach to the trial’s behavioral intervention, with no assessment of delivery.93 Therefore, the quality or intensity of the behavioral interventions across the entire trial is impossible to gauge. Sibutramine treatment for 12 months achieved the largest weight impact of any combined pharmacological and behavioral intervention tests. After 12 months of sibutramine plus a behavioral intervention, trial participants receiving 10 to15 mg per day of sibutramine treatment plus a behavioral intervention decreased their BMI 2.9 kg/m^2^, corresponding to an average weight reduction of 6.5 kg (14 pounds). This is compared with a BMI reduction of 0.3 kg/m^2^, corresponding to a weight gain of 1.9 kg (4.2 pounds), among trial participants receiving a behavioral intervention plus placebo. The difference between the sibutramine and placebo groups in this trial is similar in magnitude to that found by the behavioral intervention described as a best-case example in a specialty care setting.77 Direct head-to-head comparisons of pharmacological agents in combination with the same, proven behavioral interventions would allow us to confirm our impressions based on indirect comparisons across different studies. Studies comparing these combined treatments with effective medium-to-high intensity behavioral interventions would also be very valuable.

Combined pharmacological and behavioral interventions generally measured their impact on cardiovascular risk factors (e.g., blood pressure, lipids, insulin resistance, glucose) and waist circumference, but did not generally test their impact on adiposity in addition to BMI. Waist circumference in those receiving sibutramine was reduced in most of the sibutramine trials, 7 to 8 cm compared with 2 to 3 cm reductions in controls. Participants receiving orlistat reduced their waist and hip circumference (2.7 and 1.5 cm respectively), compared with controls (0.9 and 0.1 cm reductions). Improvements in HDL cholesterol, triglycerides, and glucose tolerance measures (serum insulin and HOMA) were reported in the sibutramine treatment group in the largest multicenter trial (n=498), but not in smaller studies or in the orlistat studies. While trial participants receiving sibutramine were consistently more likely to develop elevated heart rates than placebo-treated participants, they had similar rates of discontinuation due to this side effect. Systolic or diastolic blood pressure (or both) were elevated in about half of the trials. These differences, however, were small in magnitude and are of unknown clinical significance. Mild-moderate gastrointestinal side effects (most commonly oily spotting, evacuation, abdominal pain, fecal urgency, or flatus with discharge) occurred in 20 to 30 percent of patients taking orlistat and 9 percent reported fecal incontinence. Few participants (2 percent) discontinued treatment due to these side effects, although 35 percent dropped out before the trial ended. The impact gastrointestinal effects would have on treatment adherences outside a trial setting is unclear.

Limited evidence also suggests no adverse effects on growth or maturation for sibutramine or orlistat. Serious adverse effects were also uncommon. Although sibutramine appears to have a larger effect on weight than orlistat, based on indirect comparisons, the FDA has only approved orlistat for use in pediatric populations (aged 12 years or older). Both drugs have side effects that must be taken into account when considering treatment for an individual patient. While orlistat has a higher rate of adverse effects, the nature of these effects may be less clinically significant than those seen with sibutramine. These risks should also be weighed against the fact that both drugs lack evidence of persistence of weight reduction after active treatment ends.

### Long-Term Maintenance

Evidence of treatment maintenance is quite limited in behavioral intervention trials, and nonexistent in trials of pharmacological treatments. Although this review focused on controlled trials, additional observational evidence sheds some light on long-term effectiveness of behavioral intervention program and on the natural history of obesity in children. An observational study of a behavioral intervention by Epstein and colleagues, for example, reported on 10-year followup of four comparative effectiveness treatment trials in children 6 to 12 years of age that were conducted between 1981 and 1986 in an academic multi-disciplinary specialty obesity treatment setting.111 This study did not meet our inclusion criteria because it had no control group for comparison purposes. While this study did report that 30 percent of their participants were not obese at 10-year followup, it is difficult to determine if this is a higher rate of change than would be seen in a general population of obese children. Freedman and colleagues’ large scale observational study of children in Bogalusa, Louisiana43 found that 22.8 percent of 9 to 11 year olds who were at or above the 95th percentile were no longer obese an average of 16 years later, which is lower than the 30 percent found by Epstein and colleagues and may be a reflection of both natural history and treatment. Another retrospective observational study from the UK found that 39.3 percent of obese 16-year-olds were no longer obese at age 30, which is a higher rate of remission than that reported by the Epstein study. Several differences between the populations and settings, as well as uncertainty about what proportion were treated in these naturalistic studies, limit drawing definitive conclusions about whether children undergoing treatment programs are more or less likely to be obese at long-term followup. Limited as it is, the results from trials comparing treated and control participants are still our best evidence. Thus, longer-term followup of participants from existing (and future) trials could be extremely informative.

### Applicability to Real-World Settings

Two of the behavioral intervention programs specifically addressed the use of very low-intensity interventions (approximately 4 hours of total intervention time) that could be integrated into primary care.81,83 One of these improved short-term weight loss83 and could be feasible for implementation in some primary care practices. This program relied on support staff to provide adjunctive care through mail and phone counseling, thus relieving the primary care provider of some of the burden of conducting the intervention. Dissemination research would be needed to truly determine wide-spread feasibility.

Higher-intensity programs conducted in specialty care settings may also be feasible for many health care settings, perhaps at little extra cost, including adapting the detailed protocols developed for the trials included in this review. For example, the comprehensive and effective Bright Bodies weight management program developed by Savoye and colleagues77 was facilitated by a registered dietitian or social worker and an exercise physiologist. A team of professionals in these or related fields would likely have the requisite training to conduct this type of program without extensive additional training. Third-party payment for these types of programs or indication of their cost-effectiveness would assist their uptake in the real world.

Considering the BMI levels and ages of study participants, currently studied treatments cannot be clearly applied to the entire population of overweight and obese children and adolescents. We found no evidence addressing weight management approaches in overweight or obese children under 4 years old. Additionally, while overweight and obesity are about equally prevalent among older children and adolescents in the general population,23 behavioral intervention trials were conducted wholly or mostly in obese children and adolescents. Combined pharmacological and behavioral interventions were applied only to very obese adolescents. As recommended by others,11 behavioral interventions should be the appropriate first-line approach for overweight children and adolescents, although current studies do not clarify their use or impact in non-obese children and adolescents. Available evidence does not illuminate whether those who are overweight (but not obese) have as high a need for treatment or if they would respond similarly to weight management interventions.

The adolescents in whom effective pharmacological treatments have been studied are in the upper percentiles of the BMI range or meet criteria for Class II or III obesity in adults, and thus represent a small fraction of the 16 percent of girls and 18 percent of boys aged 12 to 19 who are obese. Recent data estimates that only 1 to 3 percent of 13- to 17-year-old girls and 3 to 5 percent of 13- to 17-year-old boys have BMIs that are at or above the 99^th^ percentile for their age and sex.22 Based on evidence, the use of pharmacological treatment would be primarily limited to this small group adolescents.

While pharmacological treatments have been studied in multi-site clinical trials, which enhances their applicability, treatment adherence outside of the trial setting and longer term weight impacts remain unclear. Adolescents choosing to participate in either behavioral or combined behavioral-pharmacologic treatment trials may also be more or less likely than the average overweight or obese adolescent to respond to the intervention provided. They may have higher levels of motivation to lose weight, for example, and therefore do better than the average adolescent. Conversely, they may also have a greater number of failed weight loss attempts, which may make them less likely to succeed than the typical overweight or obese teen in the community. The supports provided in a typical trial may also exceed those provided in a usual treatment setting.

### Applicability to Vulnerable Populations

Research on treating obesity must be considered in terms of its applicability to the general population of obese children and adolescents and, in particular, those bearing the greatest burden due to higher prevalence of obesity. These vulnerable groups include racial and ethnic minorities23,26 and those within lowest income groups,29 both of whom disproportionately bear the brunt of the obesity epidemic.

Minority involvement in addressing the obesity epidemic will be essential, and as such, their involvement in obesity research is critical. Among the behavioral trials, only a few reported that at least 10 percent of their sample was Hispanic77,83,86 or Black.77,88 One of these trials, whose sample was 24.7 percent Hispanic and 38.5 percent Black, reported that there were no differences in any outcome measure between ethnic groups.77

We found no evidence to suggest that medication treatment is more or less effective in Black or Hispanic than in White youth. Black and Hispanic youth were present in the samples of most of the medication trials, although only three92,93,98 examined differential impact of treatment by ethnicity: a large-scale trial of sibutramine,92 a large-scale trial of orlistat,93 and a small trial of metformin.98 None of these trials found that race had an effect on response to treatment. None of these trials, however, was designed to detect differences among race and ethnic groups and thus further studies among racial and ethnic minority groups are warranted.

Little was reported about the socioeconomic status of participants in any of the studies. Given the lack of universal access to health care, however, programs delivered through health care settings could be out of reach of many. Obesity prevention programs conducted in places such as schools3 could ostensibly reach those without access through healthcare systems.

## Review Limitations

### Limitations in the Body of Evidence

The quality of research on treating child and adolescent obesity has improved substantially our previous USPSTF review that enumerated concerns about the childhood obesity treatment literature, specifically regarding behavioral interventions. These concerns were echoed by others and included small sample sizes, high attrition (among other quality issues), less than ideal outcome measures, and highly heterogeneous treatment approaches.10 While several of the newly published trials have over 100 participants, retention remains somewhat problematic, with most reported retention below 90 percent. However, several trials reporting retention lower than 90 percent used statistical methods to attenuate or examine the effects of missing data. Outcome measurement has improved—almost all of the newer trials reported raw BMI scores or BMI SDS and all directly measured their participants rather than relying on self-report. A lingering quality issue is that the blinding procedures for treatment allocation and outcomes assessment were often not described. Research would also be improved with more explicit reporting on intervention fidelity and how the outcomes affected other outcomes (both harms and benefits, such as comorbidities). Finally, while treatment trials remain quite heterogeneous, it is hoped that better reporting and growth in the research base, including replication of effective intervention studies, will eventually allow determination of effective components of behavioral interventions.

While methods and reporting have improved and the number of studies has increased, providing summary measures of expected treatment effects is still very difficult due to the heterogeneity in the behavioral intervention literature (e.g., populations, intervention intensity, settings, treatment components, types of outcomes assessed). Thus, our findings and meta-analysis should be interpreted with caution. While it appears that treatment comprehensiveness and intensity are important, other factors, such as treatment setting and age, also appear to be important and may not have been fairly considered in our analyses, since we did not have enough data to conduct analyses stratified by these factors.

While larger trials of pharmacological treatments are quite new (2005 and 2006), the available treatment data for these approaches remains limited. There are only two weight-loss medications studied (sibutramine and orlistat), with few randomized trials overall, and only one large-scale trial of each of the medications. No trials were conducted among children age 11 years or younger, so no conclusions can be drawn regarding efficacy or safety for that age group. We found no data on maintenance of treatment effect or safety after the 6 to 12 months of active treatment ended. Additionally, these medication’s long-term effects have not been sufficiently documented, so longer follow up remains very important. Medication use may have either a positive or negative effect on long-term maintenance of weight changes, compared with exclusively behavioral approaches, so longer follow-up is very important. While we found sibutramine and orlistat each had one large-sample trial, these trials were not large enough to detect rare, but serious, adverse effects. The high variability across trials in intensity and possible variability in intervention fidelity for behavioral interventions hampered our ability to determine both the combined and independent effect of the medication.

### Limitations in Our Approach

A limitation to our meta-analysis is that we combined different measures of weight change that have different underlying assumptions and distributions. We attempted to minimize the effects of this by analyzing BMI change whenever it was available, so the majority of the trials did use a common metric. Qualitative examination of the forest plots indicated no obvious bias in the trials that used measures other than BMI change, and the pattern of results was similar with the meta-analysis was limited to studies the reported BMI or BMI change. Because change in BMI has a different meaning for children of different ages, it might have been preferable to analyze change in BMI SDS, which is adjusted for age and sex. However, many authors did not report BMI SDS. Given that this requires special software or look-up data to calculate BMI SDS, it was not feasible to expect authors to provide this data upon request. Further, experts still have not determined if there is a single best measure for weight management studies in children and adolescent.15

We did not include comparative effectiveness trials in this updated review, as our primary goal was to determine whether treatment worked and the size of the effects compared with no treatment. As such, our review did not include all studies that others might consider relevant. Future reviews may consider comparative effectiveness for populations and interventions viewed to be established as efficacious.

Our examination of other beneficial outcomes was limited to studies that met our general inclusion criteria, including reporting some measure of weight change 6 months or more after the baseline assessment. Given the primary purpose of this review (focus on weight management), we did not include trials that reported other beneficial outcomes without some measure of weight change, and therefore might have missed some reports of other beneficial outcomes.

We did not address the impact of population-based prevention programs on weight reduction in overweight or obese children. These programs are primarily targeted at preventing obesity, but since some children participating in these programs are already overweight or obese when they begin, it would be useful to know the degree to which overweight and obese children benefit. It would also be useful to know whether overweight and obese children suffer deleterious effects of such programs, such as increased dieting, increased teasing, poorer self-esteem, or other quality of life detriments.

## Contextual Issues/Next Steps

The research we reviewed is generally consistent with a recently proposed model of a stepped-care approach to weight management treatments that increases intensity (and treatment-associated risk) according to degree of excess weight, age/maturation, health risks, and motivation.11,40 This stepped-care model, which has been recommended by the Expert Committee (which was convened by the American Medical Association [AMA] and co-funded in collaboration with the Department of Health and Human Services’ Health Resources and Services Administration [HRSA] and the CDC), delineates approaches that range from simple preventive messages aimed at younger children and those who are not overweight, to weight management approaches that increase in intensity as the child becomes more obese or has more weight-related health problems. Behavioral interventions are seen as a best first-line treatment, and our review found that they can be effective and safe when delivered to obese children aged 4 years and older.

A broader approach to obesity care may be required to have a definite impact on childhood obesity within the health care system. These efforts should include connecting the health care system with efforts in the broader community. Dietz and colleagues112 have proposed a model of care in which self-management by the patient or parent is considered central. In order to support self-management, the health care system should make decision support tools available to office-based providers, teach providers to help children and adolescents with excess weight and their families to make changes and access helpful resources, and help increase patient confidence in their ability to make changes. The Expert Committee has recommended a complementary office-based system that relies on a network of health system resources (such as pediatric dietitians or behavioralists) and referral resources (including community resources and specialty treatment settings with access to a multidisciplinary team experienced with childhood obesity).11 Both groups recognize that health plans also have a role to play in changing the environment, particularly to support obesity prevention, through partnerships with schools and community organizations.8,112

While this report focuses on the effectiveness and benefits of treatments in children and adolescents who are already overweight or obese, the challenge of achieving significant weight loss (and the uncertainty as to how well any weight reduction can be maintained) reaffirms the importance of obesity prevention. Obesity prevention is a critical component of the full breadth of a public health approach to overweight and obesity among American children and adolescents. Preventive approaches emphasize helping children and adolescents develop lifelong healthy habits to prevent the development of overweight or obesity during childhood and into adulthood. Obesity prevention should be conceptualized broadly to include environmental modifications to encourage healthier lifestyles, as well as health promotion campaigns in schools, communities, and health care settings. Given the relatively small effects seen in most behavioral interventions, and the fact that more invasive interventions are only appropriate for a small portion of the population, prevention programs are likely to be the most effective agents in slowing the growth of childhood obesity.

Calling for public health action at its broadest and most inclusive level, the Institute of Medicine (IOM) created a set of 10 integrated recommendations for families, schools, communities, the public sector, and the private sector to prevent the development of obesity in the majority of children and adolescents in the United States.12 The IOM recommendation for the healthcare system is that clinicians engage in the prevention of childhood obesity, with support from professional organizations, insurers, and accrediting groups, for both individual and population-based prevention. Given this emphasis, but a lack of evidence for effective healthcare system-based prevention approaches in the past,7 it will be important for the next USPSTF update to consider whether there is sufficient evidence to evaluate primary care’s role in primary prevention.

Given the importance of child and adolescent obesity worldwide, this is an extremely active area for ongoing research, guideline development, and implementation of policies that affect all aspects of society. Federal agencies and private foundations, such as the Robert Wood Johnson Foundation,113 have put very high priority on funding obesity research and disseminating findings. We identified over 20 ongoing clinical studies that investigate the broad spectrum of issues related to obesity in children and adolescents.114 Thus, this issue will require frequent revisiting for those intending to make policy and clinical decisions based on the most up-to-date thinking and evidence available.

## Future Research

Based on this review, we have several recommendations for funding additional research in obesity treatment. These recommendations also reflect input from our expert reviewers. The relative importance of funding treatment studies (as compared to prevention studies) is beyond the scope of this report, but bears consideration.

Childhood overweight has been the focus of considerable research in recent years, and certainty in the short-term effectiveness of medium- to high-intensity behavioral intervention programs is emerging. Replication of behavioral intervention trials (particularly given their heterogeneity of treatment components) is needed to confirm the benefits of these programs, to estimate their likely effects in real-world settings, to determine their feasibility and sustainability, and to report on cost-effectiveness. Understanding important components of behavioral interventions is also an ongoing need, including determining whether specific diet or physical activity approaches or general skills training in making and sustaining behavior change are critical. To help clarify which components of these programs are most important, and for which age groups, researchers should provide consistent and detailed descriptions of treatment components, including information on intensity and duration of treatment components. In addition, trials should report on program adherence, including receipt of treatment, quality of delivery, participant responsiveness, and whether any of these factors varied by subgroups. This would enable reviewers to distinguish small group differences due to difficulty in adhering to the treatment program from ineffectiveness of the program as designed for that subgroup. Consistency in reporting of weight-related outcomes is also crucial for analyzing the literature as a body and to allow statistical pooling, as well as potentially exploring the importance of treatment components statistically. Future meta-analyses would be improved if all studies consistently reported at least the means and standard deviations for these weight-related measures: BMI, change in BMI, BMI SDS, and change in BMI SDS. Similarly, all studies and trials of weight management treatments should systematically assess and report on possible harms, on changes in weight-related co-morbidities, on changes in psychosocial and related outcomes, and should monitor and report other unanticipated effects, particularly associated with non-behavioral treatments. Additionally, once it becomes clear to what degree multi-factorial treatments can resolve weight-related co-morbidities, it will be important to investigate whether certain intervention components (e.g., increased physical activity, fat-mass reduction, and modification of dietary macronutrient or micronutrient intakes) are the key drivers of health benefits.

Longer-term followup is needed to confirm maintenance of treatment and to assess longer term risks or harms, preferably with outcomes measured at the end of treatment and at fixed follow-up points, such as 1, 2, and 5 years from baseline. As further research elucidates both short- and long-term health benefits, more appropriate clinical treatment planning will be possible, particularly for children and adolescents who are not experiencing immediate weight-related health consequences. There is a particular need for more information on the maintenance of treatment effect in youth taking sibutramine and orlistat for weight loss. Followup data at least 1 year, and ideally up to 3 years, after pharmaceutical treatment has ended is sorely needed. Given our limited certainty about the quality of the behavioral interventions delivered within current pharmaceutical trials, exploring whether greater treatment effects are possible when pharmacotherapies are combined with proven, effectively delivered behavioral interventions could be important. As effective treatment data accrue, it would also be useful to explore whether different subgroups of patients respond better to different types of treatments within a single modality (e.g., different medications or behavioral approaches), different treatment modalities, (behavioral interventions as opposed to pharmacotherapies), or different treatment combinations (e.g., behavioral only vs. behavioral with pharmacotherapy).

More studies are needed in understudied populations: in minority children and adolescents; of behavioral interventions in younger children (5 years and under); and of behavioral interventions in children who are overweight but not obese. Future studies should also evaluate specific approaches that have been advocated by experts for treating excess weight in childhood and adolescence. For example, the Expert Committee’s recommendation11 of a stepped care approach, which is pragmatic and evidence-informed, but has never been tested through formal research. We also found no controlled trials on more aggressive dietary treatments, such as protein-modified fasts, which may be of use in very obese children for whom more invasive treatments would be considered. It could be beneficial to compare aggressive dietary treatments to both standard weight management approaches and pharmacological approaches.

The health effects of childhood obesity (particularly independent of the long-term increased risk of adult obesity and its attendant morbidity) are still not sufficiently understood. Researchers and clinicians are left with the question, “What are the best ways to improve the current and future health of obese, as well as overweight, children and adolescents?” In addition, a broader understanding of the prevalence and implications of obesity-related disorders in childhood, and of the natural history of overweight and obesity, are needed to answer this question. Documenting changes in BMI (growth trajectories) and their determinants—in those who are underweight, normal weight, overweight, and obese, beginning at various time points in childhood and adolescence, and considering males and females and different racial/ethnic subgroups separately—would be very useful. A better understanding of the natural history of this condition will be important to complement prevention and intervention efforts.

Finally, just as the portability of research-tested interventions into the real world must be tested in dissemination trials, it is also important for researchers to make efforts to describe results and implications in real-world terms that can be understand and used by policy makers and the general public. Being clear about how much weight loss a child may be expected to experience, or how much weight gain is prevented, is crucial. It is very useful to lay readers if researchers provide illustrative examples and ranges of outcomes in terms that the public understands, such as pounds (in the United States) or kilograms. To the extent possible, it is important for researchers to translate clinical outcomes such as changes in blood pressure and fitness levels into terms that demonstrate whether these changes are likely to have any real impact on a child’s health. Ongoing epidemiologic research within children and adolescents who have made favorable weight-related changes to help establish the health impact of various degrees of weight change on short-term and longer term health outcomes will be critical in this regard.

## Conclusions

Considerable headway has been made in the past several years in determining the effectiveness of treatments for obese children and adolescents. Behavioral interventions have been studied in children and adolescents aged 4 to 18 years, while adjunctive pharmacological treatments have been studied only in highly obese adolescents. Behavioral interventions have demonstrated beneficial effects on weight compared with no or minimal treatment. Effects are small to moderate after 6 to 12 months of treatment. Some evidence supports more robust effects on weight from medium- to high-intensity comprehensive interventions, with weight changes in some instances similar to those achieved through pharmacological treatments combined with behavioral interventions. Limited evidence supports maintenance of behavioral treatment effects for at least 12 months after treatment ends. Effective behavioral interventions address healthy lifestyle, utilize behavioral management techniques, provide physical activity as part of treatment, and, in children under aged 12 years, involve parents. Sibutramine plus a behavioral intervention can lead to moderate weight loss over 12 months of treatment in very obese adolescents, with smaller treatment effects from orlistat treatment. The evidence base for pharmacological treatments is limited to one large multicenter study for each type of medication, along with a small number of other trials. No trials provide follow-up after treatment has been discontinued.

Clarifying the contribution of various treatment approaches in achieving short-term and long-term health benefits (as well as weight loss) is imperative in all ages of children and adolescents and across all levels of overweight and obesity. Since most children and adolescents who are overweight or obese will likely be best served by behavioral interventions, further research in this area is imperative. Thoughtful planning by funding agencies to support studies that elucidate the role of common behavioral treatment components across a range of overweight subjects and settings would be very beneficial. Given the limited role that treatment can play in the obesity epidemic, research to further our understanding of obesity prevention programs in children and adolescents must also be a high priority.

Table 9 Overall summary of evidence

No. of studies | Design | Limitations | Consistency | Applicability | Overall Quality | Summary of Findings
KQ1. Short-Term (6- to 12-month) Weight Outcomes
Behavioral Interventions
11 | 10 RCTs, 1 CCT | Heterogeneity along many dimensions, including age of participants, baseline degree of excess weight, intervention approach, setting, country, treatment intensity, time to followup; high attrition in many trials | Fair: All medium- or high-intensity, comprehensive programs were consistently effective; some low- and very low-intensity trials were effective, but are so heterogeneous that patterns cannot be identified to explain the inconsistencies. | Fair: Two trials conducted in primary care with primary care samples, and a third was conducted in primary care but used a sample referred for help with obesity. Higher intensity treatments could be feasible for health care systems to offer, but may not be broadly available. | Fair to Good: 5 rated fair quality and 6 rated good quality | Comprehensive moderate- to high-intensity interventions resulted in a 1.9 to 3.3 kg/m^2^ difference in mean BMI change in children aged 6 and older, 6–12 months after starting treatment, compared with controls. For a 16-year-old girl, the largest BMI difference (3.3 kg/m^2^) would translate into a 20 pound difference at the end of treatment. Low and very low-intensity programs showed inconsistent results and generally had smaller effects.
Phamacological + Behavioral Interventions
Sibutramine:5 Orlistat: 2 Metformin: 3 | RCTs | Only one large-scale trial for each of sibutramine and orlistat; fairly high attrition in large trials; only studies in very obese (adult class II obesity) 12 to 18-year-olds; metformin has been studied only among selected populations at high risk for diabetes in small, fair-quality trials | Good for sibutramine, Fair for orlistat, fair to poor for metformin | Fair: Most trials conducted in settings feasible for primary care-referral (specialty weight loss or research clinics); metformin results are applicable only to selected populations and were a secondary outcome of treatment aimed at blood sugar regulation. | Good for sibutramine and orlistat; Fair for metformin | Sibutramine: 12 to 18-year-olds receiving 12 months of sibutramine plus a behavioral intervention showed an average BMI difference of 2.6 kg/m^2,^ compared with those receiving a placebo, and a weight difference of 19 pounds. Orlistat: Mean BMI was 0.85 kg/m^2^ less in orlistat users after treatment, compared with those receiving the behavioral intervention only in large, good-quality trial. Metformin: Metformin users showed greater reductions in BMI and BMI SDS after 6 months of treatment in two small trials but no significant BMI difference in the third trial
KQ2. Maintenance of Weight Outcomes
Behavioral Interventions
4 | 2 RCTs, 2 CCTs | Only four trials, all different from each other on dimensions listed above; | Fair | Fair: one was conducted in primary care, but only one of four conducted in the US and two of four were older trials (1993 and 1987) | Fair: 3 trials rated fair quality, 1 trial rated good quality. | Three of four trials found that improvements in weight were maintained 12 months or more after treatment ended. Two trials reported 1.7 kg/m^2^ greater weight loss in treatment than control groups, and one very low-intensity primary care-based trial reported no group differences in BMI. A trial reporting change in percent overweight found that it declined by 9.8 percentage points more in the intervention than control group.
Pharmacological + Behavioral Interventions
No evidence
KQ1a & KQ2a: Other beneficial outcomes of weight management interventions
Behavioral Interventions
13 | 11 RCTs, 2 CCTs | Other beneficial outcomes inconsistently reported; some outcomes reported in only one or a few trials; same outcomes measured differently in different trials. | Fair to poor | Fair: Two trials conducted in primary care with primary care samples, and a third was conducted in primary care but used a sample referred for help with obesity | Fair to Good: 8 rated fair quality, 5 good quality | Other outcomes reported included adiposity, cardiovascular risk factors, physical fitness, behavioral outcomes, and psychosocial outcomes. Results in all areas were mixed, but the outcomes that were most likely to show greater improvement in the intervention group were measures of adiposity (5 of 5 found group differences), insulin-related measures (2 of 3 found group differences), and measures of physical fitness (2 of 3 found group differences).
Pharmacological + Behavioral Interventions
Sibutramine: 5 Orlistat: 2 Metformin: 3 | RCTs | Only one large-scale trial for each of sibutramine and orlistat; fairly high attrition in large trials; only studies in very obese (adult class II obesity) 12 to 18-year-olds; metformin has been studied only among special populations in small, fair-quality trials | Good for sibutramine, Fair for orlistat, metformin | Fair: Most trials conducted in settings feasible for primary care-referral (specialty weight loss or research clinics); metformin results are applicable only to selected populations | Good for sibutramine and orlistat; Fair for metformin | Sibutramine: In three of four trials, the sibutramine groups reduced the waist circumference on average by 7–8 cm, compared with 2–3 cm in the control groups. One good quality trial also found greater reductions in HDL cholesterol, triglycerides, serum insulin, and HOMA, compared to the placebo group, but no differences in LDL or fasting serum glucose. Orlistat: Groups differed on fat mass in large, good quality trial, but not in the smaller trial; no differences in either trial on LDL, HDL, TG, FPG, insulin, or systolic blood pressure. The good-quality trial found small reduction in diastolic blood pressure. Metformin: One trial reported improved subcutaneous adiposity; two of three found improvements in fasting glucose and insulin. One trial found improvements in lipid parameters.
KQ1b & KQ2b: Effective components of weight management interventions
Behavioral Interventions
13 | 11 RCTs, 2 CCTs | Heterogeneity along many dimensions, making it impossible to isolate the effects of individual components of treatment | Poor | Fair to poor since interventions are so hetergeneous | Fair to Good—but not directly applicable to this question | We examined the use of organized physical activity sessions, parental involvement, and the use of behavior management techniques. None of the components clearly improved the chance of showing a positive weight management effect. Organized physical activity sessions did increase the likelihood of treatment success, but it was confounded with treatment intensity, and it was therefore impossible to determine whether it was the exercise sessions or the overall intensity of the treatment program that improved the chances of success.
Pharmacological + Behavioral Interventions
Data were insufficient to explore the importance of specific treatment components.
KQ1c & KQ2c: Population or environmental factors that affect weight management interventions
Behavioral Interventions
Data were insufficient to explore the importance of population or environmental factors.
Pharmacological + Behavioral Interventions
Data were insufficient to explore the importance of population or environmental factors.
KQ3. Harms of weight management interventions
Behavioral Interventions
11 (9 + 2 supplementary) | RCTs | Harms inconsistently reported, specific harm outcomes reported in only 1 to 3 trials, and outcomes were measured differently | Fair: outcomes consistently show no harms, but little consistency in what and how harms were measured. | Fair: Both of the primary care-based trials reported one of more harms outcomes, but most studies didn’t provide this data | Fair to poor—given reporting limitations for harms | Trials reported potential harms of impact on height, eating pathology or body image, depression, and injury. We found no evidence that behavioral intervention programs may be harmful
Pharmacological + Behavioral Interventions
Sibutramine: 5 Orlistat: 2 Metformin: 3 | RCTs | Only one large-scale trial for each of sibutramine and orlistat and limited to 12 months f/u. Metformin studied only in small, fair-quality studies | Good for sibutramine, orlistat and metformin | Fair: Most trials conducted in settings feasible for primary care-referral (specialty weight loss or research clinics); metformin results are applicable only to very selected populations | Good for sibutramine and orlistat; Fair for metformin | Sibutramine: Serious adverse effects: 2.7% (sibutramine) vs. 1% (placebo); sibutramine had increased heart rate, systolic blood pressure, abdominal complaints, and constipation; no effects on growth Orlistat: Serious adverse effects 3% in both drug and placebo; greater gastrointestinal side effects (>30% in drug); no effects on growth Metformin: No serious adverse effects; serum lactate and renal function remained normal; gastrointestinal side effects in 29% of metformin patients.

Abbreviations: BMI-body mass index; BMI SDS- Body Mass Index Standard Deviation Score; LDL-Low-density lipoprotein cholesterol, HDL- High-density lipoprotein cholesterol, TG-triglycerides, FPG-fasting plasma glucose; HOMA- Homeostasis model assessment of insulin sensitivity