# Results

We begin the results section by reporting the short-term (KQ1) and maintenance (KQ2) results, for behavioral and then pharmacological studies. We then discuss the questions of other positive outcomes (KQ1a and KQ2a), important components of treatment (KQ1b and KQ2b), and the impact of population and environmental factors (KQ1c and KQ2c) on the combined evidence of KQ1 and KQ2. We only identified four trials that met our criteria for maintenance for the behavioral trials, and two of these were also part of KQ1. Thus, the evidence base was too sparse to explore the subquestions of other positive outcomes (KQ2a), important components of treatment (KQ2b), and other factors (KQ2c) for the maintenance trials alone. And, as these trials were divided on the basis of time to followup only, the two groups of trials were not fundamentally different bodies of literature.

Finally, we discuss harms of behavioral and pharmacological interventions (KQ3) as reported in the trials reviewed in KQ1 and 2. In this section, we report on two additional behavioral trials that did not meet inclusion criteria for either KQ1 or KQ2, but did meet criteria for KQ3.

## KQ1. Do weight management programs (behavioral, combined behavioral and pharmacological) lead to BMI, weight, or adiposity stabilization or reduction in children and adolescents who are obese (≥95^th^ BMI percentile) or overweight (84–94^th^ percentile)?

### Behavioral Interventions

Summary of findings. Of the 11 behavioral interventions trials which measured short-term weight outcomes (6 to 12 months after entry), only two were included in the previous (2005) USPSTF review. All 11 behavioral intervention trials were consistent with a beneficial effect on BMI, BMI SDS, or on percentage overweight among the 1099 obese or overweight children or adolescents aged 4 to 18 years studied, although not all differences were statistically significant (Table 3; Figure 4). Differences between intervention and control groups ranged from 0.3 to 3.3 kg/m^2^ and reflected weight loss as well as weight gain prevention among treated participants. Intervention effectiveness tended to increase with more intensive interventions. The largest effects (between-group BMI differences of 1.9 to 3.3 kg/m^2^) were seen in three comprehensive weight management programs (including dietary or weight loss counseling, physical activity counseling or program, and use of behavioral management technique to assist in behavior change) with at least medium (26 to 75 contact hours) or high (76+ contact hours) intensity. Meta-analysis confirmed that among comprehensive weight management programs, medium-to-high intensity interventions had a significantly larger effect on weight outcomes than did very low-intensity (under 10 hours) interventions. Data were limited about non-comprehensive weight management programs, and showed mixed results.

Figure 4 Pooled analysis: Short-term effect size of behavioral interventions (KQ1)

This figure shows a forest plot of an analysis of the effect of behavioral interventions on short-term weight outcomes (as measured in change in body mass index [BMI]) in children and adolescents. The data are grouped on the basis of the comprehensiveness and intensity of the intervention in the trial. The first category of trials offered comprehensive, medium- to high-intensity behavioral interventions. In the Savoye 2007 trial treatment group, there were 105 subjects and the mean change in BMI was -1.70 kg/m2, with a standard deviation (SD) of 3.14; in the control group, there were 69 subjects and the mean change in BMI (SD) was 1.60 kg/m2 (3.17); the weight of the study was 38.30%; and the standardized mean difference (SMD) between the treatment and control group was -1.04 kg/m2, with a 95% confidence interval (CI) of -1.37 to -0.72. In the Reinehr 2006 treatment group, there were 174 subjects and the mean change in BMI (SD) was 0.10 kg/m2 (1.90); in the control group, there were 37 subjects and the mean change in BMI (SD) was 2.00 kg/m2 (1.80); the weight of the study was 36.49%; and the SMD (95% CI) was -1.01 kg/m2 (-1.37 to -0.64). In the Nemet 2005 treatment group, there were 20 subjects and the mean change in BMI (SD) was -1.50 kg/m2 (2.10); in the control group, there were 20 subjects and the mean change in BMI (SD) was 0.60 kg/m2 (2.50); the weight of the study was 25.21%; and the SMD (95% CI) was -0.89 kg/m2 (-1.54 to -0.24). The SMD (95% CI) for these trials combined was -1.01 kg/m2 (-1.24 to -0.78). The heterogeneity results were χ2=0.17, df=2 (p=0.92), and I2=0%. The z score was 8.70 (p<0.00001). The second category of trials offered comprehensive, low-intensity behavioral interventions. In the Golley 2007 treatment group, there were 31 subjects and the mean change in BMI (SD) was -0.24 kg/m2 (0.43); in the control group, there were 31 subjects and the mean change in BMI (SD) was -0.13 kg/m2 (0.40); the weight of the study was 41.21%; and the SMD (95% CI) was -0.26 kg/m2 (-0.76 to 0.24). In the Celio Doyle 2007 treatment group, there were 40 subjects and the mean change in BMI (SD) was -0.15 kg/m2 (1.75); in the control group, there were 40 subjects and the mean change in BMI (SD) was 0.39 kg/m2 (2.08); the weight of the study was 44.47%; and the SMD (95% CI) was -0.28 kg/m2 (-0.72 to 0.16). In the Senediak 1985 treatment group, there were 10 subjects and the mean change in BMI (SD) was -19.22 kg/m2 (5.34); in the control group, there were 70 subjects and the mean change in BMI (SD) was -5.86 kg/m2 (5.95); the weight of the study was 14.32%; and the SMD (95% CI) was -2.27 kg/m2 (-3.57 to -0.97). The SMD (95% CI) for these trials combined was -0.67 kg/m2 (-1.43 to 0.09). The heterogeneity results were χ2=8.52, df=2 (p=0.01), and I2=76.5%. The z score was 1.72 (p=0.09). The third category of trials offered comprehensive, very low-intensity behavioral interventions. In the Gillis 2007 treatment group, there were 11 subjects and the mean change in BMI (SD) was -0.04 kg/m2 (0.19); in the control group, there were 7 subjects and the mean change in BMI (SD) was 0.08 kg/m2 (0.08); the weight of the study was 20.18%; and the SMD (95% CI) was -0.72 kg/m2 (-1.71 to 0.26). In the McCallum 2007 treatment group, there were 73 subjects and the mean change in BMI (SD) was 0.50 kg/m2 (1.10); in the control group, there were 80 subjects and the mean change in BMI (SD) was 0.80 kg/m2 (1.00); the weight of the study was 48.55%; and the SMD (95% CI) was -0.28 kg/m2 (-0.60 to 0.03). In the Saelens 2002 treatment group, there were 18 subjects and the mean change in BMI (SD) was 0.10 kg/m2 (2.00); in the control group, there were 19 subjects and the mean change in BMI (SD) was 1.40 kg/m2 (1.70); the weight of the study was 31.27%; and the SMD (95% CI) was -0.69 kg/m2 (-1.35 to -0.02). The SMD (95% CI) for these trials combined was -0.39 kg/m2 (-0.66 to -0.11). The heterogeneity results were χ2=1.62, df=2 (p=0.44), and I2=0%. The z score was 2.76 (p=0.006). The fourth and last category of trials offered focused (non-comprehensive) behavioral interventions. In the Epstein 2008 treatment group, there were 35 subjects and the mean change in BMI (SD) was -0.24 kg/m2 (1.89); in the control group, there were 32 subjects and the mean change in BMI (SD) was -0.13 kg/m2 (2.09); the weight of the study was 52.48%; and the SMD (95% CI) was -0.05 kg/m2 (-0.53 to 0.42). In the Rooney 2005 treatment group, there were 24 subjects and the mean change in BMI (SD) was -0.87 kg/m2 (1.27); in the control group, there were 27 subjects and the mean change in BMI (SD) was -0.43 kg/m2 (1.09); the weight of the study was 47.52%; and the SMD (95% CI) was -0.37 kg/m2 (-0.92 to 0.19). The SMD (95% CI) for these trials combined was -0.19 kg/m2 (-0.55 to 0.17). The heterogeneity results were χ2=0.70, df=1 (p=0.40), and I2=0%. The z score was 1.02 (p=0.31). A vertical line of no effect appears in the middle of the forest plot with a value of 0 and a plot of the SMD (95% CI) for each trial. Boxes to the left of the vertical axis favor the treatment; e boxes to the right of the vertical axis favor the control.

Table 3 Short-term and maintenance outcomes of behavioral interventions

Study Reference Setting | N Randomized Age Baseline BMI | Intervention Hours (I-C) Intervention Components | Short-Term BMI Change: Mean Change (SD of Change) | Maintenance of BMI Change: Mean Change (SD of Change)
Comprehensive Programs, Medium (26–75 hrs) to High (76+ hrs) Intensity
Savoye et al 2007^77^ Health Care | N: 174 Age 8–16 BMI: I: 35.8 ± 7.6 C: 36.2 ± 6.2 | 97.5 hrs I: D, PA+, BehMod, Fam C: Brief semi-annual counseling | 12-mo (post-tx)^**^ I: −1.7 ± 3.1 (c) C: +1.6 ± 3.2 (c) | (Not Reported)
Reinehr et al 2006^79,89^ Health Care | N: 240 Age 6–14 BMI: I: 27.0 ± 4.4 (c) C: 26.1 ± 4.0 (c) | 76 hrs I: D, PA+, BehMod, Fam, MHTx C: No treatment due to distance from clinic | 12-mo (post-tx)^**^ I: +0.1 ± 1.9 (c) C: +2.0 ± 1.8 (c) | 24-mo (12-mos post-tx)^**^ I: +1.2 ± 2.4 (c) C: +2.9 ± 1.9 (c)
Nemet et al 2005^85^ Child Health and Sports Center | N=54 Average age 11.1 BMI: I: 27.7 ± 3.6 C: 28.0 ± 5.2 | 35.75 hrs I: D, PA+, BehMod, Fam C Nutritional counseling | 12-mo (9-mo post-tx)^*^ I: −1.5 ± 2.1 (c) C: +0.6 ± 2.5 (c) | (Not Reported)
Comprehensive Programs, Low-Intensity (11–25 hrs)
Mellin et al 1987^104^ Health Care | N=66 Age 12–18 (15.6) BMI:NR † Percent Overweight: I: 36.5% (SD NR) C: 29.5% (SD NR) | 24 hrs I: D, PA+, BehMod C: No treatment | (Not Reported) | 15-mo (12-mo post-tx): † Percent Overweight: I: −9.9 ± 15.0 (p<0.01)^**^ C: −0.1 ± 13.2 (n.s.)^**^
Golley 2007^80^ Health Care | N=111 Age 6–9 BMI: 24.3 ± 2.6 (overall) | 10.3 hrs (I1), 22 hrs (I2) I1: D, PA, Fam, MHTx I2: D, PA+, BehMod, Fam, MHTx C: Wait List | [underlined: 12-mo (7-mos post-tx):] † BMI SDS: I1: −0.15 ± 0.47 I2: −0.24 ± 0.43 C: −0.13 ± 0.40 | (Not Reported)
Doyle et al 2008;^86^ Celio et al 2006^88^ E-mail, Internet | N=83 Age 12–18 BMI: I: 34.6 ± 7.8 C: 33.9 ± 6.9 | 16 hrs I: D, PA, BehMod C: Information only | [underlined: 8-mo (4-mo post-tx):]^‡^ I: −0.2 ± 1.8 C: +0.4 ± 2.1 | (Not Reported)
Senediak et al 1985^84^ Setting NR | N=35 Age 6–12 BMI:NR † Percent Overweight: I1: 32.9% ± 14.0 I2: 35.9% ± 12.2 C: 36.7% ± 5.5 | 12 hrs (I1, I2, C) I1: D, PA, BehMod, Fam I2: D, PA, BehMod, Fam C: Social support, relaxation, mood monitoring | 6-mo (3–5 mo post-tx)^*^: † Percent Overweight: I1: −13.0% ± 6.3 (c) I2: −19.2% ± 5.4 (c) C: −5.9% ± 6.0 (c) | (Not Reported)
Comprehensive Programs, Very Low-Intensity (<10 hrs)
Gillis 2007^78^ Health Care | N: 27 Age 7–16 BMI SDS I: 1.98 ± 0.21 C: 2.16 ± 0.34 | 8 hrs I: D, PA, BehMod C: 1 counseling session | [underlined: 6-mo (post-tx)]: † BMI SDS: I: −0.045 ± 0.19 C: +0.075 ± 0.08 | (Not Reported)
McCallum et al, 2007^81,90^ Primary Care | N=163 Age 5–9 BMI: I: 20.5 ± 2.2 C: 20.0 ± 1.8 | 4 hrs I: D, PA, BehMod, Fam C: Usual primary care | [underlined: 9-mo (6-mo post-tx):] I: +0.5 ± 1.1 (c) C: +0.8 ± 1.0 (c) | [underlined: 15-mo (12-mo post-tx):] I: +1.2 ± 1.5 (c) C: +1.2 ± 1.1 (c)
Saelens et al 2002^83^ Primary Care | N=44 Age 12–16 BMI: I: 31.0 ± 3.5 C: 30.7 ± 3.1 | 3.8 hrs I: D, PA, BehMod C: Usual primary care | 7-mo (3-mo post-tx)^*^: I: +0.1 ± 2.0 (c) C: +1.4 ± 1.7 (c) | (Not Reported)
Focused Interventions, Very Low- to Low-Intensity
Flodmark 1993^103^ Health Care | N=93 Age 10–11 BMI: I1: 25.5 ± 2.3 (c) I2: 24.7 ± 1.8 (c) C: 25.1 ± 2.5 (c) | 12 hrs (I1), 24 hrs (I2) I1:D, PA, Fam I2:D, PA, Fam, MHTx C: Matched controls, no treatment | (Not Reported) | ~48-mo (30–34 mo post-tx)^*^: I1: +1.6 ± 2.0 (c) I2: +1.1 ± 1.8 (c) C: +2.8 ± 2.3 (c)
Rooney 2005^82^ Community | N=98 families, 353 people Age 5–12 BMI: I1: 21.1 ± 6.2 I2: 22.2 ± 6.2 C: 21.9 ± 6.0 | 3 hrs (I1), 21 hrs (I2) I1: PA, Fam, Pedometer I2: D, PA, Fam, Pedometer C: No Treatment | [underlined: 9-mo (6 mo post-tx):]^‡^ I1 −0.4 ± 1.0 (c) I2: −0.9 ± 1.3 (c) C: −0.4 ± 1.1 (c) | (Not Reported)
Epstein et al 2008^87^ Health Care | N=70 Age 4–7 BMI: I: 19.3 ± 2.5 C: 19.1 ± 3.5 | Hours NA, likely Very Low I: PA, Fam, Use of device to limit TV & computer time C: Fam, No device | 24-mo (post-intervention)^§^ † BMI SDS: I: −0.24 ± 1.9 C: −0.13 ± 2.1 | (Not Reported)

Note: Interventions ordered first by setting and second by intensity.

Abbreviations: I- Intervention group; C- Control group; (c)-calculated; NR-Not Reported; D-dietary counseling; PA-physical activity counseling; PA+-organized physical activity sessions; BehMod-behavioral modification principles used to address diet and physical activity changes; Fam-family or parent was a target of the intervention; MHTx-mental health treatment beyond behavior modification for diet and physical activity; post-tx- post treatment; SD-standard deviation

* p<0.05;

** p<0.01, bold if p<0.05

† BMI not reported, so other outcome listed

‡ Unpublished data supplied by author

§ Data were not provided for the 12-month mid-treatment effect, so the 24-month effect is provided, which is an underestimate of the 12-month effect. Graphical data indicated significant between-group differences at 12 months, so the 24 month data are considered statistically significant.

Intervention descriptions from the seven effective comprehensive programs and two effective non-comprehensive programs are described in Table 4, with two representative “best-case” programs in specialty healthcare and in primary care further detailed in the text below.

Table 4 Effective behavioral interventions for overweight or obesity

Study Reference | Age Range, N, Intervention Hours (Intensity) | Description of Intervention
Short-Term Outcomes
Savoye et al 2007^77^ Health Care | 8–16 n=174 97.5 hrs (High) | Diet: Non-dieting approach emphasizing low-fat, nutrient-dense foods of moderate portion sizes. PA: Two 50-min sessions/wk for first 6 months, then 1 session every 2 weeks. Each session included warm-up, high-intensity aerobic exercise, and cool-down. Goal to sustain 65% to 80% of age-adjusted max heart rate for duration of aerobic exercise. Also encouraged to exercise 3 additional days/week at home and to decrease sedentary behaviors. Beh Tx : One 50-min session/wk for first 6 months, then 1 session every 2 weeks. Topics included self-awareness, goal-setting, stimulus control, coping skills training, cognitive behavior strategies, contingency management. Family: Parents attended separate group during children’s behavioral treatment groups. Emphasized parents’ role modeling health behavior, coping skills training.
Reinehr et al 2006^79^ Health Care | 6–14 n=240 76 hrs (High) | Diet: Recommended diet of 30% fat, 15% protein, 55% carb (only 5% sugar). Categorized foods using Traffic Light system: red=”stop”, yellow=”consider the amount”, green=”OK when hungry or thirsty. Total kcal went from 1459 ± 379 pre-treatment to 1250 ± 299 kcal post-treatment PA: Once per week for 12 months, consisted of ballgames, jogging, trampoline, instruction in physical activity as part of everyday life, and encouragement to reduce amount of time spend watching TV Beh Tx : In first 3 months, 6-session nutrition course and 6-session behavior therapy groups for children. Family therapy provided for the next 3 months, with up to 3-month extension as needed. Lifestyle modification approach, details of topic covered not reported. Family: 6-session parents’ course for parents, 3 “Talk rounds for parents”, plus family therapy described above.
Gillis 2007^78^ Health Care | 7–16 n=27 8 hrs (Very low) | Diet: Two discussions of healthy diet; asked to record food intake once/week. No details of recommended diet reported. PA: Two sessions discussing exercise; asked to record exercise once/week. No details of exercise recommendations reported. Beh Tx : Self-monitor food and physical activity one day per week Family: None
Nemet et al 2005^85^ Health Care (“Child Health and Sports Center”) | Avg age 11.1 n=54 35.75 hrs (Medium) | Diet: 6 one-on-one meetings with a dietitian plus four group lectures, covering reasons for childhood obesity, nutrition information such as the food pyramid, food labels, food preparation, eating habits, regular meals. Recommend balanced diet of 5,021 to 8,368 KJ, a deficit of ~30% from baseline intake, or 15% less than estimated daily required intake. PA: Two 1-hour sessions/week for 14 weeks designed to mimic the type and intensity of exercise that children normally perform. Activities varied in duration and intensity, but usually included activities promoting endurance. Attention given to improving flexibility and coordination. Instructed to exercise at home for additional 30–45 minutes/week and to reduce sedentary activities. Beh Tx : Information on controlling the environment to minimize over-eating, coping with situations that encourage overeating. Family: Varied with child’s age. Ages 6–8: parents only for first 2 meetings, children joined thereafter. Ages 8 years-puberty: parents and children invited to all sessions. Puberty onward: Parents and youth attend first meeting, then alternate parents and child.
Short-Term Outcomes
Saelens et al 2002^83^ Primary Care | 12–16 n=44 3.8 hrs (Very low) | Diet: Adaptation of Traffic Light diet, goal to reduce to ~1200–1500 kcal/day. Focus on reduction in overall quantity of food and increasing healthy eating, with no prohibition of any particular foods. Computer-based assessment used to identify eating habits, develop initial recommendation/plan. Meeting with pediatrician to confirm/modify plan, 11 10–20 minute follow-up phone calls with support staff to discuss food diaries and other behavior change issues. PA: PA also assessed via computer, goals set with pediatrician, encouraged by phone counselors. Monitored PA starting with 5^th^ phone call, goal minimum of 60 minutes of at least moderate intensity PA 5 days/week. Beh Tx : Behavioral skills covered include self-monitoring, goal setting, problem solving, stimulus control, self-reward, and preplanning. Family: Parents sent information sheets corresponding to materials received by youth, highlighting ways in which parents can be most helpful. Recommended parental skills included stimulus/environmental control, positive reinforcement, and preplanning.
Senediak et al 1985^84^ Setting NR | 6–12 n=45 12 hrs (Low) | Diet: Covered variety of nutritional and dietary topics, recommended diet based on Food Exchange System and Traffic Light System. PA: Children instructed to engage in at least four 30-minute aerobic exercise sessions per week. Basic conditioning exercises introduced initially, then more strenuous aerobic exercise. Also recommended other lifestyle changes (such as walking instead of riding in the car) to encourage physical activity. Beh Tx : Utilized self-monitoring, self-reinforcement and parental reinforcement, stimulus control techniques (e.g., restricting food consumption to specific times and places), attempted to modify negative cognitions that may contribute to obesity. Family: Both parents and children involved in all sessions, given materials and homework.
Epstein et al 2008^87^ Health Care | 4–7 N=70 Hours NA (Very low) | Diet: None described PA: Installed devices on all computer and television screens to monitor screen time and limit their use, following a gradual reducing schedule. Beh Tx: None described Family: Separate codes were entered for each person in the household, so screen time was monitored and limited separately for each person.
Maintenance Outcomes
Mellin et al 1987^104^ Health Care | 12–18 n=66 24 hrs (Low) | Diet: Sustainable, small changes in diet; very-low-calorie or restrictive diets discouraged. No specific details on recommended diet. PA: Encouraged to make sustainable, small changes in exercise habits. No further details provided. Beh Tx : 14 weekly sessions; self-directed change format, encourage small, sustainable changes in relationships, lifestyle, communication, and attitudes. Details of encouraged change process not described. Family: Two parent meetings; instructed on strategies for supporting their child’s weight-loss efforts, including altering family dietary and activity habits, and improving parenting and communication skills.
Flodmark et al, 1993^103^ Health Care | 10–11 n=93 I1: 12 hrs I2: 24 hrs (Low) | Diet: Counseling by pediatrician and/or dietitian; recommend 1500 to 1700 kcal, with 30% of calories from fat. PA: No recommendations described Beh Tx : None described. Family: Family therapy focused on reinforcing the resources of the family and creating and optimal emotional climate for helping the obese child. Adjustments to family hierarchy/structure, plus solution-focused therapeutic techniques.

Abbreviations: PA- physical activity; Beh TX – behavioral treatment

Study Details. Eleven trials^7–0^ (in 14 publications) measured short-term weight outcomes (6 to 12 months after entry into treatment) (Figure 4), with only two83,84 available at the time of our 2005 review.2 These trials randomized a total of 1099 overweight or obese children and adolescents (Table 3). Ages enrolled in trials varied substantially, with some trials focusing only on younger children, some only on adolescents, and others spanning a wide age range. Trial participants were evenly divided between males and females: most trials were between 40 and 60 percent female, but two trials were more than 60 percent female and one was only 34 percent female. Only four trials reported a substantial proportion of nonWhite or Hispanic participants, ranging from 24 to 63 percent. The remaining either did not report race or ethnicity, or were predominantly nonHispanic White. Before treatment the mean BMI indicated that most participants in these trials exceeded the 95^th^ percentile for BMI, and in some cases met adult criteria for Class I obesity.

Trial characteristics are listed in Table 3. All but three of the interventions provided comprehensive programs, which included dietary counseling, physical activity program or counseling, and behavior modification principles. Many involved families. Unique intervention elements included specialty mental health treatment that was not focused solely on weight management, pedometers, and screen monitoring devices to limit television and computer use. Settings included primary care,81,83 specialty health care or similar,^7–0^,85,87 the internet,86 a community setting,82 or the setting of one trial could not be ascertained.84 Studies were conducted in the United States, Australia, Germany, Israel, and Sweden

We evaluated a total of 14 different active treatment arms. Treatment duration ranged from 3 to 24 months, with the exception of one study using a “rapid pace” treatment arm that lasted only 4 weeks.84 Treatment intensity (estimated in hours of contact) ranged from 3.8 to almost 100 hours. We could not calculate exact hours of contact for one trial that involved a device limiting the television viewing and computer use, but the number of contact hours with the study staff was estimated to be very low. Control groups varied from no treatment to 1 to 2 brief counseling sessions to usual care (in primary care settings), and one older trial84 matched the number of contact hours in the intervention group with social support, relaxation, and mood monitoring activities rather than healthy lifestyle counseling.

All trials were consistent with a beneficial effect on BMI or weight change, compared with controls. Not all of these differences, however, were statistically significant. Across all trials, short-term BMI changes in intervention groups ranged from dropping 1.7 kg/m^2^ 77 to increasing by 0.5 kg/m^2^.81 Control group BMI changes ranged from dropping 0.4 kg/m^2^ 82 to increasing by 2.0 kg/m^2^.79 Thus, differences in short-term improvements in BMI between intervention and control groups ranged from 0.3 to 3.3 kg/m^2^ and these differences reflected weight loss and weight gain prevention among treated participants. Comprehensive medium- to high-intensity programs showed the largest effects and were consistently statistically significant.77,79,85 BMI change in comprehensive medium- to high-intensity programs were 1.9 to 3.3 kg/m^2^ greater in the interventions than the control conditions.

Seven of 11 trials reported BMI changes from baseline or post-intervention, while three reported changes in BMI SDS78,80,87 and one reported changes in percent overweight.84 Meta-analyses of all 11 trials reporting standardized mean differences for short-term, weight-related outcomes after behavioral interventions were conducted after grouping the trials on the basis of comprehensiveness and intensity (Figure 4). A parallel analysis was also conducted on the subset of trials reported BMI change, calculating weighted mean differences, which resulted in a very similar pattern of results, though with greater statistical heterogeneity (Figure not shown).

Standardized effect sizes ranged from −1.01 (p<0.001, I2=0 percent, weighted mean BMI difference of −2.4 with p<0.001, I2=64%) for the comprehensive, medium- to high-intensity programs to −0.19 (p=0.31, I2=0 percent) for low- to very low-intensity focused interventions. The standardized effect size for comprehensive, low-intensity programs was not statistically significant (p=0.08) and showed a high degree of statistical heterogeneity (I2=77 percent). One84 of these three trials had a much larger effect than the other two,80,86 but was also much older (published in 1985 compared with 2007 for both of the others), smaller (n=35 randomized), and suffered from high attrition. Thus, the two more recent, better quality trials represent better estimates of the effects of low-intensity comprehensive interventions, which were small (−0.26 and −0.28) and not statistically significant.

Although comprehensive low-intensity interventions did not produce statistically significant treatment benefits, the standardized effect of comprehensive very low-intensity trials was statistically significant at −0.39 (p=.006, I2=0 percent, weighted mean difference of −0.63, p=0.18 I2=60%). Two of these were conducted in primary care settings and recruited participants through primary care. The third was conducted in a primary care setting, though the participants had all been referred to one of the researchers for weight management, and are therefore more akin to a specialty care population. Though data are very sparse and must be interpreted cautiously, these data suggest that very low-intensity interventions may result in improved weight management in primary care settings in the short term.

The non-comprehensive (focused) interventions were all estimated to be low or very low-intensity. Results showed that the use of pedometers without a comprehensive weight management program was not effective in improving weight management.82 Devices to monitor and limit weekly screen time (computer or television) in young children (4–7 year old) who spend an average of 2 hours or more per day in front of a screen, however, were effective weight management tools at 12 months, even without a comprehensive weight management program, although data reporting limited our ability to report effect sizes at 12 months.87 At the end of the two-year intervention, BMI SDS had declined by 0.24 in the treatment group (n=35) and only 0.13 in the control group (n=32). Post-hoc analyses showed that socioeconomic status moderated the effect of the intervention, with children from lower SES families showing a greater benefit than those from higher SES families.87

Study design and quality. We rated six77,80,81,83,86,87 of the trials good-quality, while the remaining trials were rated fair-quality (see Appendix A Table 3 for quality criteria). Most trials were randomized controlled trials, but one was a nonrandomized controlled trial.79 Most trials using randomization failed to report whether treatment allocation was blinded and most trials did not report whether those conducting followup assessments were blind to the treatment condition. Many of the trials were also quite small; only three trials had treatment arms with more than 40 participants at followup. While most trials reported retention of 90 percent or higher, retention in three trials was below 70 percent.77,78,84 One of these three trials77 included statistical methods to compensate for attrition. Several trials statistically tested for differential attrition (none found differential attrition between treatment and control groups), but most did not. Two smaller trials78,85 appeared to have differential attrition, but these differences were not tested statistically. The majority of trials were published in 2005 or later, and only two83,84 were included in the previous USPSTF review.

It is difficult to determine how well the results of these trials would generalize to patients in real-world treatment settings. Several studies relied at least in part on media advertisements for recruitment, and may therefore have enrolled participants who are more motivated to lose weight than a typical obese young person. One trial81 recruited participants via primary care screening. Because they attempted to find and enroll all eligible primary care patients, rather than relying on interested patients to contact them, generalizability to primary care settings is improved. However, only 32 percent who met weight criteria actually enrolled in the trial. There may be unmeasured differences between children who did and children who did not participate that influence how well they respond to the intervention. For example, children and adolescents who participated may have higher levels of motivation, more free time, more involved parents, more failed attempts at weight loss, or any number of factors that may moderate the intervention’s effectiveness.

Best average intervention effect from a specialty healthcare setting. One good-quality trial conducted by Savoye and colleagues77 provides a realistic best-case scenario. This trial reported one of the largest effect sizes of the outpatient programs included in this review and a comprehensive program in which many families with overweight children could realistically participate. This year-long program (Bright Bodies Weight Management) was conducted at a pediatric obesity clinic in the United States and accepted children ranging from age 8 to 16 years, with an average age of 12.1 years. Sixty-one percent of the 174 participants were girls. The Bright Bodies program involved about 98 hours of contact and an extensive educational program providing information on nutrition, physical activity, behavior change strategies, coping skills, and relapse prevention. The program provided organized exercise sessions twice per week during the first 6 months, then once every two weeks during the next 6 months. Parents or caregivers attended all educational sessions. Children and adolescents in the intervention group began the program with an average BMI of 35.8 kg/m^2^, which dropped by an average of 1.7 kg/m^2^ by the end of the intervention, compared with an average increase of 1.6 kg/m^2^ in the control group. This trial suffered from somewhat low retention (77.6 percent at 6 months and 66.7 percent at 12 months), but took statistical measures to examine and combat the effects of attrition, including comparing results in completers only with results involving multiple imputation and data replacement methods.

To provide a more concrete example of the average impact of the Bright Bodies program, we modeled the impact on a 12-year-old girl who began the program at an assumed height of 5’0”, with the average entry BMI of 35.8, and who experienced the average reduction in her BMI by 1.7 kg/m^2^ over the course of the intervention year, while growing 2 inches (an average for this age and sex). This would amount to a change from 183 pounds to 186 pounds 1 year after she participated in the program, compared with an expected 21 pound weight gain and an increase of 1.6 BMI kg/m^2^ if she had not participated.

Best average intervention effect from a primary healthcare setting. One good-quality primary care-based trial showed a statistically significant effect in overweight and obese adolescents. This trial would likely be feasible for implementation in many primary case settings, with some additional resources and institutional support.83 The Healthy Habits intervention began with a computerized assessment and planning tool that assessed eating, physical activity, and sedentary behavior in 12 to 16 year olds, average age of 14 years. The intervention then developed a personalized plan to improve each participant’s habits in these areas. The computer program helped the youth identify benefits, barriers, and specific strategies to reach identified goals. The youth were also given a non-tailored treatment manual covering behavioral skills for weight control. The pediatrician discussed the summary and action plan generated by the computer program. Telephone counselors contacted the adolescents weekly for 8 weeks and biweekly for the last three calls to help them implement their treatment plan and troubleshoot adjustments to the plan. As calls lasted 10 to 20 minutes, we estimated that the entire program involved approximately 3.8 hours of contact.

Youth in the intervention group began the trial with an average BMI of 31.0 kg/m^2^ (obese by adult standards, and well above the 95^th^ percentile). This average, however, dropped to 30.9 kg/m^2^ at the end of the 4-month treatment phase, and averaged 31.1 kg/m^2^ 3 months later. The control group participants had an average baseline BMI of 30.7 kg/m^2^, which increased to 31.8 kg/m^2^ 4 months later, and ended up with an average BMI of 32.1 kg/m^2^. We modeled the impact of the program on a 14-year-old girl (average baseline age was 14.2) who began the program at an assumed height of 5’4” and who grew 1 inch from baseline to 7-month assessment. Based on the average BMIs at baseline and 7-month assessment for each group, she would have gained 7 pounds (from 180 to 187 pounds) if she had been in the intervention group, and 14 pounds (179 to 193) in the control group.

### Combined Behavioral and Pharmacological Interventions

Summary of Findings. Among 691 obese adolescents aged 12 to 18 years, BMI was reduced 2.9 to 3.6 kg/m^2^ in those treated with 6 to 12 months of sibutramine plus behavioral intervention compared with a BMI reduction of 0.3 to 1.8 kg/m^2^ in those receiving placebo plus behavioral intervention (between group BMI differences of 1.6 to 2.7 kg/m^2^) (Table 5). In a very small study (n=24) of obese adolescents, shorter-term (3 month) sibutramine treatment within a 6-month behavioral intervention was not more effective than behavioral intervention alone. Among 539 obese adolescents aged 12 to 18 years, 12 months of orlistat plus behavioral intervention reduced weight gain (0.53 kg) compared with behavioral intervention alone (3.14 kg), resulting in a small, but statistically significant between-group BMI difference (0.85 kg/m^2^). In a smaller study (n=40), 6-month orlistat plus behavioral intervention resulted in a smaller (0.55 kg/m^2^) non-significant BMI reduction compared with behavioral intervention alone. In a small number (n = 145) of very selected obese children and adolescents aged 9 to 19 years (all with additional risk factors for developing type 2 diabetes mellitus), 6 months of metformin therapy led to a statistically significant net reduction in BMI SDS in two of three studies (between-group difference in BMI of −0.79 to −1.4 kg/m^2^).

Table 5 Results of randomized controlled trials of pharmacological anti-obesity treatments among adolescents, by drug type

Source | N | Baseline BMI (kg/m^2^) | Treatment months | Change BMI (kg/m^2^) p value | Physiological Outcomes | | Adverse Events
Sibutramine
Berkowitz et al, 2003^91^ | 43 39 | I: 37.5 ± 4.0 C: 38.0 ± 3.6 | 6 | −3.2^a^ −1.5^a^ p=0.001^b^ | WC: SD LDL: NS HDL: NS TG: NS FPG: NS | Insulin: NS HOMA: NS Heart Rate: SD^e^ Systolic BP: SD^e^ Diastolic BP: NS | Adverse Events: NS
Berkowitz et al, 2006^92^ | 368 130 | I: 36.1 ± 3.8 C: 35.9 ± 4.1 | 12 | −2.9 −0.3 p < 0.001 | WC: SD LDL: NS HDL: SD TG: SD FPG: NS | Insulin: SD HOMA: SD Heart Rate: SD^e^ Systolic BP: SD^e^ Diastolic BP: SD^e^ | Adverse Events: NS SAE: NS d/c med: NS Growth: NS Maturation: NS
Garcia-Morales et al, 2006^94^ | 26 25 | I: 35.1± 5.3 C: 36.6 ± 5.2 | 6 | −3.4 (−2.5, −4.2) −1.8 (−0.9, −2.6) P< 0.005^*^ | WC: NS LDL: NS HDL: NS TG: NS | FPG NS Heart Rate: SD^e^ Systolic BP: NS Diastolic BP: SD^e^ | Adverse Events: NS d/c med: NS Maturation: NS Growth: NS
Godoy-Matos et al, 2005^95^ | 30 30 | I: 37.5 ± 3.8 (f) 37.6 ± 4.3 (m) C: 35.8 ± 4.2 (f) 37.4 ± 1.9 (m) | 6 | −3.6 ± 2.5 −0.9 ± 0.9 p < 0.001 | WC: SD LDL: NS HDL: NS TG: NS FPG: NS | Insulin: NS Heart Rate: NS Systolic BP: NS Diastolic BP: NS | SAE: NS d/c med: NS Other: SD
Van Mil et al, 2007^97^ | 12 12 | I: 30.1 ± 4.5 C: 33.3 ± 5.0 | 3 + 3 mos f/u^c^ | −0.8^d^ −1.4^d^ NR | % Fat Mass: NS Heart Rate: NS | Systolic BP: NS Diastolic BP: NS | Adverse Event: NS d/c med: NS Other: SD
Orlistat
Chanoine et al, 2005^93^ | 357 182 | I: 35.7 ± 4.2 C: 35.4 ± 4.1 | 12 | −0.55 +0.3 p < 0.001 | WC: SD Other Adiposity: SD LDL: NS HDL: NS TG: NS | FPG: NS Insulin: NS Heart Rate: NS Systolic BP: NS Diastolic BP: SD^f^ | Growth: NS Maturation: NS Other: SD
Maahs et al, 2006^96^ | 20 20 | I: 39.2 ± 1.2 C: 41.7 ± 2.6 | 6 | −1.3 ± 1.6 −0.8 ± 3.0 NS | % Fat Mass: NS LDL: NS HDL: NS | TG: NS FPG: NS Insulin: NS | Other: SD

a Calculated based on average BMI at baseline and average percentage change in BMI for each group (I: −8.5% ± 6.8%, C: −4.0% ± 5.4%).

b Based on comparison of percent change in BMI between groups

* result of ANOVA testing interaction between treatment group and time

c Patients were treated with BT + sibutramine or placebo for 3 mos and then BT alone for 3 mos.

d calculated based on differences reported baseline to 3 mos and 3 mos to 6 mos.

e Relative increased rate over time in sibutramine group compared to placebo group

f Relative reduction in rate over time in orlistat group compared to placebo group

Abbreviations: IG - Intervention group; CG - Control group; BT - Behavioral Treatment, NS - not significant; NR - not reported; WC - Waist circumference; LDL - Low-density Lipoprotein; HDL- High-density Lipoprotein; TG - triglyceride; FPG - Fasting plasma glucose; BP - Blood pressure; SD - statistically significant difference; SAE - Serious adverse events; HOMA - Homeostasis model assessment of insulin sensitivity; d/c - discontinue.

Study Details. We identified seven trials (all fair- or good-quality RCTs)^9–7^ evaluating a pharmacological agent’s effect (either sibutramine or orlistat) on overweight or obesity in a total of 1,294 adolescents aged 12 to 19 years (Appendix B Table 2). Five obesity treatment trials91,92,94,95,97 evaluated the effectiveness of 1–5 mg/day of sibutramine in 715 patients. Two trials93,96 evaluated the effectiveness of orlistat (120 mg three times a day) in 579 patients. All pharmacological obesity treatment trials compared the active medication plus behavioral counseling (with or without a behavioral management program) to the effects of placebo plus the same behavioral counseling. Multivitamin supplementation was provided for all participants in both of the orlistat trials. Although these are not broadly generalizable, we also describe weight-related and other outcomes from three small trials testing the effect of metformin on preventing glucose intolerance or improving insulin sensitivity in 145 selected obese adolescents with additional risk factors for diabetes.^9–00^ The trials compared the effect of metformin to placebo therapy, either with minimal100 or no98,99 concurrent behavioral counseling intervention. (see Table 6)

Table 6 Randomized, placebo-controlled, clinical trials evaluating pharmacological agents among special populations of obese children and adolescents and reporting weight outcomes

Source | N randomized Study design Country | Population Length of study | Intervention Drug dose | Baseline BMI | BMI Results
Srinivasan et al, 2006^99^ | N = 28 Cross-over RCT Australia | Obese children and adolescents ages 9–18 years with clinical suspicion of insulin resistance(fasting insulin: glucose > 4.5 or acanthosis nigricans) 12 months | A: Metformin for 6 months, then placebo for 6 months B: Placebo for 6 months, then metformin for 6 months Metformin dose: gradually increased(over 3 wks) up to 2 g/day vs. placebo | Total sample: 35.2 ± 5.1 kg/m^2^ (not reported by study group) | Δ ΔBMI SDS^*^ −0.12 p=0.005 Δ ΔBMI −1.26 kg/m^2^BMI p=0.002
Freemark et al., 2001^98^ | N =32 RCT USA | Obese adolescents ages12 to 19 years with fasting insulin concentration > 15μU/mL; and ≥ 1 first- or second-degree relative with type 2 DM 6 months | IG: Metformin CG: Placebo Metformin dose: 500 mg, twice per day | IG: 41.5 ± 0.9 CG: 38.7 ± 1.3 (p < 0.05) | ΔBMI SDS IG: −0.12 CG: 0.23 p< 0.02 Δ BMI IG: −0.5 kg/m^2^ CG: 0.9 kg/m^2^ p-value NR
Love-Osborne et al, 2008^100^ | N = 85 RCT USA | Adolescents 12–19 with fasting insulin level >25μU/mL or homeostasis model assessment > 3.5 and 2 of 3 risk factors(presence of acanthosis nigricans, obesity(BMI>95%ile), or family history of T2DM) 6 months | IG: Metformin + behavioralintervention (personal goal-setting) CG: Placebo + behavioral intervention (personal goal-setting) Metformin dose: increased over 2 months to 850 mg twice per day, (if tolerated) | IG:39.4 ± 6.5 CG:39.3 ± 7.2 | ΔBMI IG: −0.16 ± 1.89 CG: 0.63 ± 1.29 p-value 0.11 >5% BMI decrease: IG: 11 (22.9%) CG: 0 (0%) p = 0.001

Abbreviations: BMI - Body mass index; DM - Diabetes mellitus; IG - intervention group; CG - control group; RCT - randomized controlled trial

* ΔΔBMI = ΔBMI_IG_ − ΔBMI_CG_

Participants in the sibutramine and orlistat trials all met a BMI-based criteria for obesity (either above the age- and sex-specific 95 to 97^th^ percentile or above a BMI of 30 kg/m^2^), and mean BMI in these trials was typically 35 to 38 kg/m^2^ at baseline. Most trials excluded those at or above the midpoint for Class III (morbid) obesity (BMI exceeding 44 kg/m^2^) and those with type 1 or type 2 diabetes mellitus. The sibutramine trials also generally excluded patients who had cardiovascular disease or hypertension. About two-thirds of participants in these trials were females. The majority of trials did not report race/ethnicity of participants. In the two largest multi-center RCTs, however, almost half of the sibutramine patients were racial/ethnic minorities,92 as were one-quarter of orlistat patients.93 The sibutramine trial included 21 percent Black participants, 16 percent Hispanic participants, and 7 percent other nonWhite patients. The orlistat trial included 17 percent Black participants and 7 percent of other race-ethnicity. Additionally, a small (n=52) sibutramine trial conducted in Mexico could have applicability to adolescents of Mexican heritage living in the United States.94

The minimal behavioral intervention provided to all participants in sibutramine and orlistat trials consisted of advice to follow a calorie-restricted diet (e.g., 500 kcal/day deficit) and meet physical activity goals (e.g., at least 30 minutes of aerobic activity per day). All but one trial95 also included a behavior management program, ranging in intensity from seven to 19 sessions with a dietitian, psychologist, or psychiatrist. Family members attended behavioral management sessions in only two of the seven trials.91,97 The length of drug therapy was 3, 6, or 12 months (in one, four, and two trials, respectively). We report the followup results at 6 months in the single trial evaluating 3 months of drug therapy (sibutramine). No other trials reported followup results describing weight patterns after pharmacologic treatment ended.

Of the six trials that reported their funding sources, all but one was funded completely or partially by the pharmaceutical industry. Two of these pharmaceutical-industry sponsored trials were large (about 500 participants) multi-center RCTs (over 30 study sites) conducted in the United States and Canada. One evaluated sibutramine92 and the other evaluated orlistat.93 The remaining trials randomized much smaller samples (n = 24 to 82), were conducted at single sites, and reported outcomes after only 6 months of treatment.

Sibutramine. Five trials reported outcomes 6 or 12 months after starting sibutramine treatment (in seven publications) (Table 4).91,92,94,95,97,101,102 One of these was a small trial (n=24) that evaluated 3 months of a behavioral intervention plus sibutramine (10 mg) or placebo treatment, followed by 3 months of a behavioral intervention alone.97 Based on our calculations, BMI was not reduced more in those receiving sibutramine plus a behavioral intervention compared with placebo treatment plus a behavioral intervention. Both groups had similar, modest (−0.8 kg/m^2^ to −1.4 kg/m^2^) mean reduction in BMI at 6 months. All of the three trials reporting weight outcomes immediately after 6 months of treatment with sibutramine plus a behavioral intervention found a statistically significant difference between the intervention and control groups, favoring a greater reduction in BMI in the group treated with sibutramine.91,94,95 Among patients treated with sibutramine plus a behavioral intervention, the mean reduction in BMI ranged from −3.2 kg/m^2^ to −3.6 kg/m^2^. In contrast, the mean reduction in BMI among patients treated with placebo plus behavioral therapy ranged from −0.9 kg/m^2^ to−1.8 kg/m^2^. Budd and colleagues101 presented a secondary analysis of the data from one of these trials,91 reporting outcomes separately for the 34 Black and 45 White participants. At month 6, there were no statistically significant differences in the outcomes between racial groups. This trial, however, was not designed to have adequate power to detect differences between racial groups.

The single large trial that reported weight outcomes after 12 months of sibutramine plus a behavioral intervention also found statistically significant results in favor of the sibutramine group.92 The mean reduction in BMI in the sibutramine group was −2.9 kg/m^2^ compared to −0.3 kg/m^2^ in the control group (p <0.001). As noted, this trial had higher attrition in the placebo control group (38 percent) than the sibutramine group (24 percent, p = 0.001), somewhat reducing our confidence in these findings. BMI measures over time, however, were also analyzed using a linear mixed-effects model to predict missing values. In these analyses, the mean change in BMI between treatment and control groups was also statistically significantly different at all study visits from week 1 through month 12. The difference between the changes in BMI z-scores was also statistically significant. The mean change in body weight (± standard error [SE]) at month 12 was −6.5 ± 0.31 kg in the sibutramine group versus 1.9 ± 0.56 kg in the placebo group (difference, −8.4 kg, or 18.5 pounds (CI: −9.7, −7.2 kg); p < 0.001 by linear mixed-effects model).

Orlistat. Two trials reported the weight outcomes after 6 or 12 months of orlistat therapy plus a behavioral intervention and results were mixed. The large (n=539), multi-center trial evaluating 12 months of orlistat therapy found a statistically significant difference between the change in BMI favoring the orlistat plus a behavioral intervention group (−0.55 kg/m^2^ vs. 0.3 kg/m^2^, p < 0.001).93 The absolute mean body weight increased in both groups during the 12-month trial, but increased less in the orlistat group (0.53 kg vs. 3.14 kg, p <0.001). Attrition in this trial was quite high (33 to 34 percent), but analyses of primary weight outcomes included over 98 percent of randomized participants and replaced missing data using the last observation carried forward (LOCF) method. Also, baseline characteristics were not different for completers or those who dropped out within each group. Nevertheless, the high level of attrition in the trial somewhat limits its validity. A smaller trial (n=40) that evaluated the effects of 6 months of orlistat plus a behavioral intervention found that the orlistat group had a larger BMI reduction than the control group (−1.3 kg/m^2^ vs. −0.8 kg/m^2^), but this difference was not statistically significant.96

Study design and quality. All included studies of sibutramine and orlistat were double-blinded, placebo-controlled RCTs of fair- or good- quality (see Appendix A Table 3 for quality criteria). Most trials used appropriate randomization methods and took explicit measures to conceal allocation assignment. Intervention and control groups were similar at baseline for age, sex, and anthropometric characteristics in all of the trials. Descriptions of drug protocols were clear. Descriptions of behavioral interventions were generally adequate, but much less detailed than trials evaluating behavioral interventions. Adherence to medication protocols (measured by pill counts) was 80 percent or higher in the majority of the trials. Adherence was slightly lower (72 to 73 percent) in the large multi-center orlistat RCT. Most of the trials did not report how the behavioral intervention program was supervised, or if it was delivered as intended. Most trials also did not report any data on adherence to diet, physical activity, or other behaviors. Most of the trials specified that outcomes were assessed by personnel blinded to treatment status.

Attrition rates ranged from 10 to 35 percent. Notably, both of the large, multi-center trials had fairly high attrition. Overall attrition was 35 percent in the large orlistat trial. In the large sibutramine trial, the attrition rate was 28 percent overall and was differential between groups (24 percent in the sibutramine group and 38 percent in the control group, p=0.001). All of the trials analyzed main weight outcomes among the intent-to-treat (ITT) or modified ITT population. The modified ITT population included any participant who had at least one post-baseline efficacy measurement. Missing values were replaced using the LOCF method in most trials and/or a linear mixed-effects model for repeated measures over time. One trial94 excluded 10 percent of patients, even in the modified ITT population analyses, because they left the trial in less one month.

Metformin. Two of three trials among obese adolescents with additional risk factors for developing type 2 diabetes mellitus evaluating Metformin found statistically significant differences between groups for BMI or BMI SDS at 6 months, with results favoring the metformin group. The third trial found that a statistically higher proportion of adolescents in the metformin group had a greater than 5 percent BMI reduction, compared to those in the placebo group.

Study design and quality. Results should be interpreted with caution, however, as these were very small studies and because analyses in these trials included only patients who completed the trial (attrition rates were 9 and 25 percent), which could have caused bias. In one trial, attrition was also quite different between intervention and control groups (20 percent versus 36 percent).

## KQ2. Do weight management programs (behavioral, combined behavioral and pharmacological) help children and adolescents who are initially obese or overweight maintain BMI, weight, or adiposity improvements after the completion of an active intervention?

### Behavioral Interventions

Summary of Findings. Data from fewer studies (four trials, 562 patients) suggests BMI or other weight change improvements can persist longer-term (15 to 48 months after beginning a behavioral intervention and at least 12 months since the intervention ended)(Figure 5; Table 3). Of the two trials that conducted repeated measures in participants to assess weight change maintenance, BMI reduction was maintained for 12 months after a high-intensity behavioral intervention ended.

Figure 5 Pooled analysis: Maintenance effect size of behavioral interventions (KQ2)

This figure shows a forest plot of an analysis of the effect of behavioral interventions on weight-change maintenance (15 to 48 months after beginning a behavioral intervention and at least 12 months since the intervention ended) in children and adolescents. The data are grouped on the basis of the comprehensiveness and intensity of the intervention in the trial. The first trial, Reinehr 2006, offered comprehensive, medium- to high-intensity behavioral interventions. In the treatment group, there were 174 subjects, and the mean change in BMI was 1.20 kg/m2, with a standard deviation (SD) of 2.39; in the control group, there were 37 subjects and the mean effect size (SD) was 2.90 kg/m2 (1.90); and the standardized mean difference (SMD) between the treatment and control group was -0.73 kg/m2, with a 95% confidence interval (CI) of -1.09 to -0.37. The z score was 3.97 (p<0.0001). The second trial, Mellin 1987, offered comprehensive, low-intensity behavioral interventions. In the treatment group, there were 34 subjects, and the mean change in BMI (SD) was -9.90 kg/m2 (15.00); in the control group, there were 29 subjects and the mean change in BMI (SD) was -0.10 kg/m2 (13.20); and the SMD (95% CI) was -0.68 kg/m2 (-1.19 to -0.17). The z score was 2.62 (p=0.009). The third trial, McCallum 2007, offered comprehensive, low- to very low-intensity behavioral interventions. In the treatment group, there were 70 subjects, and the mean change in BMI (SD) was 1.20 kg/m2 (1.47); in the control group, there were 76 subjects and the mean change in BMI (SD) was 1.20 kg/m2 (1.11); and the SMD (95% CI) was 0.00 kg/m2 (-0.32 to 0.32).The z score was 0.00 (p=1.00). The fourth and last trial, Flodmark 1993, offered focused (non-comprehensive) behavioral interventions. In the treatment group, there were 270 subjects, and the mean change in BMI (SD) was 1.10 kg/m2 (1.85); in the control group, there were 48 subjects and the mean change in BMI (SD) was 2.80 kg/m2 (2.26); and the SMD (95% CI) was -0.78 kg/m2 (-1.32 to -0.24). The z score was 2.84 (p=0.004). A vertical line of no effect appears in the middle of the forest plot with a value of 0 and a plot of the SMD (95% CI) for each trial. Boxes to the left of the vertical axis favor the treatment; boxes to the right of the vertical axis favor the control.

Study Details. Four trials in six publications79,81,89,90,103,104 reported medium-term outcomes at least 12 months after the intervention ended and 15 to 48 months since beginning treatment (see Table 3). Two studies measured short-term as well as maintenance outcomes 79,81 while two measured maintenance outcomes only.103,104 Three of the four trials found that intervention groups had beneficial changes in BMI or percent overweight compared to controls at least 1 year after treatment ended.79,103,104 We did not combine any of the trials quantitatively as they each fell into different a priori groups based on comprehensiveness and intensity. We do provide a forest plot of the four trials showing standardized effect sizes (see Figure 5). The two trials79,103 with statistically significant group differences in BMI change found that the intervention group BMI increased by 1.7 kg/m^2^ less in the intervention group than in the control group. In the third trial showing group differences,104 the intervention participants dropped from 36.5 percent overweight to 26.6 percent overweight (a 9.9-point difference), while the degree of overweight in the control participants was unchanged. This trial testing a low-intensity (24 hours), short-duration (3 month) intervention found a greater difference in overweight measures between intervention and controls at 15 months than at 3 months.104 This result was the only one to suggest that treatment effects could be enhanced beyond the end of active treatment. This result should be interpreted with caution since we excluded trials reporting only outcomes before 6 months, and therefore cannot determine whether this 3-month outcome was typical.

One of the two comprehensive weight management trials reporting both short-term and maintenance outcomes confirmed that BMI benefits after a high-intensity behavioral intervention seen at 12 months post-treatment were largely maintained 12 months later.79 The second trial with both short-term and maintenance outcomes did not find improved weight outcomes at either 9 or 15 months and was a very low-intensity (4 hours), short-duration (3 month) treatment.81

Study design and quality. Two were fair-or-good quality randomized controlled trials, and two were fair-quality controlled clinical trial.79,103 Two had 40 or fewer participants per arm,103,104 however the other two had over 75 to 100 per arm.79,81,90 Quality issues included failure to report blinding for treatment allocation and outcome assessment.

Three trials were set in specialty health care treatment settings79,103,104 and one in primary care.81 Three trials involved comprehensive interventions with high-,79 low-,104 and very low-81 intensity interventions. The remaining trial involved a low-intensity intervention focused on providing family therapy.103

### Combined Behavioral and Pharmacological Interventions

No trials reported on maintenance of weight loss after active treatment with sibutramine or orlistat was discontinued. Cross-over results from one small metformin trial were available graphically only, and did not meet inclusion criteria (maintenance of results at least 12 months after intervention end).

## KQ1a & 2a. Do behavioral or combined behavioral and pharmacological weight management programs lead to other positive outcomes (e.g., improved behavioral or physiological measures, decreased childhood morbidity, improved childhood functioning, or reduced adult morbidity and mortality)?

### Behavioral Interventions

All of the 13 trials reporting either short-term (KQ1) or maintenance (KQ2) outcomes also reported one or more beneficial outcomes, including measures of adiposity, cardiovascular risk factors, physical fitness, behavioral outcomes, and psychosocial outcomes (see Table 7 for studies reporting cardiovascular risk factors and adiposity outcomes). Results in all areas were mixed, but the outcomes that were most likely to show greater improvement in the intervention group were insulin-related measures, measures of adiposity, and measures of physical fitness. Limits to findings include incomplete reporting of these outcomes across studies, including the possibility of selective reporting, and possible bias in measurements where lack of blinding of outcome assessors could affect results (e.g. waist circumference).

Table 7 Other positive medical outcomes reported in behavioral intervention trials

Study Reference | Increase in High- density lipids(HDL) | Decrease in Low- density lipids (LDL)^†^ | Decrease in Triglycerides | Decrease in systolic BP | Decrease in diastolic BP | Decrease in Fasting Glucose | Decrease in Fasting Insulin | Decrease in HOMA- IR | Adiposity (Measure)
Flodmark 1993^103^ | -- | -- | -- | -- | -- | -- | -- | -- | IG: Triceps, subscapular, suprailiac skinfold; decrease in thickness
Gillis 2007^78^ | N | N | N | -- | -- | -- | -- | -- | --
Golley 2007^80^ | N | -- | N | N | N | N | N | -- | IG: decrease in Waist circumference
Nemet et al 2005^85^ | -- | -- | -- | -- | -- | -- | -- | -- | IG: Triceps, subscapular skinfold; decrease in thickness
Reinehr et al 2006^79^ | N | IG | N | IG | N | N | IG | IG | --
Savoye et al 2007^77^ | N | N | N | -- | -- | N | IG | IG | IG: Bioelectric impedance;decrease in body fat percentage
Senediak et al 1985^84^ | -- | -- | -- | -- | -- | -- | -- | -- | IG: Subscapular skinfold; decrease in thickness

N - No group differences, IG - Result favors intervention group

† HDL and LDL differences are reported separately; trials do not report on the ratio of HDL to LDL

BP- blood pressure; DEXA - Dual-energy x-ray absorptiometry; HOMA - homeostasis model assessment of insulin resistance

Measures of adiposity. Five of the trials77,80,84,85,103 reported measures of adiposity and all found that the intervention groups showed greater improvement in adiposity than the control groups. Four of these five trials77,84,85,103 also found positive effects in the primary weight outcome as well as either skinfold measures or body fat (as measured by bio-electrical impedance). The remaining trial,80 which did not have a positive primary weight outcome, showed improvement in adiposity as measured by waist circumference.

Cardiovascular risk factors and physical fitness outcomes. Physiologic outcomes included lipid levels, glucose tolerance, insulin-related measures, blood pressure, and physical fitness. Results for all of these outcomes were quite mixed. Reduced fasting insulin and reduced insulin resistance were the most commonly found group differences. Two77,79 of the three77,79,80 trials reporting on fasting insulin found reductions of fasting insulin in the intervention groups relative to the control group. Two of these three trials77,79 also reported significant reductions in insulin resistance, as measured by the homeostasis model assessment of insulin resistance (HOMA). By contrast, none of the four trials^7–0^ reporting lipid levels found group differences in HDL or triglyceride levels, and only one found reductions in LDL levels.79

Neither of the two trials79,80 reporting on blood pressure found group differences on diastolic blood pressure and only one79 reported reductions in systolic blood pressure. Similarly, none of the three trials77,79,80 reporting on glucose levels found any group differences.

Three trials78,85,103 reported on physical fitness, each using a different measure, and two85,103 of these found that participants the intervention groups were more fit than those in the control groups. Nemet and colleagues85 reported increased endurance in the participants in their intervention group after completing a 14-week, twice-weekly exercise program along with up to six meetings with a dietitian. This study measured endurance by the number of seconds participants were able to continue a treadmill test. Another trial103 reported improvement in physical fitness without organized exercise sessions. The third trial78 did not include organized exercise sessions and did not see group differences in scores on the Harvard Step Test.

Behavior changes. The interventions in these trials appeared to have a minimal impact on the intermediate outcomes of diet and activity level. While five trials78,81,83,85,87 explored dietary changes, only two81,87 found group differences. The study of the screen-time monitoring and limiting device87 found that the intervention group showed greater reductions in energy intake than the control group at 18 and 24 months (but not at 6 or 12 months). The only dietary differences found in the other trial81 were that children in the intervention group reported consuming less whole milk and consuming more skim milk and water.

Six trials^78,8–3,85,87^ reported changes in physical activity levels and/or sedentary behavior. Only two reported positive effects.85,87 One of these85 provided organized physical activity sessions during the 3-month intervention and measured the amount of sedentary and physical activity participants reported 1 year later. Groups did not differ in average reduction in amount of screen time per day, but participants in the intervention group reported an average increase of 9.1 weighted metabolic-equivalent (MET) units of habitual activity, compared with a 7.3 unit drop in the control group (p<0.05). The authors did not describe how these data should be interpreted, but in general 1.0 MET is considered a resting metabolic rate, and brisk walking (4.0 miles per hour) is estimated at 5.0 MET.105 This suggests that long-term changes in physical activity can be sustained after only 3 months of intervention, though the magnitude of the change is unclear. The other trial,87 examining the use of a screen time limiting and monitoring device, found no differences in the amount of physical activity, but greater reductions in the target sedentary behaviors of television viewing and computer use. The remaining four trials, which did not show group differences, included one trial targeting physical activity,82 two low-intensity primary care-based trials,81,83 and a small (n=27) low-intensity trial involving weekly brief contact with a case manager which showed mixed results.78

Psychosocial outcomes. Finally, several trials measured psychosocial constructs. The only group differences were found in either of the two trials83,86 reporting on eating disorder pathology are that Doyle and colleagues86 reported reduced levels of shape concern (one of four eating disorder dimensions assessed) in the intervention participants in their trial. Mellin and colleagues104 found reductions in depression scores among intervention participants and no changes in depression scores in control participants. They did not, however, directly test the groups against each other. Also, Mellin and colleagues did not find group differences in change in self-esteem; both groups showed improvement in repeated measures tests.

### Combined Behavioral and Pharmacological Interventions

Sibutramine. Physiological outcomes in the sibutramine trials are also presented in Table 5. Three of the four trials that reported changes in waist circumference found statistically significant differences favoring the sibutramine groups. In these three trials, the sibutramine groups reduced the waist circumference on average by 7 to 8 cm. In contrast, the placebo groups reduced waist circumference on average by 2 to 3 cm (p <0.001 for all three trials). Four trials reported the effects on lipid profiles or glycemic parameters at 6 or 12 months followup. Of these, statistically significant differences were only reported in the large, multi-center that found greater improvements in HDL cholesterol and reductions in triglycerides, serum insulin, and HOMA, compared to the placebo group. Differences in LDL cholesterol and fasting serum glucose were not statistically different between groups.

Orlistat. Chanoine and colleagues93 reported that both waist circumference and hip circumference decreased significantly more in those receiving orlistat and a behavioral intervention, compared with placebo plus behavioral intervention controls at 12 months (p=0.01 for both in least squares mean analysis). The LSM reduction for waist and hip were −2.67 and −1.52 cm, respectively, for the orlistat group, compared with −0.89 and −0.10 cm the control group. In a subset of patients evaluated with dual-energy x-ray absorptiometry (DEXA), patients in the orlistat group lost significantly more fat mass than patients in the placebo group (−2401 g vs. −380 g; p =0.03). In contrast, percent body fat at 6 months was measured using bioelectrical impedance analysis in the Maahs trial, and no statistically significant differences were found between groups. Levels of LDL, HDL, TG, FPG, and insulin were measured in both Orlistat trials, and no significant differences were found between groups in either trial. The Chanoine and colleagues trial, however, reported a small reduction in diastolic blood pressure in the orlistat group (−0.51 mm Hg), compared to an increase in the placebo patients (+1.30 mm Hg; p=0.04). Change in systolic BP was similar in both groups and not statistically different.

Metformin. One of the trials99 found statistically significant improvements favoring the metformin group for waist circumference and subcutaneous adipose tissue, but no difference for visceral abdominal adipose tissue. These parameters were not reported in the other trials. Two trials reported improvements in fasting glucose and insulin, either between groups or only within the metformin group. Neither of these two trials found statistically significant differences between groups for insulin sensitivity when using minimal model analyses, glucose effectiveness, acute insulin response disposition index, or glucose disposal. The third trial found no differences between in fasting glucose, insulin, or 2-hour glucose. One trial reported on lipid parameters and found to be statistically different between groups.98

## KQ1b & KQ2b. Do specific components of the weight management programs influence the effectiveness of the programs?

### Behavioral Interventions

We examined the results of the full group of 13 KQ1 (short-term) and KQ2 (maintenance) trials to identify important components of treatment. Treatment approaches generally focused on making healthy lifestyle improvements, emphasizing healthy eating, and increased physical activity. Specific interventions and the components of treatments, however, were quite heterogeneous (Table 3). For example, participants engaged in organized physical activity sessions as part of the intervention in of five of the trials.77,79,80,85,104 Five additional trials78,81,83,84,86 applied behavioral modification principles to help participants increase their physical activity on their own time. Two trials provided only information and encouragement for physical activity, but did not appear to apply behavioral modification principles.82,103 The final trial87 attempted to increase physical activity indirectly through reducing sedentary behavior.

Many of the trials involved the parents as primary participants in the intervention, in most cases along with the overweight or obese child.^77,7–2,84,85,87,103^ All but one77 of these trials involved children aged 11 years and younger on average. Parental involvement took many forms in these trials, including weight control educational sessions (with or without their overweight child),77,81,82,84,85 family therapy,79,103 or parenting skills training.80 Family involvement in the remaining trials ranged from no involvement to including parents in one to three counseling sessions. The trials with less parent involvement targeted older children, although one included children as young as 7 years old.78

The number of trials was too small to permit quantitative examination of the variation in treatment components through meta-regression. Therefore, we coded three treatment components possibly related to treatment success: the provision of organized physical activity sessions as part of the intervention (shown as “PA+” on Table 3, third column), parental involvement within age groups (“Fam” on Table 3, third column), and the use of behavior modification principles (“BehMod” on Table 3, third column). We then sorted the trials by each of these variables and qualitatively examined the overall patterns of variation in treatment components and their association with statistically significant effects on weight outcomes (see Appendix C Tables -3).

While we discuss our findings from this exercise, they should be considered primarily as hypothesis-generating. The degree of variability among this small number of treatment programs, including important differences in effects due to setting, age, and treatment intensity, greatly limits our ability to examine treatment components. In summary, none of the component clearly improved the chance of showing a positive weight management effect. While organized physical activity sessions did increase the likelihood of treatment success, it was confounded with treatment intensity, and it was therefore impossible to determine whether it was the exercise sessions or the overall intensity of the treatment program that improved the chances of success.

Organized physical activity sessions. Programs that provided organized physical activity sessions (rather than encouraging participants to exercise at home) appeared to be more likely to improve BMI. Group differences were seen in four of five programs with organized physical activity sessions, compared to four of eight programs without organized physical activity sessions. The one trial80 with organized physical activity that did not see beneficial changes in BMI reported greater improvements in other weight and adiposity measures in intervention participants compared with control participants. We did not have sufficient data to determine whether programs with organized physical activity or those that improved physical activity or fitness were more likely to have a positive impact on other health outcomes (such as fasting insulin or blood pressure). The physical activity sessions ranged from seven 1-hour sessions at 2- to 4-week intervals, which consisted of fun, noncompetitive physically active games and activities,80 to twice-weekly 60-minute sessions for 6 months (and bi-weekly sessions for the subsequent 6 months).77 Efforts were generally made to present a variety of enjoyable activities, including team sports, noncompetitive games, dancing, swimming, walking, jogging, and obstacle courses. Two trials80,85 employed activities to help develop motor skills. One trial77 used exercise physiologists to facilitate the exercise sessions and help children maintain a target heart rate of 65 to 80 percent of their age-adjusted maximal heart rate. However, programs offering organized physical activity also tended to be more intensive programs, and therefore it is difficult to determine whether the exercise itself or the generally greater hours of contact that improved the likelihood of success.

Parental involvement. The role of parental involvement in weight management programs can only be considered in the context of the child’s age. None of the three trials that focused on adolescents included parents as the intervention’s primary participants. However, one of the trials104 in adolescents invited parents to one or more intervention sessions, and this trial did show positive weight outcomes. The two remaining trials lacked parental involvement and one83 was successful in improving weight and the other was not.86 Thus, we had insufficient evidence to evaluate whether parental participation increases the likelihood of successful weight loss in adolescents.

All seven of the trials limited to children aged 12 or younger had high levels of parental involvement, as did two of the trials that included both younger children and adolescents. Due to the lack of variability we could not explore the importance of parental involvement further than concluding that weight-loss researchers consider parental involvement crucial for successful weight loss in young children. Parental involvement took many forms in the trials with high levels of involvement. In some trials parents and children attended weight control educational sessions together,81,84,85 while others provided family therapy,79,103 or parenting skills training80 in addition to traditional weight control topics.

Behavior management techniques. The inclusion of behavior management techniques did not clearly have an impact on the probability of effectiveness. Sixty percent of the 10 programs including behavior management techniques had a significant positive treatment effect, as did two (67 percent) of the three trials lacking behavior management techniques. There were too few trials that lacked behavior management techniques, however, to provide confidence in any conclusions regarding the impact of behavioral management techniques on weight outcomes.

### Combined Behavioral and Pharmacological Interventions

Sibutramine. Data were largely insufficient to explore the importance of specific treatment components. Based on the limited number of trials, shorter treatment (3 months, compared with 6 or 12 months) may be related to reduced beneficial effects on BMI. There are other possible explanations for these between trial differences, however, such as lack of placebo run in or differences in population or setting.

Orlistat and Metformin. Data were insufficient to explore the importance of specific treatment components.

## KQ1c & KQ2c. Are there population or environmental factors that influence the effectiveness of the weight management programs?

### Behavioral Interventions

Data were insufficient to explore the importance of population or environmental factors.

### Combined Behavioral and Pharmacological Interventions

Data were insufficient to explore the importance of population or environmental factors.

## KQ3. What are the adverse effects of weight management programs (behavioral, combined behavioral and pharmacological) attempting to stabilize, reduce, or maintain BMI?

### Behavioral Interventions

Summary of Findings. Available evidence suggests little to no harm associated with behavioral weight management interventions (Table 8). Very limited data from one small trial suggests possible increased risk of injury with exercise programs in obese children. Most trials (seven of 13) did not report harms, thus our conclusions about the safety of behavioral weight management interventions with respect to growth, eating disorders, body image, and depression need to be confirmed through further research.

Table 8 Potentially harmful effects of behavioral interventions for childhood overweight

Study Reference | Outcomes of All Potential Harmful Effects Examined
Height
Savoye et al 2007^77^ | No group difference in changes in height at 6 months or 12 months
Golley 2007^80^ | No group difference in changes in height at 12 months
Eating Pathology and Body Image
Saelens et al 2002^83^ | Problematic eating/eating disorder psychopathology did not differ between groups
Doyle et al, unpub;86 | Control group showed greater decline in Shape Concern than Intervention group; no other differences in eating disorder pathology
McCallum et al 2007^81^ | No differences on child-reported ratings of body satisfaction or appearance/self-worth
Other
Mellin et al 1987^104^ | Depression improved in treatment group, did not change in control group.
Supplementary Trials, Injuries Related to Physical Activity
Sung et al 2002^107^ | No training-related injuries. (Ages 8–11, Baseline BMI 25.5)
Davis et al 2006^106^ | 1 bone fracture in exercising group (11 and I2 combined) (Ages 7–11, Baseline BMI 26.5)

Study Details. Six77,80,81,83,86,104 of 13 trials addressing weight outcomes also reported potential harms of behavioral weight management interventions (Table 8). In order to more fully illuminate serious adverse events (i.e., those requiring urgent medical treatment), we eliminated the minimal followup time criterion of 6 months for beneficial outcomes based on the assumption that adverse effects could happen well before a treatment effect is apparent. We also eliminated the requirement that the trial be conducted in a country with a United Nations Human Development Index (HDI) (http://hdrstats.undp.org/indicators/1.html) of >0.90, based on our assumption that cultural conditions are unlikely to affect likelihood of injury. Thus, two additional supplementary trials106,107 reporting on injury rates in exercise programs with obese children were included. These trials did not meet criteria for inclusion for the previous questions because they only reported weight outcomes of less than 6 months, and one was also excluded because it took place in China, which was not on our list of included countries.

We found no evidence that behavioral intervention programs may be harmful, except perhaps mildly increasing injury risk with exercise. Among the eight trials, two77,80 reported no group differences in change in height measured at 10 to 12 months. Three trials81,83,86 reported either favorable or no effects on several measures of eating disorder pathology or body image. One trial104 reported that depression symptomatology improved in intervention group participants, but did not change in the control group, which represents an added benefit rather than an adverse effect. In the two trials examining injuries in exercise programs, Sung and colleagues reported that none of the 41 obese children in their exercise condition were injured, however, one of the 73 obese children in the trial by Davis and colleagues fractured a bone. No children in the control groups of either of these trials reported any injuries.

In addition to the eight trials shown in Table 6, Nemet and colleagues85 reported that no adverse events were noted, but did not describe what events they examined or how they elicited information on adverse events.

### Combined Behavioral and Pharmacological Interventions

Summary of Findings. Over 6 to 12 months, adolescent users of sibutramine or orlistat were no more likely to discontinue treatment due to adverse effects than those on placebo. Serious adverse events were reported in 2.7 percent of sibutramine patients compared with less than 1 percent of placebo patients and in 3 percent of those on orlistat and on placebo. Adolescent sibutramine users were more likely to develop small increases in heart rate, and in some cases, blood pressure, although the clinical significance of these is not clear. Adolescent orlistat users commonly experienced mild-to-moderate gastrointestinal side-effects, with 20 to 30 percent reporting oily spotting, oily evacuation, abdominal pain, fecal urgency or flatus with discharge and 9 percent reporting fecal incontinence. Oily spotting, fatty or oily stools, and cramping improved with time, although fecal incontinence did not. Available data suggests that neither medication adversely affects growth and maturation over the short-term (6 to 12 months), and orlistat does not adversely affect fat-soluble vitamin levels. Trials of metformin reported no serious adverse effects and no abnormalities in serum lactate, liver function or renal function among selected obese children and adolescents after six months of treatment. Twenty-nine percent of patients who took metformin reported some type of gastrointestinal side effect.

Sibutramine. Adverse effects results are reported in Table 5. A more detailed account is included in Appendix B Table 3. All sibutramine trials evaluated the effects on heart rate and systolic and diastolic blood pressure. Three of the five sibutramine trials found statistically greater increases in heart rate and systolic and/or diastolic blood pressure in the sibutramine group compared to the control group after 6 or 12 months of treatment. These differences, however, were small in magnitude. In the 12-month, multi-center sibutramine trial, tachycardia occurred more commonly in the sibutramine than the control group (12.5 percent vs. 6.2 percent, p = 0.049). Withdrawals due to tachycardia, however, were similar between groups.

None of the sibutramine trials reported statistically significant differences between groups in the overall rates of having any adverse event, any serious adverse event, or discontinuation due to adverse events. In the large, 12-month sibutramine trial, serious adverse events were reported by 2.7 percent of patients in the sibutramine group and less than 1 percent of the control group. Only one of these events (excessive nausea and vomiting) was thought to be related to sibutramine. Two trials examined short-term effects on growth and maturation, including the 12-month, multi-center trial. Neither trial found a significant difference between the groups. Abdominal complaints and constipation were also found to be statistically higher in the sibutramine group in the shorter-term trials.

Orlistat. Rates of serious adverse effects and discontinuation of therapy due to adverse effects were low in both trials and were not reported to be statistically different between groups. In the Chanoine and colleagues trial,93 one or more serious adverse effects occurred in 3 percent of both groups. Discontinuation of therapy due to a serious adverse event occurred among 12 of 357 (3 percent) of orlistat patients and three of 182 (2 percent) patients in the placebo group. In the orlistat group, only one event was thought to be study-related— asymptomatic cholelithiasis in a 15-year-old female who had lost 15.8 kg by the time of the event. In the Maahs and colleagues trial,96 two of 20 patients in the orlistat group and zero of 20 patients in the placebo group withdrew from the trial due to adverse effects. One suicide death occurred in the orlistat group to a patient who was under a psychiatrist’s care. No deaths occurred in the placebo group.

Gastrointestinal (GI) side effects were very common among patients taking orlistat. Chanoine and colleagues reported that among patients taking orlistat, 50 percent reported fatty or oily stools compared to 8 percent of those on placebo; 20 to 30 percent reported oily spotting, oily evacuation, abdominal pain, fecal urgency, or flatus with discharge compared to 2 to 11 percent on placebo; and 10 to 15 percent experienced soft stool, nausea, and increased defecation compared to 9 to 13 percent on placebo. Notably, 9 percent of orlistat patients reported fecal incontinence, compared with less than 1 percent of placebo patients. Chanoine and colleagues also reported that the GI side effects were mostly mild- to moderate-intensity and led to discontinuation of treatment among only 2 percent of orlistat patients. In the smaller 6-month orlistat trial, Maahs and colleagues also reported that numerous adverse gastrointestinal effects occurred significantly more frequently in the orlistat group than the placebo group, including: soft stools, oily spotting, fatty or oily stools, oily evacuation, liquid stools, cramping, flatus with discharge, and fecal incontinence. Soft stools, oily spotting, fatty or oily stools, oily evacuation, and liquid stools all occurred in over 50 percent of patients treated with orlistat. Flatus with discharge occurred in 20 to 47 percent of patients treated with orlistat (varying by study month), in contrast to 0 percent in all but the first month for the control group. Fecal incontinence occurred in 6 to 13 percent of the orlistat group at each month, in contrast to 0 percent of the control group during any month. The authors report that the oily spotting, fatty or oily stools, and cramping improved more over time in the orlistat group than in the placebo group.

Both orlistat trials measured vitamin A, D, and E levels and reported that levels were not different between groups. It is important to note, however, that multivitamin supplementation was provided for all participants in the orlistat trials. In the Maahs trial, quality of life measured using four different scales showed no statistically significant differences between groups over time. Possible lack of blinding in the outcome assessors, however, could have influenced these results. No between-group differences in growth, bone mineral density, and sexual maturation were reported.93

Metformin. Trials were limited in their ability to detect adverse effects due to small sample size and limited duration. No trials reported any serious adverse events. One trial specifically reported that no episodes of vomiting or lactic acidosis occurred. Serum lactate, liver, and renal function parameters were reported as remaining normal or not different between groups in two trials.98,98,99,99 The largest of the three trials reported gastrointestinal side effects among 29 percent of patients on metformin compared to 19 percent of those on placebo.100 In the other two trials, some patients were reported to have nausea which, in three cases, required a 25 to 50 percent dose reduction in order to continue in the trial.