# Introduction

## Scope and Purpose

This targeted systematic review was undertaken to assist the United States Preventive Services Task Force (USPSTF) in updating its previous recommendation on screening and interventions for overweight in children and adolescents.1 Based on our previous systematic review in 2005,^2^ the USPSTF found insufficient evidence to recommend screening for overweight, due to uncertainties about the effectiveness of behavior counseling or other interventions with overweight children and adolescents that could be conducted in primary care settings or to which primary care clinicians can make referrals. Given recent work on another systematic review, Effectiveness of Weight Management Programs in Children and Adolescents,3 the USPSTF determined to focus its update on what was considered the critical evidence gap at the time of our last systematic review to allow an efficient and timely updating of their recommendation. Thus, for this targeted updated systematic review, we examine previous and newly available evidence on behavioral^*^ and pharmacological weight management interventions for overweight and/or obese children and adolescents (defined as those between 2 and 18 years of age that meet criteria for increased body mass index [BMI] appropriate to their age and sex) that are relevant to primary care practice. Readers should note that while this current review builds on our previous USPSTF review, it also differs in scope and definitions of overweight and obesity used in that review. Specifically, the USPSTF has decided to upgrade the terminology it uses to define categories of increased BMI (see Table 1) to align its definitions with other major bodies addressing this issue. Attention to these differences in terminology is key, as children and adolescents defined as “overweight” in the 2005 report would now be defined as “obese”.

* Words found in the glossary (located after the text) are italicized on first mention.

Table 1 Definition of overweight and obesity terms for children and adolescents and adults

Current Terminology | Terminology Used in Previous Report | Definition in Children and Adolescents11 | Definition in Adults 115
Overweight | At risk for overweight | 85^th^–94^th^ percentile BMI (age-sex specific) | 25–29 BMI (kg/m^2^)
Obese | Overweight | ≥ 95^th^ percentile BMI (age-sex specific) or BMI ≥ 30 kg/m^2^ | Class I: 30–34.9 BMI (kg/m^2^) Class II: 35.0–39.9 BMI (kg/m^2^) Class III: ≥ 40 BMI (kg/m^2^)
Severe obesity | Not used | > 99^th^ percentile BMI (age-sex specific) | NIH criteria for bariatric surgery:116 >40 BMI (kg/m^2^) or >35 BMI (kg/m^2^) with co-morbidities

And, while the current review is intended to fill the critical evidence gap about intervention effectiveness identified during the 2005 review, our previous review also found that there was insufficient evidence to ascertain the magnitude of the potential harms of screening or intervention. In this targeted update, the USPSTF focused our attention on updating both the benefits and potential harms of primary care feasible interventions, but did not choose to update the evidence on screening benefits or harms. Evidence on the harms as well as benefits of BMI screening programs, along with good data on the diagnostic accuracy of BMI as a measure of obesity in children, still appear to be lacking,4 resulting in arguments against the use of BMI screening of individuals in schools or in other screening programs5,6 that go beyond its use as a tool by clinicians for monitoring growth and development. The previous review also found fair evidence that obese adolescents and children (i.e., those at or above the 95^th^ BMI percentile for age and sex) aged 8 years and older are at increased risk for becoming obese adults. Evidence on the benefits and harms of screening and on the risk of pediatric obesity persisting into adulthood will not be updated in the current review.

Additionally, in keeping with the USPSTF focus on primary and secondary clinical preventive services, surgical treatment of obesity was considered out of scope for this updated review, since surgical treatment is only considered for extremely obese young people, particularly those who are experiencing negative health effects as a result of their obesity necessitating treatment. We therefore focus on behavioral and pharmacological interventions, both of which may be appropriate for less obese or overweight children who would be identified and treated in or in coordination with primary care.

While prevention is a critical component of an overall public health strategy to address the dramatic increase in childhood and adolescent overweight in the United States and elsewhere, recent reviews indicate little empirical evidence of effective interventions for preventing development of overweight in clinical settings and are not included in this report.7,8 Guidance on obesity prevention thereby generally focuses on pragmatic advice for clinicians8,9 or on settings with evidence, as in schools and, to a lesser extent, community settings.9,10 The conceptual integration of preventive programs across clinical and community settings have been addressed by several comprehensive reports elsewhere.11–13

## Background

### Definition and Measurement of Overweight and Obesity in Children and Adolescents

Obesity is a condition of excess body fat (adiposity), which is associated with adverse health states and risk for future disease. Despite their colloquial usage, obesity and overweight represent specific conditions in the medical and scientific literature. While these terms are defined primarily based on health risks in adults, the medical definition of obesity in children and adolescents is not as straightforward. At present, there is no universally accepted definition that distinguishes children with normal or healthy weight from those with unhealthy levels of adiposity. This creates significant problems for clinicians, policy makers, and researchers in that while obesity and its health effects are obvious in some children and adolescents, determining those who face health risks from adiposity when their overweight is less extreme is less apparent. In the absence of a clear, health-based definition of obesity, children are instead categorized as “overweight” and “obese” based on how they compare with a normative sample of children of the same age and sex.

Body mass index (BMI) is the most common measure used to define overweight and obesity in children, adolescents, and adults. BMI is a height-adjusted weight measure that is calculated from measured weight (in kg) and height (in meters) as kilograms divided by meters-squared (kg/m^2^). Clinicians compare a child’s BMI to that of other children of the same age and sex to determine a percentile score based on published norms, such as those developed by the Centers for Disease Control and Prevention (CDC) (see Figures 1 and 2).14 Because BMI naturally changes with age, percentile scores based on age- and sex-specific norms are used to monitor growth and development in children and adolescents. Percentiles are based on population norms, rather than on health status, and those above the 85^th^ or 95^th^ percentile are categorized as having excess weight. Over time, changes in percentile scores can show clearly when a developing child is moving towards becoming fatter or slimmer.15 Thus, while the actual BMI might stay the same or increase in an overweight growing child, a decrease in percentile score would indicate a positive outcome, as growth in height outstripped weight gain. Table 1 shows the BMI-based terms that denote different levels of excess weight in children and adolescents and compares them to terms in adults. Figures 1 and 2 also provide comparisons between various height (inches or centimeters) and weight (pounds and kilograms) measures and absolute BMI, BMI percentiles, and BMI standard deviation scores (SDS).

Figure 1 Illustrative BMI percentile chart with table of weight and BMI standard deviation score for selected percentiles: Boys

This figure depicts a sample growth chart, developed by the Centers for Disease Control and Prevention, for clinicians to use to plot the growth of male children and adolescents ages 2 to 20 years old. At the top of the form is a place to record the patient’s name and record number. Below that is the growth chart, which plots the patient’s body mass index (BMI) by age. The x-axis is age in years, starting at 2 years and progressing to 20 years in increments of 1 year. The y-axis is BMI in kg/m2, starting at 12 kg/m2 and progressing to 35 kg/m2 in increments of 1 kg/m2. Between the ages of 18 and 19 years the chart notes the location of the 5th, 10th, 25th, 50th, 75th, 85th, 90th, and 95th BMI percentiles to allow comparison with other boys of the same age. In the top left of the chart there is a blank table where clinicians can record the date; the patient’s age, weight, height, and BMI; and any comments. Below the growth chart is a table depicting the BMI standard deviation score (SDS) for selected percentiles. For boys aged 8 years old who measure 50.5 in (128.3 cm) tall (50th percentile for height) , the data for the 50th percentile is the following: weight of 57.2 lb (26.0 kg), BMI of 15.8 kg/m2, and a BMI SDS of 0.0. For the 85th percentile: weight of 64.8 lb (29.5 kg), BMI of 17.9 kg/m2, and a BMI SDS of 1.0. For the 95th percentile: weight of 72.4 lb (32.9 kg), BMI of 20.0 kg/m2, and a BMI SDS of 1.6. For boys aged 12 years old who measure 58.5 in (148.6 cm) tall (50th percentile for height), the data for the 50th percentile is the following: weight of 86.5 lb (39.3 kg), BMI of 17.8 kg/m2, and a BMI SDS of 0.0. For the 85th percentile: weight of 102.0 lb (46.4 kg), BMI of 21.0 kg/m2, and a BMI SDS of 1.0. For the 95th percentile: weight of 117.6 lb (53.4 kg), BMI of 24.2 kg/m2, and a BMI SDS of 1.6. For boys aged 16 years old who measure 68.5 in (174.0 cm) tall (50th percentile for height), the data for the 50th percentile is the following: weight of 136.5 lb (62.1 kg), BMI of 20.5 kg/m2, and a BMI SDS of 0.0. For the 85th percentile: weight of 161.2 lb (73.3 kg), BMI of 24.2 kg/m2, and a BMI SDS of 1.0. For the 95th percentile: weight of 183.2 lb (83.3 kg), BMI of 27.5 kg/m2, and a BMI SDS of 1.6.

Figure 2 Illustrative BMI percentile chart with table of weight and BMI standard deviation score for selected percentiles: Girls

This figure depicts a sample growth chart, developed by the Centers for Disease Control and Prevention, for clinicians to use to plot the growth of female children and adolescents ages 2 to 20 years old. At the top of the form is a place to record the patient’s name and record number. Below that is the growth chart, which plots the patient’s body mass index (BMI) by age. The x-axis is age in years, starting at 2 years and progressing to 20 years in increments of 1 year. The y-axis is BMI in kg/m2, starting at 12 kg/m2 and progressing to 35 kg/m2 in increments of 1 kg/m2. Between the ages of 18 and 19 years the chart notes the location of the 5th, 10th, 25th, 50th, 75th, 85th, 90th, and 95th BMI percentiles to allow comparison with other girls of the same age. In the top left of the chart there is a blank table where clinicians can record the date; the patient’s age, weight, height, and BMI; and any comments. Below the growth chart is a table depicting the BMI standard deviation score (SDS) for selected percentiles. For girls aged 8 years old who measure 50.5 in (128.3 cm) tall (50th percentile for height), the data for the 50th percentile is the following: weight of 57.2 lb (26.0 kg), BMI of 15.8 kg/m2, and a BMI SDS of 0.0. For the 85th percentile: weight of 66.3 lb (30.1 kg), BMI of 18.3 kg/m2, and a BMI SDS of 1.0. For the 95th percentile: weight of 75.0 lb (34.0 kg), BMI of 20.7 kg/m2, and a BMI SDS of 1.7. For girls aged 12 years old who measure 59.5 in (151.1 cm) tall (50th percentile for height), the data for the 50th percentile is the following: weight of 90.9 lb (41.3 kg), BMI of 18.1 kg/m2, and a BMI SDS of 0.0. For the 85th percentile: weight of 109.0 lb (49.5 kg), BMI of 21.7 kg/m2, and a BMI SDS of 1.0. For the 95th percentile: weight of 126.6 lb (57.5 kg), BMI of 25.2 kg/m2, and a BMI SDS of 1.6. For girls aged 16 years old who measure 64.0 in (162.6 cm) tall (50th percentile for height), the data for the 50th percentile is the following: weight of 118.7 lb (53.9 kg), BMI of 20.45 kg/m2, and a BMI SDS of 0.0. For the 85th percentile: weight of 143.1 lb (65.0 kg), BMI of 24.6 kg/m2, and a BMI SDS of 1.0. For the 95th percentile: weight of 168.1 lb (76.4 kg), BMI of 28.9 kg/m2, and a BMI SDS of 1.6.

An Expert Committee (A committee convened by the American Medical Association [AMA] and co-funded in collaboration with the Department of Health and Human Services’ Health Resources and Services Administration [HRSA] and the CDC) recently recommended a change to the terminology used to define overweight and obesity in children, while retaining the same percentile cutoffs (Table 1).11 The group now recommends using the term “overweight” to refer to children aged 2 to 18 years with BMI in the 85^th^ to 94^th^ percentiles for their age and sex. They recommend the term “obese” to refer to children with BMI at or above the 95^th^ percentile for their age and sex or with a BMI at or above 30, which is the adult standard for defining obesity and may apply to older adolescents.11 The 95^th^ percentile curve for adolescents does not exactly match up with the BMI definition in adults because the adolescent curve is norm-based but the adult cut-off is not. Therefore, the alternate specification of having a BMI at or above 30 is added to the definition for children and adolescents to ensure consistency as adolescents mature into the adult norms.

Although it is not a direct measure of adiposity, BMI-for-age percentile measures in boys and girls correlate reasonably well with percentile rankings of directly measured percent body fat (correlations generally between 0.78 to 0.88).16 Obesity (primarily defined as BMI ≥ 95^th^ percentile) has also been correlated with childhood health consequences and risk factors for obesity-related morbidity in adults.17–19 This relationship is complicated, however, by the fact that obesity may not persist into adulthood in as many as half of obese 10 year-olds, and obesity that does not persist has little impact on adult health outcomes.20 And, since BMI is an imperfect measure of body fat, categorizing individual children and adolescents as obese based on BMI definitions can be problematic;5 this may be particularly the case for non-white children who are less represented in the populations underlying CDC norms.21 and who may also differ in normal body composition, growth, or development.2 Recent data from the Bogalusa Heart Study found that 35 percent of children aged 5 to17 years with BMI ≥ 95^th^ percentile did not have excess body fat.22 However, almost all (94 percent) of those at or above the 99^th^ percentile had excess body fat. Those with the highest BMI percentiles (≥99^th^) were also much more likely to have two or more cardiovascular risk factors (59 percent), compared with those in the broader group at or above the 95^th^ percentile (39 percent with two or more risk factors). Noting these differences, experts have recently proposed distinguishing the “severely obese,” defined by the 99^th^ percentile, as those in particular need of clinical evaluation and treatment.

Since no measure is ideal for every age or degree of weight, many youth obesity researchers report multiple measures, including BMI, BMI percentiles, proportion change in BMI (BMI percentage), or BMI standard deviation scores (also known as BMI z-scores or zBMI), or an older measure, “percent overweight.” Among these BMI measures, absolute BMI or BMI percentage may be preferable for measuring adiposity change in individual children.15 For more detail on these measures see Appendix A, Detailed Methods, Literature Synthesis.

### Prevalence of Children and Adolescent Obesity in the United States

Childhood and adolescent obesity has increased substantially during the past three decades. Between the early 1970s and 2003 to 2004, the prevalence of child and adolescent obesity (defined as age- and sex-specific BMI ≥ 95^th^ percentile) increased three- to six-fold, depending on age, sex, and ethnicity.23 During the most recent 2 years, the prevalence plateaued among all gender, racial/ethnic, and age sub-groups.24 Updated prevalence figures (2003 through 2006) suggest approximately 12 to 18 percent of 2- to 19-year-old children and adolescents are obese.24–26

Obesity prevalence varies somewhat with age and tends to be higher in older children, in males, and in racial and ethnic minorities. Children and adolescents aged 6 to 19 years had a higher prevalence of obesity (17 to 18 percent) than younger children aged 2 to 5 years (12.4 percent), according to data from the 2003 to 2006 National Health and Nutritional Evaluation Survey (NHANES).24 Additionally, males had slightly higher prevalence of obesity for all age categories than females. When overweight (defined as age- and sex-specific BMI in the 85^th^ to 94^th^ percentile) children and adolescents were included, between one in three and one in four children and adolescents were identified as overweight or obese (24 to 34 percent).23,24,26 Looking at the youth with the most severe levels of obesity, 3 to 6 percent of boys aged 13 to 17 years were at or above the 99^th^ percentile. The comparable figure for girls was 1 to 3 percent.22 Other researchers have used the 97^th^ percentile as a cut point for measuring high BMI for age. Using that approach, 9 to 14 percent of boys and 8 to 11 percent of girls aged 2 to 19 years had a BMI at or above the 97^th^ percentile.24 See Table 2 for BMI and weight measures at median, overweight, obese and very obese BMI percentiles for boys and girls of several ages.

Table 2 BMI (kg/m^2^) at 50^th^, 85^th^, 95^th^, and 99^th^ percentiles and weight in pounds for BMI (kg/m^2^) of 25, 30, 35, and 40 at ages 8, 12, and 16 years

| | BMI (kg/m^2^) at percentiles^*^ Children and adolescents | | | | Weight (lbs) at Adult BMI cut-points^**^
| 50^th^ Percentile for Height | | Over-weight | Obesity | Severe Obesity | Over-weight | Obesity Class I | Obesity Class II | Obesity Class III
Age (Sex) | inches | 50th | 85th | 95th | 99th | 25 | 30 | 35 | 40
8 (Male) | 50.5 | 15.8 | 17.9 | 20.0 | 25.6 | 91 | 109 | 127 | 145
8 (Female) | 50.5 | 15.8 | 18.3 | 20.7 | 26.4 | 91 | 109 | 127 | 145
12 (Male) | 58.5 | 17.8 | 21.0 | 24.2 | 31.8 | 122 | 146 | 170 | 195
12 (Female) | 59.5 | 18.1 | 21.7 | 25.2 | 33.1 | 126 | 151 | 176 | 201
16 (Male) | 68.5 | 20.5 | 24.2 | 27.5 | 33.9 | 167 | 200 | 234 | 267
16 (Female) | 64 | 20.4 | 24.6 | 28.9 | 39.1 | 146 | 174 | 204 | 233

* Estimated average height for age from 50^th^ percentile on CDC Growth Chart “Stature-for-age percentiles: Boy (or Girls), 2 to 20 years”.

** Pounds = (BMI × inches2)/703 was used to convert from BMI to pounds.

### Risk Factors for Child and Adolescent Obesity and Overweight

While childhood and adolescent obesity has increased across the US population as a whole, minority children and adolescents in the US suffer obese and overweight disproportionately at all ages.23 A recent, large, nationally representative study using NHANES data found that 23 percent of Mexican-American boys aged 2 to 19 years were obese, which was significantly higher than nonHispanic White (16 percent) and nonHispanic Black (17 percent) boys in the same age range.24 Native American boys were also more likely to be obese—39 percent of Native American adolescent boys in the National Longitudinal Study of Adolescent Health (Add Health) were categorized as obese in the mid-1990s, compared with 10 to 15 percent among other ethnic groups.27 Among girls in the NHANES study, prevalence of obesity in 2- to 19- year-olds was highest among nonHispanic Black girls (24 percent), followed by Mexican American (18 percent) and then nonHispanic White girls (14 percent).24 These racial/ethnic disparities are consistent with prevalence figures reported by the Add Health study, which reported higher proportions of obesity in Black (18 percent), Hispanic (13 percent), and Native American (14 percent) adolescent girls, compared with Asian (4 percent) and nonHispanic White girls (10 percent).27 Statistical tests of these differences, however, were not reported. Racial differences were also apparent in the persistence of obesity into adulthood among children and adolescents aged 5 to 14 years. One study found that among a mixed aged group (5 to 14 years), 65 percent of obese White girls and 84 percent of obese Black girls remained obese into adulthood, with similar results for obese boys (71 percent of White boys versus 82 percent of Black boys).28

Disparities in obesity prevalence are also apparent along socio-economic lines. There is a clear inverse correlation between income level and obesity prevalence in nonHispanic White children and adolescents. Obesity prevalence is highest in the lowest income bracket, and those with the highest income levels have the lowest obesity prevalence.29 This inverse correlation is less clear for Black and Hispanic ethnic groups, however, since data on the relationship between income and obesity are mixed.29

Parental obesity is also an important risk factor. Children of obese parents have a higher risk of obesity,30 with children of two obese parents having the highest risk of obesity.31 A large-scale epidemiological study published in 1976 found that by age 17, children with two obese parents had three times larger triceps skinfold measures as those with two lean parents.31 Compared to children without obese mothers, children with obese mothers are three to ten times more likely to be obese themselves. White and Black children of obese mothers are three times more likely to be obese, Hispanic children of obese mothers are twice as likely to be obese, and Asian children of obese mothers may be as much as ten times more likely to be obese.32 In addition, maternal obesity has been associated with earlier age of obesity onset in children of the affected mothers.32

Comprehensive reviews have identified additional risk factors, some of which are modifiable (e.g., levels of physical activity and sedentary behavior, consumption of sweetened soft drinks or energy dense food, birth weight) and some of which are not (e.g., genetic variants, rate of maturation).33–36 Modifiable factors are often the target of intervention. Non-modifiable risk factors, such as those highlighted here, may indicate a need to tailor a treatment approach, or a need for special recruitment efforts to increase participation in treatment programs in some high risk groups.

### Prevalence and Burden of Illness

There is growing evidence that childhood and adolescent obesity can have a substantial health impact.17,19 Causal relationships are difficult to establish, however, as the data on the health and psychosocial consequences of obesity in children and adolescents are almost exclusively observational. Observational data do show some important consistent relationships, however, between childhood obesity and specific health problems. For example, while most children will not experience the health consequences of persistent childhood obesity for decades, data suggest that some of these consequences can occur prior to adulthood, particularly in those who are severely obese.19 Obese children and adolescents have a higher risk of type 2 diabetes mellitus, asthma, and nonalcoholic fatty liver disease, are more likely to have cardiovascular risk factors, such as hypertension and hyperlipidemia. These children and adolescents are also more likely to experience other adverse health-related events, such as perioperative adverse respiratory events when undergoing procedures requiring anesthesia.17,19,37 Obese children may also be more likely to experience mental health and psychological issues, such as depression38 and low self-esteem,19,38,39 than nonobese children. The risk of mental health issues increases with age and is higher in girls,17 likely reflecting the pressures of the social environment. For severely obese children, impacts on quality of life can be severe and other serious conditions such as obstructive sleep apnea, orthopedic problems, infertility, and increased intracranial pressure can occur.17,19,40,41

These increased health risks, however, do not necessarily lead to increased expenditures. Despite higher prevalence of health problems in obese children, actual health care expenditures paid by families (including costs of services, devices, and insurance) do not differ between healthy weight and overweight or obese children, when models are adjusted for age, gender, race, poverty status, and insurance type.42 The authors of the study examining these models hypothesize that there are unmet healthcare needs among obese children, who are disproportionably low-income.

Costs incurred during childhood and adolescence however, may not give us a full representation of obesity’s true impact. One of the greatest concerns about childhood obesity is that it may persist into adulthood.43 Adult obesity, in turn, has a detrimental effect on adult health9,44,45 and mortality.44,46 Other systematic reviews have examined the persistence of obesity from childhood into adulthood.2 Factors associated with greater persistence of obesity from childhood into young adulthood included older age and higher BMI (above the 95^th^ percentile or higher). Recent data from the Bogalusa Heart Study confirm these findings.43

Even though it is difficult to disentangle childhood obesity’s effects on morbidity and mortality from the effect of adult obesity, a systematic review reporting on the long-term consequences of pediatric obesity concluded that obesity-related cardiovascular disease can originate in childhood obesity.17 This review, and others, indicate that childhood obesity has also been associated with adverse social and economic outcomes in young adulthood,17,19,47 although childhood obesity in the absence of adult obesity appears to have little impact on adult socioeconomic, educational, social and psychological outcomes.20 Much more research is needed to determine long-term health effects of childhood and adolescent obesity independent of adult obesity.

### Current Interventions for Child and Adolescent Obesity and Overweight

Behavioral Intervention. Behavioral interventions are the most widely used and studied interventions for childhood overweight and obesity. Behaviorally-based interventions promote weight loss through modifications in diet and activity level without the use of adjuncts, such as pharmacologic agents, and are the first-line treatment for overweight and obesity in children and adolescents.40 Typical behavioral interventions are designed to modify an individual’s food consumption by emphasizing healthy eating and reducing consumption of high-calorie/low-nutrient snack foods. A range of approaches have been used to encourage more healthy patterns of dietary intake and physical activity, which are discussed in detail elsewhere.11,40,48 Behavioral interventions often involve parents or entire families, particularly for younger children. Optimally, behavioral interventions include cognitive and behavioral management techniques to help participants initiate and sustain needed lifestyle changes, and may include elements such as problem solving, limiting exposure to unhealthy food, healthy thinking about food and the body, and relapse prevention.40,48 We refer to programs that focus on dietary counseling and brief lifestyle change advice without more extensive use of behavioral management principles as “brief behaviorally-based counseling” interventions. We use the term “behavioral management intervention” to denote more extensive programs that include principles of cognitive and/or behavioral management. We use the term “behavioral intervention” to refer to both behavioral counseling and management interventions.

Pharmacologic treatment. Pharmacological agents represent another intervention for childhood obesity. Weight loss drugs can be divided into two main categories based on their putative mechanism of action—appetite suppressants and lipase inhibitors. Orlistat is currently the only drug that the United States Food and Drug Administration (FDA) has approved for prescription use in obese children and adolescents (aged 12 and older).49 Orlistat is a lipase inhibitor that is thought to promote weight loss by reversibly binding to the active center of the enzyme lipase, preventing digestion and absorption of some dietary fats. It also reduces the absorption of fat-soluble vitamins. In 2007, the FDA approved orlistat for over-the-counter use among adults aged 18 years and older.50

Sibutramine is a centrally acting appetite suppressant that selectively inhibits the reuptake of serotonin and norepinephrine, increasing their levels in the brain. Sibutramine has been approved by the FDA for treating obesity in adults, and its labeling indicates that safety and effectiveness is not established in pediatric patients under 16 years of age.51 Sibutramine and orlistat are the two most well-studied weight loss drugs among adults. Several other appetite suppressants are FDA-approved only for short-term treatment of overweight adults (benzphetamine, diethylpropion, phendimetrazine, and phentermine).52 These drugs are all structurally similar to amphetamine and pose a theoretical risk for abuse and addiction.53 Two other amphetamine-like drugs that were widely used during the 1990’s, fenfluramine and its active isomer dexfenfluramine, were implicated in unusual cases of left-sided cardiac valve degeneration and were taken off of the market in 1997.^53^ Additional drugs that are not FDA-approved for treating overweight or obesity have been considered as potential weight loss agents, such as some antidepressants (fluoxetine, sertraline, and bupropion), antiepileptic drugs (topiramate, zonisamide, lamotrigine), and the antidiabetic biguanide metformin.52

A recent systematic evidence review found that numerous different drugs produced modest weight loss among adults when combined with dietary recommendations: sibutramine, orlistat, phentermine, bupropion, fluoxetine, topiramate, and probably diethylpropion.54 The review found that additional weight loss attributable to these drugs was less than 5 kg at 1 year. The drugs were not compared directly against each other, however, and the report found no evidence that any particular drug produced more weight loss than any other. All of the drugs had side effects. Sibutramine was associated with modest increases in heart rate and blood pressure and with preventing decreases in blood pressure that may have occurred with weight loss. Orlistat was associated with numerous gastrointestinal side effects such as diarrhea, flatulence, bloating, abdominal pain, and dyspepsia.

### Factors Contributing to the Recent Increase in Childhood Obesity

While many experts have speculated on the causes of the recent increases in childhood obesity,55,56 data are not available to conclusively determine causality. Evidence does support the relationship between childhood obesity and several lifestyle factors, however, such as overall physical activity, sedentary behaviors, and intake of sweetened beverages.40 These and other factors, such as self-reported dieting to lose weight (particularly unsupervised, drastic, and/or inconsistent efforts using unhealthy weight loss approaches), are also associated with persistence of obesity between adolescence and adulthood.57,58 Children (ages 2 to 17) averaged 4.7 hours per day of “screen time” (e.g., television and computer use),59 and cross-sectional data show that higher prevalence of obesity is associated with more hours per day watching television.60,61 Likewise, an obesity prevention program that reduced screen time by an average of almost 10 hours per week also resulted in a BMI reduction of 0.45 kg/m^2^ in sample of 3^rd^ and 4^th^ grade school children.62

Environmental factors also likely reduce children’s physical activity. In 1969, for example, 42 percent of children walked or rode their bikes to school. By 2001 this number had fallen to 16 percent.63 Enrollment in physical education classes has declined from 41.6 percent in 1991 to 28.4 percent in 2003 in high school students.64 These figures are especially poignant given that longitudinal and cross-sectional observational data have demonstrated that higher levels of physical activity tend to be associated with lower BMIs in children.60,65 In one study, for example, an increase in 1 hour/day of physical activity was associated with a BMI decrement of 0.22 kg/m^2^ in boys and 0.16 kg/m^2^ in girls after 1 year.65

Intake of sweetened beverages has also increased and appears to contribute to childhood obesity.40,66–68 Between the late 1970s and the late 1990s, average daily intake of sweetened beverages increased from 5 ounces to 12 ounces in 6 to 17 year-olds.68 This 7 ounce daily increase is especially troubling given that BMI increases by an estimated 0.01 kg/m^2^ with every 100 grams of regular soda consumed daily in adolescent girls.66 Stated more clearly, the odds of obesity increase by 60 percent with each additional daily serving of sugar-sweetened soda a child consumes.69

### Previous USPSTF Recommendation

In 2005, the USPSTF concluded that the evidence was insufficient to recommend for or against routine screening for overweight in children and adolescents as a means to prevent adverse health outcomes (“I” Recommendation). This recommendation was based on the conclusion that while there was fair evidence that overweight adolescents and children aged 8 years and older are at increased risk for becoming obese adults, there was insufficient evidence for the effectiveness of behavioral counseling or other preventive interventions with overweight children and adolescents that could be conducted in primary care settings or to which primary care clinicians can make referrals. The previous report also concluded that there was insufficient evidence to ascertain the magnitude of the potential harms of screening or prevention and treatment interventions.