Table 1 Behavioral intervention trials, sorted by the presence of organized physical activity

Study Reference | Age Range (Mean) N | Treatment Hours | PA+ | Fam | Age Grp | Beh Mod
Savoye et al 2007^77^ | 8–16 (12.1) n=174 | 97.5 | 1 | 2 | B | 1
Reinehr et al 2006^79^ | 6–14 (10.4) n=240 | 76 | 1 | 2 | B | 1
Nemet et al 2005^85^ | Avg age 11.1 n=54 | 35.75 | 1 | 2 | C | 1
Mellin et al1987^104^ | 12–18 (15.6) n=66 | 24 | 1 | 1 | A | 1
Golley 2007^80^ | 6–9 (8.2) n=111 | 22 | 1^*^ | 2 | C | 1
Flodmark et al, 1993^103^ | 10–11 (Avg NR) n=93 | 24 | 0 | 2 | C | 0
Rooney 2005^82^ | 5–12 (9.7) n=98 | 21 | 0 | 2 | C | 0
Celio/Doyle et al 2007^88^ | 12–18 (14.5) n=43 | 16 | 0 | 0 | A | 1
Senediak et al 1985^84^ | 6–12 (10.3) n=45 | 12 | 0 | 2 | C | 1
Gillis 2007^78^ | 7–16 (10.6) n=27 | 8 | 0 | 1 | B | 1
McCallum et al, 2007^81,90^ | 5–9 (7.4) n=163 | 4 | 0 | 2 | C | 1
Saelens et al 2002^83^ | 12–16 (14.2) n=44 | 3.8 | 0 | 0 | A | 1
Epstein et al 2008^87^ | 4–7 (5.9) N=70 | (very low) | 0 | 2 | C | 0

* Organized physical activity in only one of two treatment arms

Note: Grayed interventions show statistically significant weight benefits compared with controls. PA=Physical Activity (1=included organized PA sessions, 0=no organized PA session) Fam=Family Involvement (2=parent a primary participant, 1=parent invited to 1–3 treatment sessions, 0=minimal parental involvement)

Age Grp=Age Group (A=adolescent, exclusively aged 10 and older; B=age spans younger children and adolescents; C=exclusively aged 12 and younger)

Beh Mod=Behavior Modification (1=Behavior modification employed, 0=not employed)

Table 2 Behavioral intervention trials, sorted by family involvement, within age group

Study Reference | Age Range (Mean) N | Treatment Hours | PA | Fam | Age Grp | Beh Mod
Mellin et al1987^104^ | 12–18 (15.6) n=66 | 24 | 1 | 1 | A | 1
Celio/Doyle et al 2007^88^ | 12–18 (14.5) n=43 | 16 | 0 | 0 | A | 1
Saelens et al 2002^83^ | 12–16 (14.2) n=44 | 3.8 | 0 | 0 | A | 1
Savoye et al 2007^77^ | 8–16 (12.1) n=174 | 97.5 | 1 | 2 | B | 1
Reinehr et al 2006^79^ | 6–14 (10.4) n=240 | 76 | 1 | 2 | B | 1
Gillis 2007^78^ | 7–16 (10.6) n=27 | 8 | 0 | 1 | B | 1
Nemet et al 2005^85^ | Avg age 11.1 n=54 | 35.75 | 1 | 2 | C | 1
Golley 2007^80^ | 6–9 (8.2) n=111 | 22 | 1^*^ | 2 | C | 1
Flodmark et al, 1993^103^ | 10–11 (Avg NR) n=93 | 24 | 0 | 2 | C | 0
Rooney 2005^82^ | 5–12 (9.7) n=98 | 21 | 0 | 2 | C | 0
Senediak et al 1985^84^ | 6–12 (10.3) n=45 | 12 | 0 | 2 | C | 1
McCallum et al, 2007^81,90^ | 5–9 (7.4) n=163 | 4 | 0 | 2 | C | 1
Epstein et al 2008^87^ | 4–7 (5.9) N=70 | (very low) | 0 | 2 | C | 0

* Organized physical activity in only one of two treatment arms

Note: Grayed interventions show statistically significant weight benefits compared with controls. PA=Physical Activity (1=included organized PA sessions, 0=no organized PA session) Fam=Family Involvement (2=parent a primary participant, 1=parent invited to 1–3 treatment sessions, 0=minimal parental involvement)

Age Grp=Age Group (A=adolescent, exclusively aged 10 and older; B=age spans younger children and adolescents; C=exclusively aged 12 and younger)

Beh Mod=Behavior Modification (1=Behavior modification employed, 0=not employed)

Table 3 Behavioral intervention trials, sorted by the presence of behavioral management techniques

Study Reference | Age Range (Mean) N | Treatment Hours | PA | Fam | Age Grp | Beh Mod
Savoye et al 2007^77^ | 8–16 (12.1) n=174 | 97.5 | 1 | 2 | B | 1
Reinehr et al 2006^79^ | 6–14 (10.4) n=240 | 76 | 1 | 2 | B | 1
Nemet et al 2005^85^ | Avg age 11.1 n=54 | 35.75 | 1 | 2 | C | 1
Mellin et al1987^104^ | 12–18 (15.6) n=66 | 24 | 1 | 1 | A | 1
Golley 2007^80^ | 6–9 (8.2) n=111 | 22 | 1^*^ | 2 | C | 1
Celio/Doyle et al 2007^88^ | 12–18 (14.5) n=43 | 16 | 0 | 0 | A | 1
Senediak et al 1985^84^ | 6–12 (10.3) n=45 | 12 | 0 | 2 | C | 1
Gillis 2007^133^ | 7–16 (10.6) n=27 | 8 | 0 | 1 | B | 1
McCallum et al, 2007^81,90^ | 5–9 (7.4) n=163 | 4 | 0 | 2 | C | 1
Saelens et al 2002^83^ | 12–16 (14.2) n=44 | 3.8 | 0 | 0 | A | 1
Flodmark et al, 1993^103^ | 10–11 (Avg NR) n=93 | 24 | 0 | 2 | C | 0
Rooney 2005^82^ | 5–12 (9.7) n=98 | 21 | 0 | 2 | C | 0
Epstein et al 2008^87^ | 4–7 (5.9) N=70 | (very low) | 0 | 2 | C | 0

* Organized physical activity in only one of two treatment arms

Note: Grayed interventions did not show statistically significant weight benefits compared with controls. PA=Physical Activity (1=included organized PA sessions, 0=no organized PA session) Fam=Family Involvement (2=parent a primary participant, 1=parent invited to 1–3 treatment sessions, 0=minimal parental involvement)

Age Grp=Age Group (A=adolescent, exclusively aged 10 and older; B=age spans younger children and adolescents; C=exclusively aged 12 and younger)

Beh Mod=Behavior Modification (1=Behavior modification employed, 0=not employed)